# Appendix D U.S. Preventive Services Task Force Quality Rating Criteria

## Randomized, Controlled Trials and Cohort Studies Criteria

- Initial assembly of comparable groups
- RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

## Definition of Ratings Based on Above Criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor:: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

## Diagnostic Accuracy Studies

Criteria:

- Participant selection
- Index tests
- Reference standard
- Flow and timing
- Concerns about applicability

Definition of ratings based on above criteria:

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients
Poor:: Has a fatal flaw, such as using inappropriate reference standard, improperly administering screening test, using biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VI

https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

Harris et al, 2001^47^

Appendix D Table 1 Quality Assessment of Diagnostic Accuracy Studies based on the QUADAS-2 Tool

| Risk of Bias | | | | Concerns About Applicability | | | Quality Rating
Author, Year | Participant Selection | Index Tests | Reference Standard | Flow and Timing | Participant Selection | Index Tests | Reference Standard
Hamdani et al, 2018^6^ | Unclear | Low | Unclear | Low | High | Low | Low | Fair

Abbreviation: QUADAS=Quality Assessment of Diagnostic Accuracy Studies.

Appendix D Table 2 Quality Assessment of Interventional Studies

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition and withdrawals reported? | Loss to followup: differential/high? | Intention-to-Treat Analysis | Quality Rating
Batisky et al, 2007^76^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Differential: unclear; High overall: no | Yes | Fair
Berenson et al, 1983,^89^ | Unclear | Unclear | No | Yes | Unclear | No | No | Yes | Differential: no; High overall: yes | Yes | Fair
Couch et al, 2008^90^ | Unclear | Unclear | Yes | Yes | Yes | Not applicable | Not applicable | Yes | Differential: no; High overall: no | Yes | Fair
Ewart et al, 1987^95^ | Unclear | Unclear | Yes | Yes | Yes | Not applicable | Not applicable | Yes | Differential: no; High overall: yes | No | Fair
Flynn et al., 2004^88^ | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Yes | Differential: unclear; High overall: no | No | Fair
Hansen et al, 1991^92^ | Unclear | Unclear | Yes | Yes | Unclear | Not applicable | Not applicable | Yes | Differential: no; High overall: no | Unclear | Fair
Hazan et al, 2010^85^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Differential: no; High overall: no | Yes | Fair
Howe et al, 1991^93^ | Unclear | Unclear | Yes | Yes | Unclear | Not applicable | Not applicable | Yes | Differential: no; High overall: no | No | Fair
Li et al, 2004^81^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | Differential: unclear; High overall: yes | Unclear | Fair
Li et al, 2010^86^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | No | Differential: no; High overall: no | Yes | Fair
Shahinfar et al, 2005^84^ | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Yes | Differential: no; High overall: no | Yes | Fair
Sinaiko et al, 1993^94^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | No | Differential: unclear; High overall: unclear | No | Fair
Soffer et al., 2003^83^ | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Yes | Differential: no; High overall: no | Yes | Fair
Son et al, 2017^91^ | Yes | Yes | Yes | Yes | Unclear | Not applicable | Not applicable | Yes | Differential: no; High overall: no | Yes | Fair
Sorof et al, 2002^80^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | Differential: unclear; High overall: yes | No | Fair
Trachtman et al, 2003^78^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | Differential: unclear; High overall: no | Unclear | Fair
Trachtman et al, 2008^77^ | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Yes | Differential: no; High overall: no | Yes | Fair
Wells et al, 2002^82^ | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Yes | Differential: unclear; High overall: no | Yes | Fair
Wells et al, 2010^79^ | Yes | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | Differential: no; High overall: yes | Yes | Fair
Wells et al, 2011^87^ | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Differential: no; High overall: no | Yes | Fair

Appendix D Table 3 Quality Assessment of Meta-Analyses

Author, Year | Concerns regarding specification of study eligibility criteria | Concerns regarding methods used to identify and/or select studies | Concerns regarding methods used to collect data and appraise studies | Concerns regarding the synthesis | Did the interpretation of findings address all of the concerns identified in Domains 1 through 4? | Was the relevance of identified studies to the review’s research question appropriately considered? | Did the reviewers avoid emphasizing results on the basis of their statistical significance? | Risk of bias in the review
Burrello et al, 2019^75^ | Some concerns | Low | Low | Some concerns | Some concerns | Probably yes | Probably yes | Fair