# Appendix C Excluded Studies

List of Exclusion Codes:

X1 Wrong language
X2 Not original research
X3 Wrong population
X4 Wrong study design
X5 Wrong geographic setting
X6 Wrong clinical setting
X7 Wrong or no intervention
X8 Wrong or no comparator
X9 Wrong or no outcome
X10 Abstract only
X11 Duplicate or superseded
X12 Other

1 Abbey LM. Screening for hypertension in the dental office. J Am Dent Assoc. 1974;88(3):563–7. Exclusion Code: X3.4521264
2 Adeniran SA, Toriola AL. Effects of different running programmes on body fat and blood pressure in schoolboys aged 13-17 years. J Sports Med Phys Fitness. 1988;28(3):267–73. Exclusion Code: X3.3068419
3 Ahern D, Dixon E. Pediatric hypertension: a growing problem. Prim Care. 2015 Mar;42(1):143–50. doi: 10.1016/j.pop.2014.09.003. PMID: 25702741. Exclusion Code: X2.25634711
4 Ahrens W, Moreno LA, Marild S, . Metabolic syndrome in young children: definitions and results of the IDEFICS study. Int J Obes (Lond). 2014 Sep;38: Suppl 2:S4–14. doi: 10.1038/ijo.2014.130. PMID: 25009219. Exclusion Code: X7.25376220
5 Ajala O, Mold F, Boughton C, . Childhood predictors of cardiovascular disease in adulthood. A systematic review and meta-analysis. Obes Rev. 2017;18(9):1061–70. doi: 10.1111/obr.12561. Exclusion Code: X9.28545166
6 Ambrosio GB, Dissegna L, Zamboni S, . Psychological effects of hypertension labelling during a community survey. A two-year follow-up. J Hypertens. 1984;2(3):S171–3. Exclusion Code: X3.
7 Anandi VS, Shaila B. Evaluation of factors associated with elevated newborn 17-hydroxyprogesterone levels. J Pediatr Endocrinol Metab. 2017 May 24;30(6):677–81. doi: 10.1515/jpem-2016-0459. PMID: 28489558. Exclusion Code: X2.28489558
8 Bachmann H. Propranolol versus chlorthalidone-a prospective therapeutic trial in children with chronic hypertension. Helv Paediatr Acta. 1984;39(1):55–61. Exclusion Code: X8.6373679
9 Bagga A, Mudigoudar BD, Hari P, . Enalapril dosage in steroid-resistant nephrotic syndrome. Pediatr Nephrol. 2004;19(1):45–50. doi: 10.1007/s00467-003-1314-y. PMID: 14648339. Exclusion Code: X3.14648339
10 Baker-Smith CM, Flinn SK, Flynn JT, . Diagnosis, evaluation, and management of high blood pressure in children and adolescents. Pediatrics. 2018;142(3) doi: 10.1542/peds.2018-2096. Exclusion Code: X7.
11 Baker-Smith CM, Flynn JT, Kaelber DC. Systematic reviews: a small fraction of the evidence used to generate the 2017 clinical pediatric hypertension clinical practice guideline. J Hypertens. 2019;37(2):451–2. doi: 10.1097/HJH.0000000000001997. Exclusion Code: X2.30640876
12 Barba G, Buck C, Bammann K, . Blood pressure reference values for European non-overweight school children: the IDEFICS study. Int J Obes (Lond). 2014 Sep;38: Suppl 2:S48–56. doi: 10.1038/ijo.2014.135. PMID: 24711519. Exclusion Code: X9.25219411
13 Batisky DL. Obesity and the role of lifestyle and dietary intervention in the management of pediatric hypertension. J Med Liban. 2010 Jul–Sep;58(3):171–4. PMID: 21462848. Exclusion Code: X2.21462848
14 Beck DT, Martin JS, Casey DP, . Exercise training reduces peripheral arterial stiffness and myocardial oxygen demand in young prehypertensive subjects. Am J Hypertens. 2013 Sep;26(9):1093–102. doi: 10.1093/ajh/hpt080. PMID: 24020971. Exclusion Code: X3.23736111
15 Becque MD, Katch VL, Rocchini AP, . Coronary risk incidence of obese adolescents: reduction by exercise plus diet intervention. Pediatrics. 1988;81(5):605–12. Exclusion Code: X4.3357722
16 Bedra M, Finkelstein J. Introducing home blood pressure telemonitoring for children with hypertension. Stud Health Technol Inform. 2015;216:889. PMID: 25432895. Exclusion Code: X3.26262191
17 Beilan JA, Lawton A, Hajdenberg J, . Pheochromocytoma of the urinary bladder: a systematic review of the contemporary literature. BMC Urol. 2013 Apr 29;13:22. doi: 10.1186/1471-2490-13-22. PMID: 28520538. Exclusion Code: X3.23627260
18 Berenson GS. The control of hypertension in African-American children: the Bogalusa Heart Study. J Natl Med Assoc. 1995;87:(8 Suppl):614–7. Exclusion Code: X2.7674355
19 Betz HH, Eisenmann JC, Laurson KR, . Physical activity, BMI, and blood pressure in US youth: NHANES 2003-2006. Pediatr Exerc Sci. 2018 Aug 1;30(3):418–25. doi: 10.1123/pes.2017-0127. PMID: 29907703. Exclusion Code: X3.29543117
20 Bharath LP, Choi WW, Cho JM, . Combined resistance and aerobic exercise training reduces insulin resistance and central adiposity in adolescent girls who are obese: randomized clinical trial. Eur J Appl Physiol. 2018 Aug;118(8):1653–60. doi: 10.1007/s00421-018-3898-8. PMID: 30137127. Exclusion Code: X3.29846794
21 Binka E, Mendley S, Gaskin P, . Description of antihypertensive medication use in a pediatric practice: single and multiple antihypertensive medication therapy. J Clin Hypertens (Greenwich). 2017 Jan;19(1):90–7. doi: 10.1111/jch.12879. PMID: 27697752. Exclusion Code: X4.27481566
22 Bloetzer C, Bovet P, Paccaud F, . Performance of targeted screening for the identification of hypertension in children. Blood Press. 2017 Apr;26(2):87–93. doi: 10.1080/08037051.2016.1213130. PMID: 29084016. Exclusion Code: X7.27601201
23 Bloetzer C, Paccaud F, Burnier M, . Performance of parental history for the targeted screening of hypertension in children. J Hypertens. 2015 Jun;33(6):1167–73. doi: 10.1097/hjh.0000000000000560. PMID: 25668354. Exclusion Code: X9.25799209
24 Brady TM. Hypertension. Pediatr Rev. 2012 Dec;33(12):541–52. doi: 10.1542/pir.33-12-541. PMID: 24669604. Exclusion Code: X2.23204396
25 Brambilla P, Andreano A, Antolini L, . How accurate is a single cutpoint to identify high blood pressure in adolescents? Am J Epidemiol. 2017 Feb 15;185(4):295–303. doi: 10.1093/aje/kww184. PMID: 28633432. Exclusion Code: X7.28087513
26 Bruyne PD, Walle JV. Management of hypertension in children and adolescents. Acta Clin Belg. 2015 Apr;70(2):87–94. doi: 10.1179/2295333714y.0000000092. PMID: 25634714. Exclusion Code: X2.25354902
27 Cadnapaphornchai MA, McFann K, Strain JD, . Prospective change in renal volume and function in children with ADPKD. Clin J Am Soc Nephrol. 2009 Apr;4(4):820–9. PMID: 19346430. Exclusion Code: X4.19346430
28 Cai L, Wu Y, Wilson RF, . Effect of childhood obesity prevention programs on blood pressure: a systematic review and meta-analysis. Circulation. 2014 May 6;129(18):1832–9. doi: 10.1161/circulationaha.113.005666. PMID: 24871251. Exclusion Code: X9.24552832
29 Carrico RJ, Sun SS, Sima AP, . The predictive value of childhood blood pressure values for adult elevated blood pressure. Open J Pediatr. 2013;3(2):116–26. Exclusion Code: X3.23991354
30 Chahine MN, Assemaani N, Sayed Hassan G, . Validation of the OMRON M3500 blood pressure measuring device using normal- and high-speed modes in adult and specific populations (obese and children) according to AAMI protocol. J Clin Hypertens (Greenwich). 2015;17(8):622–9. doi: 10.1111/jch.12540. Exclusion Code: X6.25833259
31 Chandar J, Abitbol C, Montané B, . Angiotensin blockade as sole treatment for proteinuric kidney disease in children. Nephrol Dial Transplant. 2007;22(5):1332–7. Exclusion Code: X4.17299000
32 Chaturvedi S, Lipszyc DH, Licht C, . Pharmacological interventions for hypertension in children: a systematic review and meta-analysis. Pediatr Nephrol. 2013;28(8):1357–8. doi: 10.1007/s00467-013-2521-9. Exclusion Code: X11.
33 Chaturvedi S, Lipszyc DH, Licht C, . Pharmacological interventions for hypertension in children. Evid Based Child Health. 2014 Sep;9(3):498–580. doi: 10.1002/ebch.1974. PMID: 25399733. Exclusion Code: X12.25236305
34 Chaturvedi S, Lipszyc DH, Licht C, . Cochrane in context: pharmacological interventions for hypertension in children. Evid Based Child Health. 2014 Sep;9(3):581–3. doi: 10.1002/ebch.1975. PMID: 24875194. Exclusion Code: X2.25236306
35 Chen W, Srinivasan SR, Li S, . Metabolic syndrome variables at low levels in childhood are beneficially associated with adulthood cardiovascular risk: the Bogalusa Heart Study. Diabetes Care. 2005;28(1):126–31. Exclusion Code: X3.15616245
36 Chiolero A, Bovet P. Hypertension in children: from screening to primordial prevention. Lancet Public Health. 2017 Aug;2(8):e346–e7. doi: 10.1016/s2468-2667(17)30137-8. PMID: 28585476. Exclusion Code: X2.29253470
37 Chiolero A, Bovet P, Paradis G. Screening for elevated blood pressure in children and adolescents: a critical appraisal. JAMA Pediatr. 2013 Mar 1;167(3):266–73. doi: 10.1001/jamapediatrics.2013.438. PMID: 29253470. Exclusion Code: X2.23303490
38 Chiolero A, Bovet P, Stergiou GS. Automated oscillometric blood pressure measurement in children. J Clin Hypertens (Greenwich). 2014;16(6):468. Exclusion Code: X2.24720677
39 Chiolero A, Paradis G, Maximova K, . No use for waist-for-height ratio in addition to body mass index to identify children with elevated blood pressure. Blood Press. 2013 Feb;22(1):17–20. doi: 10.3109/08037051.2012.701376. PMID: 23172928. Exclusion Code: X7.22817261
40 Chiolero A, Paradis G, Simonetti GD, . Absolute height-specific thresholds to identify elevated blood pressure in children. J Hypertens. 2013 Jun;31(6):1170–4. doi: 10.1097/HJH.0b013e32836041ff. PMID: 23426248. Exclusion Code: X7.23552125
41 Christofaro DGD, Farah BQ, Vanderlei LCM, . Analysis of different anthropometric indicators in the detection of high blood pressure in school adolescents: a cross-sectional study with 8295 adolescents. Braz J Phys Ther. 2018 Jan – Feb;22(1):49–54. doi: 10.1016/j.bjpt.2017.10.007. PMID: 27747448. Exclusion Code: X7.29169996
42 Chu C, Dai Y, Mu J, . Associations of risk factors in childhood with arterial stiffness 26 years later: the Hanzhong adolescent hypertension cohort. J Hypertens. 2017 May;35: Suppl 1:S10–s5. doi: 10.1097/hjh.0000000000001242. PMID: 28181141. Exclusion Code: X5.28060189
43 Chu PY, Campbell MJ, Miller SG, . Anti-hypertensive drugs in children and adolescents. World J Cardiol. 2014 May 26;6(5):234–44. doi: 10.4330/wjc.v6.i5.234. PMID: 24944754. Exclusion Code: X4.24944754
44 Chung H, Lee JH, Park E, . Long-term outcomes of pediatric renovascular hypertension. Kidney Blood Press Res. 2017;42(3):617–27. doi: 10.1159/000481549. PMID: 28787728. Exclusion Code: X3.28950261
45 Cifkova R, Fodor G, Wohlfahrt P. Changes in hypertension prevalence, awareness, treatment, and control in high-, middle-, and low-income countries: an update. Curr Hypertens Rep. 2016 Aug;18(8):62. doi: 10.1007/s11906-016-0669-y. PMID: 27759337. Exclusion Code: X2.27372446
46 Cléroux J, Péronnet F, de Champlain J. Effects of exercise training on plasma catecholamines and blood pressure in labile hypertensive subjects. Eur J Appl Physiol Occup Physiol. 1987;56(5):550–4. Exclusion Code: X3.3653096
47 Cloutier L, Fournier A, Houle N, . Transition in care: what is needed for adolescents with hypertension. J Hypertens. 2018;36:e252. Exclusion Code: X10.
48 Cooper R, Van Horn L, Liu K, . A randomized trial on the effect of decreased dietary sodium intake on blood pressure in adolescents. J Hypertens. 1984;2(4):361–6. Exclusion Code: X3.6530546
49 Croxtall JD. Valsartan: in children and adolescents with hypertension. Paediatr Drugs. 2012 Jun 1;14(3):201–7. doi: 10.2165/11208990-000000000-00000. PMID: 22671578. Exclusion Code: X2.22448661
50 Daley MF, Sinaiko AR, Reifler LM, . Patterns of care and persistence after incident elevated blood pressure. Pediatrics. 2013 Aug;132(2):e349–55. doi: 10.1542/peds.2012-2437. PMID: 28032627. Exclusion Code: X7.23821694
51 Davis ML, Ferguson MA, Zachariah JP. Clinical predictors and impact of ambulatory blood pressure monitoring in pediatric hypertension referrals. J Am Soc Hypertens. 2014 Sep;8(9):660–7. doi: 10.1016/j.jash.2014.05.011. PMID: 24906822. Exclusion Code: X9.25065681
52 de Moraes AC, Lacerda MB, Moreno LA, . Prevalence of high blood pressure in 122,053 adolescents: a systematic review and meta-regression. Medicine (Baltimore). 2014 Dec;93(27):e232. doi: 10.1097/md.0000000000000232. PMID: 24532079. Exclusion Code: X7.25501086
53 Dhull RS, Baracco R, Jain A, . Pharmacologic treatment of pediatric hypertension. Curr Hypertens Rep. 2016 Apr;18(4):32. doi: 10.1007/s11906-016-0639-4. PMID: 26667413. Exclusion Code: X2.27048353
54 Di Bonito P, Valerio G, Pacifico L, . A new index to simplify the screening of hypertension in overweight or obese youth. Nutr Metab Cardiovasc Dis. 2017 Sep;27(9):830–5. doi: 10.1016/j.numecd.2017.06.013. PMID: 29716715. Exclusion Code: X7.28755804
55 Diaz A, Calandra L. High blood pressure in school children and adolescents in Argentina over the past 25 years: a systematic review of observational studies. Arch Argent Pediatr. 2017 Feb 1;115(1):5–11. doi: 10.5546/aap.2017.eng.5. PMID: 28151773. Exclusion Code: X7.28097834
56 Dobson CP, Eide M, Nylund CM. Hypertension prevalence, cardiac complications, and antihypertensive medication use in children. J Pediatr. 2015 Jul;167(1):92–7.e1. doi: 10.1016/j.jpeds.2015.04.016. PMID: 25953004. Exclusion Code: X7.25957976
57 Dong B, Wang Z, Wang HJ, . Improving hypertension screening in childhood using modified blood pressure to height ratio. J Clin Hypertens (Greenwich). 2016 Jun;18(6):557–64. doi: 10.1111/jch.12712. PMID: 26452315. Exclusion Code: X5.26456632
58 Dong J, Dong H, Ye P, . Validation of the Raycome RBP-1200 upper-arm pulse wave device in children aged 3-12 years according to the Association for the Advancement of Medical Instrumentation protocol. Blood Press Monit. 2017;22(1):40–3. doi: 10.1097/MBP.0000000000000217. Exclusion Code: X5.27749333
59 Duncombe SL, Voss C, Harris K. A systematic review and meta-analysis of blood pressure measurement techniques in children. 2016. p. S207. Exclusion Code: X10.
60 Duncombe SL, Voss C, Harris KC. Oscillometric and auscultatory blood pressure measurement methods in children: a systematic review and meta-analysis. J Hypertens. 2017 Feb;35(2):213–24. doi: 10.1097/hjh.0000000000001178. PMID: 28057844. Exclusion Code: X4.27870656
61 Duran-Cantolla J, Aizpuru F, Martinez-Null C, . Obstructive sleep apnea/hypopnea and systemic hypertension. Sleep Med Rev. 2009 Oct;13(5):323–31. doi: 10.1016/j.smrv.2008.11.001. PMID: 19515590. Exclusion Code: X2.19515590
62 Ejike CE, Yin FZ. Blood pressure-to-height ratio simplifies the diagnosis of hypertension in Nigerian children. J Trop Pediatr. 2013 Apr;59(2):160–1. doi: 10.1093/tropej/fms064. PMID: 23052612. Exclusion Code: X5.23230005
63 Elizondo-Montemayor L, Gutierrez N, Moreno D, . School-based individualised lifestyle intervention decreases obesity and the metabolic syndrome in Mexican children. J Hum Nutr Diet. 2013;26:82–9. Exclusion Code: X5.23600808
64 Elkasabany AM, Urbina EM, Daniels SR, . Prediction of adult hypertension by K4 and K5 diastolic blood pressure in children: the Bogalusa Heart Study. J Pediatr. 1998;132(4):687–92. Exclusion Code: X3.9580771
65 Elliott JP, Harrison C, Konopka C, . Pharmacist-led screening program for an inner-city pediatric population. J Am Pharm Assoc. 2015 Jul–Aug;55(4):413–8. doi: 10.1331/JAPhA.2015.14273. PMID: 25799209. Exclusion Code: X4.25799209
66 Erlingsdottir A, Indridason OS, Thorvaldsson O, . Blood pressure in children and target-organ damage later in life. Pediatr Nephrol. 2010;25(2):323–8. Exclusion Code: X3.19946710
67 Ewart CK, Young DR, Hagberg JM. Effects of school-based aerobic exercise on blood pressure in adolescent girls at risk for hypertension. Am J Public Health. 1998;88(6):949–51. Exclusion Code: X3.9618627
68 Falkner B. Recent advances in pediatric hypertension. J Clin Hypertens (Greenwich). 2012 Jun;14(6):345. doi: 10.1111/j.1751-7176.2012.00664.x. PMID: 22927987. Exclusion Code: X2.22672086
69 Falkner B, Gidding SS. Is the SPRINT blood pressure treatment target of 120/80 mm Hg relevant for children? Hypertension. 2016 May;67(5):826–8. doi: 10.1161/hypertensionaha.116.06934. PMID: 26725367. Exclusion Code: X2.27021011
70 Farah BQ, Ritti-Dias RM, Balagopal PB, . Does exercise intensity affect blood pressure and heart rate in obese adolescents? A 6-month multidisciplinary randomized intervention study. Pediatr Obes. 2014 Apr;9(2):111–20. doi: 10.1111/j.2047-6310.2012.00145.x. PMID: 23911139. Exclusion Code: X3.23447453
71 Farpour-Lambert NJ, Aggoun Y, Marchand LM, . Physical activity reduces systemic blood pressure and improves early markers of atherosclerosis in pre-pubertal obese children. J Am Coll Cardiol. 2009 Dec;54(25):2396–406. PMID: 20082930. Exclusion Code: X3.20082930
72 Feig DI, Soletsky B, Johnson RJ. Effect of allopurinol on blood pressure of adolescents with newly diagnosed essential hypertension: a randomized trial. JAMA. 2008;300(8):924–32. Exclusion Code: X7.18728266
73 Fernandes E, McCrindle BW. Diagnosis and treatment of hypertension in children and adolescents. Can J Cardiol. 2000 Jun;16(6):801–11. PMID: 9298082. Exclusion Code: X2.10863171
74 Ferreira I, van de Laar RJ, Prins MH, . Carotid stiffness in young adults: a life-course analysis of its early determinants: the Amsterdam Growth and Health Longitudinal Study. Hypertension. 2012 Jan;59(1):54–61. doi: 10.1161/hypertensionaha.110.156109. PMID: 22068867. Exclusion Code: X3.22068867
75 Fixler DE, Laird WP. Validity of mass blood pressure screening in children. Pediatrics. 1983;72(4):459–63. Exclusion Code: X8.6889060
76 Flynn J. The changing face of pediatric hypertension in the era of the childhood obesity epidemic. Pediatr Nephrol. 2013 Jul;28(7):1059–66. doi: 10.1007/s00467-012-2344-0. PMID: 24088720. Exclusion Code: X2.23138756
77 Flynn JT. Impact of ambulatory blood pressure monitoring on the management of hypertension in children. Blood Press Monit. 2000;5(4):211–6. Exclusion Code: X4.11035862
78 Flynn JT, Kaelber DC, Baker-Smith CM, . Clinical practice guideline for screening and management of high blood pressure in children and adolescents. Pediatrics. 2017 Sep;140(3) doi: 10.1542/peds.2017-1904. PMID: 28755804. Exclusion Code: X2.28755804
79 Flynn JT, Meyers KEC, Neto JP, . Efficacy and safety of the angiotensin receptor blocker valsartan in children with hypertension aged 1 to 5 years. Hypertension. 2008;52(2):222–8. Exclusion Code: X3.18591457
80 Flynn JT, Newburger JW, Daniels SR, . A randomized, placebo-controlled trial of amlodipine in children with hypertension. J Pediatr. 2004 Sep;145(3):353–9. PMID: 15343191. Exclusion Code: X11.15343191
81 Foglia CF, von Vigier RO, Fossali E, . A simplified antihypertensive drug regimen does not ameliorate control of childhood hypertension. J Hum Hypertens. 2005;19(8):653–4. Exclusion Code: X4.15905892
82 Freedman DS, Foltz JL, Berenson GS. Differences between the fourth and fifth Korotkoff phases among children and adolescents. Am J Hypertens. 2014 Dec;27(12):1495–502. doi: 10.1093/ajh/hpu064. PMID: 23850404. Exclusion Code: X7.24742638
83 Freedman DS, Patel DA, Srinivasan SR, . The contribution of childhood obesity to adult carotid intima-media thickness: the Bogalusa Heart Study. Int J Obes (Lond). 2008;32(5):749–56. Exclusion Code: X3.18227845
84 Friedman A, Chesney RW, Ball D, . Effective use of captopril (angiotensin I-converting enzyme inhibitor) in severe childhood hypertension. J Pediatr. 1980;97(4):664–7. Exclusion Code: X4.6999143
85 Garcia-Hermoso A, Saavedra JM, Escalante Y. Effects of exercise on resting blood pressure in obese children: a meta-analysis of randomized controlled trials. Obes Rev. 2013 Nov;14(11):919–28. doi: 10.1111/obr.12054. PMID: 24034663. Exclusion Code: X3.23786645
86 Garzon DL. Diagnosis of primary versus secondary pediatric hypertension. Nurse Pract. 2015 Feb 15;40(2):13–6. doi: 10.1097/01.Npr.0000459735.30769.35. PMID: 25537712. Exclusion Code: X2.25537712
87 Gauer R, Qiu KM. Clinical inquiries. Does blood pressure screening benefit children? J Fam Pract. 2012 Jul;61(7):425–6. PMID: 22695459. Exclusion Code: X2.22754893
88 Genovesi S, Giussani M, Orlando A, . Prevention of cardiovascular diseases in children and adolescents. High Blood Press Cardiovasc Prev. 2019 Jun;26(3):191–7. doi: 10.1007/s40292-019-00316-6. PMID: 30177062. Exclusion Code: X2.31041682
89 George MG, Tong X, Wigington C, . Hypertension screening in children and adolescents-National Ambulatory Medical Care Survey, National Hospital Ambulatory Medical Care Survey, and Medical Expenditure Panel Survey, United States, 2007-2010. MMWR Suppl. 2014 Sep 12;63(2):47–53. PMID: 25020279. Exclusion Code: X2.25020279
90 Gillum RF, Elmer PJ, Prineas RJ. Changing sodium intake in children. The Minneapolis Children’s Blood Pressure Study. Hypertension. 1981;3(6):698–703. Exclusion Code: X12.7298122
91 Gimpel C, Wühl E, Arbeiter K, . Superior consistency of ambulatory blood pressure monitoring in children: implications for clinical trials. J Hypertens. 2009;27(8):1568–74. Exclusion Code: X9.19550356
92 Giordano U, Cifra B, Giannico S, . Mid-term results, and therapeutic management, for patients suffering hypertension after surgical repair of aortic coarctation. Cardiol Young. 2009;19(5):451–5. Exclusion Code: X7.19674497
93 Goncalves VS, Galvao TF, de Andrade KR, . Prevalence of hypertension among adolescents: systematic review and meta-analysis. Rev Saude Publica. 2016;50:27. doi: 10.1590/s1518-8787.2016050006236. PMID: 26935285. Exclusion Code: X3.27253903
94 Gooding HC, McGinty S, Richmond TK, . Hypertension awareness and control among young adults in the national longitudinal study of adolescent health. J Gen Intern Med. 2014 Aug;29(8):1098–104. doi: 10.1007/s11606-014-2809-x. PMID: 22402734. Exclusion Code: X3.24577758
95 Gregoski MJ, Barnes VA, Tingen MS, . Breathing awareness meditation and lifeskills training programs influence upon ambulatory blood pressure and sodium excretion among African American adolescents. J Adolesc Health. 2011 2011/01;48(1):59–64. doi: 10.1016/j.jadohealth.2010.05.019. Exclusion Code: X3.21185525
96 Griffin L, Kee JL, Waters L. Reducing blood pressure in the potentially hypertensive young adult. J Am Coll Health. 1990 Jan;38(4):193–4. PMID: 2299055. Exclusion Code: X3.2299055
97 Grobbee DE, Hofman A, Roelandt JT, . Sodium restriction and potassium supplementation in young people with mildly elevated blood pressure. J Hypertens. 1987;5(1):115–9. Exclusion Code: X3.3295034
98 Group ET, Wuhl E, Trivelli A, . Strict blood-pressure control and progression of renal failure in children. N Engl J Med. 2009 Oct 22;361(17):1639–50. PMID: 19846849. Exclusion Code: X8.19846849
99 Guzman-Limon M, Samuels J. Pediatric Hypertension: diagnosis, evaluation, and treatment. Pediatr Clin North Am. 2019 Feb;66(1):45–57. doi: 10.1016/j.pcl.2018.09.001. PMID: 31047092. Exclusion Code: X2.30454750
100 Hacke C, Ketelhut S, Wendt U, . Effectiveness of a physical activity intervention in preschoolers: a cluster-randomized controlled trial. Scand J Med Sci Sports. 2019 May;29(5):742–52. doi: 10.1111/sms.13390. PMID: 30999870. Exclusion Code: X3.30664816
101 Halbach S, Flynn J. Treatment of hypertension in children with chronic kidney disease. Curr Hypertens Rep. 2015 Jan;17(1):503. doi: 10.1007/s11906-014-0503-3. PMID: 25623611. Exclusion Code: X2.25432895
102 Halbach SM, Hamman R, Yonekawa K, . Utility of ambulatory blood pressure monitoring in the evaluation of elevated clinic blood pressures in children. J Am Soc Hypertens. 2016 May;10(5):406–12. doi: 10.1016/j.jash.2016.02.013. PMID: 26456632. Exclusion Code: X3.27026571
103 Hammer GB, Verghese ST, Drover DR, . Pharmacokinetics and pharmacodynamics of fenoldopam mesylate for blood pressure control in pediatric patients. BMC Anesthesiol. 2008 Oct 6;8:6. Exclusion Code: X7.18837982
104 Hansen ML, Gunn PW, Kaelber DC. Underdiagnosis of hypertension in children and adolescents. JAMA. 2007 Aug 22;298(8):874–9. doi: 10.1001/jama.298.8.874. PMID: 17712071. Exclusion Code: X2.17712071
105 Hartiala O, Magnussen CG, Kajander S, . Adolescence risk factors are predictive of coronary artery calcification at middle age: the cardiovascular risk in young Finns study. J Am Coll Cardiol. 2012 Oct 9;60(15):1364–70. doi: 10.1016/j.jacc.2012.05.045. PMID: 22981553. Exclusion Code: X9.22981553
106 Hosie J, Bremner AD, Fell PJ, . Comparison of early side effects with amlodipine and nifedipine retard in hypertension. Cardiology. 1992;80: Suppl 1:54–9. Exclusion Code: X3.1534716
107 Ilyas M, Peracha MA, Rahman I. Comparison of a semi-automated sphygmomanometer with the clinical sphygmomanometer. Jpn Heart J. 1975;16(2):118–21. Exclusion Code: X3.1117590
108 Janda J, Veleminsky M, Sulakova T, . Effect of the DASH-diet and salt Kardisal(R) on blood pressure in adolescents with prehypertension (Cooperative multicentre interventional study). Neuro Endocrinol Lett. 2018 Feb;38(8):544–8. PMID: 28481823. Exclusion Code: X4.29504732
109 Jansen MA, Dalmeijer GW, Visseren FL, . Adult derived genetic blood pressure scores and blood pressure measured in different body postures in young children. Eur J Prev Cardiol. 2017 Feb;24(3):320–7. doi: 10.1177/2047487316679526. PMID: 30278500. Exclusion Code: X9.27856808
110 Johnson PK, Ferguson MA, Zachariah JP. In-clinic blood pressure prediction of normal ambulatory blood pressure monitoring in pediatric hypertension referrals. Congenit Heart Dis. 2016 Jul;11(4):309–14. doi: 10.1111/chd.12374. PMID: 26096532. Exclusion Code: X7.27205889
111 Kaelber DC, Liu W, Ross M, . Diagnosis and medication treatment of pediatric hypertension: a retrospective cohort study. Pediatrics. 2016 Dec;138(6) doi: 10.1542/peds.2016-2195. PMID: 27255757. Exclusion Code: X9.27255757
112 Kamath N, Goud BR, Phadke KD, . Use of oscillometric devices for the measurement of blood pressure-comparison with the gold standard. Indian J Pediatr. 2012;79(9):1230–2. Exclusion Code: X5.22057397
113 Kari JA, Roebuck DJ, McLaren CA, . Angioplasty for renovascular hypertension in 78 children. Arch Dis Child. 2015 May;100(5):474–8. doi: 10.1136/archdischild-2013-305886. PMID: 25743698. Exclusion Code: X3.25527520
114 Katz SL, MacLean JE, Hoey L, . Insulin resistance and hypertension in obese youth with sleep-disordered breathing treated with positive airway pressure: a prospective multicenter study. J Clin Sleep Med. 2017 Sep 15;13(9):1039–47. doi: 10.5664/jcsm.6718. PMID: 28317244. Exclusion Code: X3.28728620
115 Kelishadi R, Bahreynian M, Heshmat R, . Accuracy of blood pressure-to-height ratio to define elevated blood pressure in children and adolescents: the CASPIAN-IV Study. Pediatr Cardiol. 2016 Feb;37(2):378–85. doi: 10.1007/s00246-015-1287-1. PMID: 28349252. Exclusion Code: X5.26559185
116 Kemper HC, Snel J, Verschuur R, . Tracking of health and risk indicators of cardiovascular diseases from teenager to adult: Amsterdam Growth and Health Study. Prev Med. 1990;19(6):642–55. Exclusion Code: X3.2263575
117 Kemper HC, van Mechelen W, Post GB, . The Amsterdam Growth and Health Longitudinal Study. The past (1976-1996) and future (1997-?). Int J Sports Med. 1997 Jul;18: Suppl 3:S140–50. PMID: 9272841. Exclusion Code: X3.9272841
118 Khoury M, Khoury PR, Dolan LM, . Clinical implications of the revised AAP Pediatric Hypertension Guidelines. Pediatrics. 2018 Aug;142(2) doi: 10.1542/peds.2018-0245. PMID: 30642106. Exclusion Code: X9.30642106
119 Kim S, Lewis JR, Baur LA, . Obesity and hypertension in Australian young people: results from the Australian Health Survey 2011-2012. Intern Med J. 2017 Feb;47(2):162–9. doi: 10.1111/imj.13298. PMID: 27461023. Exclusion Code: X7.27761992
120 Kit BK, Kuklina E, Carroll MD, . Prevalence of and trends in dyslipidemia and blood pressure among US children and adolescents, 1999-2012. JAMA Pediatr. 2015 Mar;169(3):272–9. doi: 10.1001/jamapediatrics.2014.3216. PMID: 25599372. Exclusion Code: X2.25599372
121 Koebnick C, Black MH, Wu J, . High blood pressure in overweight and obese youth: implications for screening. J Clin Hypertens (Greenwich). 2013 Nov;15(11):793–805. doi: 10.1111/jch.12199. PMID: 24101758. Exclusion Code: X3.24119024
122 Kollias A, Boubouchairopoulou N, Ntineri A, . Accuracy of automated blood pressure monitors in children: a systematic review. J Hypertens. 2017;35:e173–e4. doi: 10.1097/01.hjh.0000523473.02491.9c. Exclusion Code: X10.
123 Kollias A, Dafni M, Poulidakis E, . Out-of-office blood pressure and target organ damage in children and adolescents: a systematic review and meta-analysis. J Hypertens. 2014 Dec;32(12):2315–31; discussion 31. doi: 10.1097/hjh.0000000000000384. PMID: 24097285. Exclusion Code: X9.25304469
124 Koskinen J, Magnussen CG, Sinaiko A, . Childhood age and associations between childhood metabolic syndrome and adult risk for metabolic syndrome, type 2 diabetes mellitus and carotid intima media thickness: the International Childhood Cardiovascular Cohort Consortium. J Am Heart Assoc. 2017 Aug 16;6(8) doi: 10.1161/jaha.117.005632. PMID: 28255331. Exclusion Code: X3.28255331
125 Krmar RT, Holtback U, Bergh A, . Oscillometric casual blood pressure normative standards for Swedish children using ABPM to exclude casual hypertension. Am J Hypertens. 2015 Apr;28(4):459–68. doi: 10.1093/ajh/hpu182. PMID: 25323136. Exclusion Code: X7.25384408
126 Kropa J, Close J, Shipon D, . High prevalence of obesity and high blood pressure in urban student-athletes. J Pediatr. 2016 Nov;178:194–9. doi: 10.1016/j.jpeds.2016.07.006. PMID: 27432869. Exclusion Code: X7.27544309
127 Kumar De A, Mookerjee S, Guha S, . Evaluation of sustained blood pressure elevation in children. Indian Heart J. 2013 Sep–Oct;65(5):497–500. doi: 10.1016/j.ihj.2013.08.026. PMID: 24029505. Exclusion Code: X5.24206870
128 Kwan MW, Wong MC, Wang HH, . Compliance with the Dietary Approaches to Stop Hypertension (DASH) diet: a systematic review. PLoS One. 2013;8(10):e78412. doi: 10.1371/journal.pone.0078412. PMID: 23648395. Exclusion Code: X3.24205227
129 Lai CC, Sun D, Cen R, . Impact of long-term burden of excessive adiposity and elevated blood pressure from childhood on adulthood left ventricular remodeling patterns: the Bogalusa Heart Study. J Am Coll Cardiol. 2014 Oct 14;64(15):1580–7. doi: 10.1016/j.jacc.2014.05.072. PMID: 25301461. Exclusion Code: X9.25301461
130 Lambrechtsen J, Rasmussen F, Hansen HS, . Tracking and factors predicting rising in ‘tracking quartile’ in blood pressure from childhood to adulthood: Odense Schoolchild Study. J Hum Hypertens. 1999;13(6):385–91. Exclusion Code: X3.10408588
131 Lamotte C, Iliescu C, Libersa C, . Increased intima-media thickness of the carotid artery in childhood: a systematic review of observational studies. Eur J Pediatr. 2011 Jun;170(6):719–29. doi: 10.1007/s00431-010-1328-y. PMID: 19249448. Exclusion Code: X4.20978785
132 Lapointe T, Brassard P, Rattray B, . Physical activity counteracts the influence of mental work on blood pressure in healthy children. Physiol Behav. 2016 Oct 1;164(Pt A):102–6. doi: 10.1016/j.physbeh.2016.05.048. PMID: 27871267. Exclusion Code: X4.27241633
133 Larsen MN, Nielsen CM, Madsen M, . Cardiovascular adaptations after 10 months of intense school-based physical training for 8- to 10-year-old children. Scand J Med Sci Sports. 2018 Aug;28: Suppl 1:33–41. doi: 10.1111/sms.13253. PMID: 29680994. Exclusion Code: X3.30047176
134 Ledyaev MY, Stepanova OV, Ledyaeva AM. Validation of the BPLab(®) 24-hour blood pressure monitoring system in a pediatric population according to the 1993 British Hypertension Society protocol. Med Devices (Auckl). 2015;8:115–8. doi: 10.2147/MDER.S78515. Exclusion Code: X8.25674018
135 Leenen FH, Balfe JA, Pelech AN, . Postoperative hypertension after repair of coarctation of aorta in children: protective effect of propranolol? Am Heart J. 1987;113(5):1164–73. Exclusion Code: X6.3554943
136 Leiba A, Fishman B, Twig G, . Association of adolescent hypertension with future end-stage renal disease. JAMA Intern Med. 2019 Feb 25 doi: 10.1001/jamainternmed.2018.7632. PMID: 30801616. Exclusion Code: X9.30801616
137 Leyvraz M, Chatelan A, da Costa BR, . Sodium intake and blood pressure in children and adolescents: a systematic review and meta-analysis of experimental and observational studies. Int J Epidemiol. 2018 Dec 1;47(6):1796–810. doi: 10.1093/ije/dyy121. PMID: 30316666. Exclusion Code: X3.29955869
138 Li S, Chen W, Srinivasan SR, . Relation of childhood obesity/cardiometabolic phenotypes to adult cardiometabolic profile: the Bogalusa Heart Study. Am J Epidemiol. 2012 Oct 1;176 Suppl 7:S142–9. doi: 10.1093/aje/kws236. PMID: 23102798. Exclusion Code: X3.23035138
139 Li X, Li S, Ulusoy E, . Childhood adiposity as a predictor of cardiac mass in adulthood: the Bogalusa Heart Study. Circulation. 2004;110(22):3488–92. Exclusion Code: X3.15557363
140 Li Z, Snieder H, Harshfield GA, . A 15-year longitudinal study on ambulatory blood pressure tracking from childhood to early adulthood. Hypertens Res. 2009;32(5):404–10. Exclusion Code: X9.19325561
141 Liao CC, Su TC, Chien KL, . Elevated blood pressure, obesity, and hyperlipidemia. J Pediatr. 2009;155(1):79–83, .e1. Exclusion Code: X5.19446850
142 Litwin M, Michalkiewicz J, Gackowska L. Primary hypertension in children and adolescents is an immuno-metabolic disease with hemodynamic consequences. Curr Hypertens Rep. 2013 Aug;15(4):331–9. doi: 10.1007/s11906-013-0360-5. PMID: 23645323. Exclusion Code: X2.23737217
143 Liu Q, Hou Y, Yang L, . Diagnostic effect of the single BP cut-offs for identifying elevated BP and hypertension in adolescents aged 13-17 years. Pediatr Cardiol. 2019 Apr;40(4):738–43. doi: 10.1007/s00246-019-02058-7. PMID: 30916142. Exclusion Code: X7.30707250
144 Liu S, Dunford SD, Leung YW, . Reducing blood pressure with Internet-based interventions: a meta-analysis. Can J Cardiol. 2013 May;29(5):613–21. doi: 10.1016/j.cjca.2013.02.007. PMID: 23614041. Exclusion Code: X3.23618507
145 Lobeck IN, Alhajjat AM, Dupree P, . The management of pediatric renovascular hypertension: a single center experience and review of the literature. J Pediatr Surg. 2018 Sep;53(9):1825–31. doi: 10.1016/j.jpedsurg.2017.12.008. PMID: 30045336. Exclusion Code: X3.29397961
146 Lopez A, Stuckey P, Mallory D. Making positive health changes in obese/overweight children with hypertension. Pediatr Nurs. 2016 Sep–Oct;42(5):243–6. PMID: 27443376. Exclusion Code: X2.29406644
147 Lopilato AC, Muratagic M, Patel S. Pediatric hypertension: a pharmacological review. AACN Adv Crit Care. 2015 Apr–Jun;26(2):81–90; quiz 1-2. doi: 10.1097/nci.0000000000000084. PMID: 25889498. Exclusion Code: X2.25898872
148 Lurbe E, Parati G. Out-of-office blood pressure measurement in children and adolescents. J Hypertens. 2008;26(8):1536–239. Exclusion Code: X2.18622226
149 Lustig RH, Mulligan K, Noworolski SM, . Isocaloric fructose restriction and metabolic improvement in children with obesity and metabolic syndrome. Obesity (Silver Spring). 2016 Feb;24(2):453–60. doi: 10.1002/oby.21371. PMID: 26235973. Exclusion Code: X11.26499447
150 Ma C, Kelishadi R, Hong YM, . Performance of eleven simplified methods for the identification of elevated blood pressure in children and adolescents. Hypertension. 2016 Sep;68(3):614–20. doi: 10.1161/hypertensionaha.116.07659. PMID: 24858765. Exclusion Code: X7.27432869
151 Ma C, Liu Y, Lu Q, . The performance of blood pressure-to-height ratio as a screening measure for identifying children and adolescents with hypertension: a meta-analysis. Blood Press Monit. 2016 Feb;21(1):43–8. doi: 10.1097/mbp.0000000000000159. PMID: 26810340. Exclusion Code: X5.26466124
152 Ma C, Wang R, Liu Y, . Performance of user-friendly screening tools for elevated blood pressure in children. Pediatrics. 2017 Feb;139(2) doi: 10.1542/peds.2016-1986. PMID: 27544309. Exclusion Code: X7.27544309
153 Mabry-Hernandez I, Chu K. Screening for primary hypertension in children and adolescents. Am Fam Physician. 2015 Feb 15;91(4):257–8. PMID: 26037424. Exclusion Code: X2.25955627
154 Magnussen CG, Smith KJ, Juonala M. When to prevent cardiovascular disease? As early as possible: lessons from prospective cohorts beginning in childhood. Curr Opin Cardiol. 2013 Sep;28(5):561–8. doi: 10.1097/HCO.0b013e32836428f4. PMID: 23351791. Exclusion Code: X2.23928921
155 Manios Y, Karatzi K, Protogerou AD, . Prevalence of childhood hypertension and hypertension phenotypes by weight status and waist circumference: the Healthy Growth Study. Eur J Nutr. 2018 Apr;57(3):1147–55. doi: 10.1007/s00394-017-1398-y. PMID: 28382960. Exclusion Code: X7.28349252
156 Marcovecchio ML, Mohn A, Diddi G, . Longitudinal assessment of blood pressure in school-aged children: a 3-year follow-up study. Pediatr Cardiol. 2016 Feb;37(2):255–61. doi: 10.1007/s00246-015-1271-9. PMID: 23850194. Exclusion Code: X5.26439942
157 Marlais M, Cuthell O, Langan D, . Hypertension in autosomal dominant polycystic kidney disease: a meta-analysis. Arch Dis Child. 2016;101(12):1142–7. doi: 10.1136/archdischild-2015-310221. Exclusion Code: X3.27288429
158 McNiece KL, Poffenbarger TS, Turner JL, . Prevalence of hypertension and pre-hypertension among adolescents. J Pediatr. 2007 Jun;150(6):640–4, 4.e1. doi: 10.1016/j.jpeds.2007.01.052. PMID: 17517252. Exclusion Code: X2.17517252
159 Meadows J, Minahan M, McElhinney DB, . Intermediate outcomes in the prospective, multicenter Coarctation of the Aorta Stent Trial (COAST). Circulation. 2015 May 12;131(19):1656–64. doi: 10.1161/circulationaha.114.013937. PMID: 25487173. Exclusion Code: X3.25869198
160 Meng L, Zhao D, Pan Y, . Validation of Omron HBP-1300 professional blood pressure monitor based on auscultation in children and adults. BMC Cardiovasc Disord. 2016;16:9. doi: 10.1186/s12872-015-0177-z. Exclusion Code: X5.26758197
161 Michaud PA. Adolescent hypertension: a follow-up study in the community. Rev Epidemiol Sante Publique. 1989;37(1):23–8. PMID: 2710975. Exclusion Code: X4.2710975
162 Moffett BS, Penny DJ. Variability in treatment of post-coarctectomy hypertension: a multicenter study. Pediatr Cardiol. 2016 Apr;37(4):772–7. doi: 10.1007/s00246-016-1349-z. PMID: 26945324. Exclusion Code: X3.26897371
163 Mollerup PM, Lausten-Thomsen U, Fonvig CE, . Reductions in blood pressure during a community-based overweight and obesity treatment in children and adolescents with prehypertension and hypertension. J Hum Hypertens. 2017 Oct;31(10):640–6. doi: 10.1038/jhh.2017.36. PMID: 26558818. Exclusion Code: X4.28492239
164 Moore LL, Bradlee ML, Singer MR, . Dietary Approaches to Stop Hypertension (DASH) eating pattern and risk of elevated blood pressure in adolescent girls. Br J Nutr. 2012 Nov 14;108(9):1678–85. doi: 10.1017/s000711451100715x. PMID: 23102765. Exclusion Code: X3.22243687
165 Moore LL, Singer MR, Bradlee ML, . Adolescent dietary intakes predict cardiometabolic risk clustering. Eur J Nutr. 2016 Mar;55(2):461–8. doi: 10.1007/s00394-015-0863-8. PMID: 26592688. Exclusion Code: X3.25724172
166 Morgan GJ, Lee KJ, Chaturvedi R, . Systemic blood pressure after stent management for arch coarctation implications for clinical care. JACC Cardiovasc Interv. 2013 Feb;6(2):192–201. doi: 10.1016/j.jcin.2012.10.009. PMID: 23446318. Exclusion Code: X3.23428013
167 Mourato FA, Lima Filho JL, Mattos Sda S. Comparison of different screening methods for blood pressure disorders in children and adolescents. J Pediatr (Rio J). 2015 May–Jun;91(3):278–83. doi: 10.1016/j.jped.2014.08.008. PMID: 26040929. Exclusion Code: X5.25475553
168 Mourato FA, Nadruz W, Jr., Moser LR, . A modified blood pressure to height ratio improves accuracy for hypertension in childhood. Am J Hypertens. 2015 Mar;28(3):409–13. doi: 10.1093/ajh/hpu159. PMID: 25384408. Exclusion Code: X7.25194155
169 Moyer VA. Screening for primary hypertension in children and adolescents: U.S. Preventive Services Task Force recommendation statement. Pediatrics. 2013 Nov;132(5):907–14. doi: 10.1542/peds.2013-2864. PMID: 24097285. Exclusion Code: X2.24101758
170 Mu J, Liu Z, Liu F, . Family-based randomized trial to detect effects on blood pressure of a salt substitute containing potassium and calcium in hypertensive adolescents. Am J Hypertens. 2009;22(9):943–7. Exclusion Code: X5.19661927
171 Muir VJ, Keating GM. Olmesartan medoxomil: in children and adolescents with hypertension. Drugs. 2010;70(18):2439–47. Exclusion Code: X2.21142262
172 Nanton MA, Olley PM. Residual hypertension after coarctectomy in children. Am J Cardiol. 1976;37(5):769–72. Exclusion Code: X7.1266744
173 Nelson MJ, Ragland DR, Syme SL. Longitudinal prediction of adult blood pressure from juvenile blood pressure levels. Am J Epidemiol. 1992;136(6):633–45. Exclusion Code: X3.1442730
174 Nishibata K, Nagashima M, Tsuji A, . Comparison of casual blood pressure and twenty-four-hour ambulatory blood pressure in high school students. J Pediatr. 1995;127(1):34–9. Exclusion Code: X8.7608808
175 Novartis Pharmaceuticals. A 6 week, randomized, multicenter, double-blind, double-dummy study to evaluate the dose response of valsartan on blood pressure reduction in children 1-5 years old with hypertension, with or without chronic kidney disease, followed by a 20 week open-label titration phase. 2014. Exclusion Code: X9.
176 Nussinovitch N, Elishkevitz K, Rosenthal T, . Screening for hypertension in high school. Clin Pediatr (Phila). 2005;44(8):711–4. PMID: 16211196. Exclusion Code: X4.16211196
177 Olson DL, Lieberman E. Renal hypertension in children. Pediatr Clin North Am. 1976 Nov;23(4):795–805. PMID: 27217408. Exclusion Code: X2.995444
178 Ostchega Y, Zhang G, Sorlie P, . Blood pressure randomized methodology study comparing automatic oscillometric and mercury sphygmomanometer devices: National Health and Nutrition Examination Survey, 2009-2010. Natl Health Stat Report. 2012(59):1–15. Exclusion Code: X3.
179 Ostrye J, Hailpern SM, Jones J, . The efficacy and safety of intravenous hydralazine for the treatment of hypertension in the hospitalized child. Pediatr Nephrol. 2014 Aug;29(8):1403–9. doi: 10.1007/s00467-014-2772-0. PMID: 24706259. Exclusion Code: X3.24554119
180 Outdili Z, Marti-Soler H, Simonetti GD, . Performance of blood pressure-to-height ratio at a single screening visit for the identification of hypertension in children. J Hypertens. 2014 May;32(5):1068–74; discussion 74. doi: 10.1097/hjh.0000000000000152. PMID: 24134059. Exclusion Code: X7.24625656
181 Padua LM, Garcia LC, Rubira CJ, . Stent placement versus surgery for coarctation of the thoracic aorta. Cochrane Database Syst Rev. 2012 May 16(5):Cd008204. doi: 10.1002/14651858.CD008204.pub2. PMID: 24151290. Exclusion Code: X7.22592728
182 Patankar N, Fernandes N, Kumar K, . Does measurement of four-limb blood pressures at birth improve detection of aortic arch anomalies? J Perinatol. 2016 May;36(5):376–80. doi: 10.1038/jp.2015.203. PMID: 28376458. Exclusion Code: X3.26765554
183 Paulus D, Saint-Remy A, Jeanjean M. Blood pressure during adolescence: a study among Belgian adolescents selected from a high cardiovascular risk population. Eur J Epidemiol. 1999 Oct;15(9):783–90. PMID: 10608356. Exclusion Code: X4.10608356
184 Pellicer A, Riera J, Lopez-Ortego P, . Phase 1 study of two inodilators in neonates undergoing cardiovascular surgery. Pediatr Res. 2013 Jan;73(1):95–103. doi: 10.1038/pr.2012.154. PMID: 23143352. Exclusion Code: X3.23138399
185 Pérez EA, Olivares VM, Martínez-Espinosa RM, . New insights about how to make an intervention in children and adolescents with metabolic syndrome: diet, exercise vs. changes in body composition. A systematic review of RCT. Nutrients. 2018;10(7) doi: 10.3390/nu10070878. Exclusion Code: X3.
186 Podoll A, Grenier M, Croix B, . Inaccuracy in pediatric outpatient blood pressure measurement. Pediatrics. 2007;119(3):e538–43. Exclusion Code: X8.17332173
187 Polonia J, Santos AR, Gama GM, . Accuracy of twenty-four-hour ambulatory blood pressure monitoring (night-day values) for the diagnosis of secondary hypertension. J Hypertens. 1995;13(12 Pt 2):1738–41. PMID: 8903643. Exclusion Code: X3.8903643
188 Porras D, Stein DR, Ferguson MA, . Midaortic syndrome: 30 years of experience with medical, endovascular and surgical management. Pediatr Nephrol. 2013 Oct;28(10):2023–33. doi: 10.1007/s00467-013-2514-8. PMID: 23774056. Exclusion Code: X7.23775038
189 Rames LK, Clarke WR, Connor WE, . Normal blood pressure and the evaluation of sustained blood pressure elevation in childhood: the Muscatine study. Pediatrics. 1978 Feb;61(2):245–51. PMID: 634679. Exclusion Code: X9.634679
190 Redwine KM, Daniels SR. Prehypertension in adolescents: risk and progression. J Clin Hypertens (Greenwich). 2012 Jun;14(6):360–4. doi: 10.1111/j.1751-7176.2012.00663.x. PMID: 22672089. Exclusion Code: X9.22672089
191 Redwine KM, James LP, O’Riordan M, . Accuracy of the Spacelabs 90217 ambulatory blood pressure monitor in a pediatric population. Blood Press Monit. 2015;20(5):295–8. doi: 10.1097/MBP.0000000000000132. Exclusion Code: X9.26529437
192 Ringel RE, Vincent J, Jenkins KJ, . Acute outcome of stent therapy for coarctation of the aorta: results of the coarctation of the aorta stent trial. Catheter Cardiovasc Interv. 2013 Oct 1;82(4):503–10. doi: 10.1002/ccd.24949. PMID: 23592275. Exclusion Code: X3.23592408
193 Rocchini AP, Katch V, Anderson J, . Blood pressure in obese adolescents: effect of weight loss. Pediatrics. 1988;82(1):16–23. Exclusion Code: X3.3288957
194 Roeleveld PP, Zwijsen EG. Treatment strategies for paradoxical hypertension following surgical correction of coarctation of the aorta in children. World J Pediatr Congenit Heart Surg. 2017 May;8(3):321–31. doi: 10.1177/2150135117690104. PMID: 28657375. Exclusion Code: X3.28520538
195 Romero M, Kapur G, Baracco R, . Treatment of hypertension in children with catecholamine-secreting tumors: a systematic approach. J Clin Hypertens (Greenwich). 2015 Sep;17(9):720–5. doi: 10.1111/jch.12571. PMID: 24345633. Exclusion Code: X3.26010736
196 Rosner B, Hennekens CH, Kass EH, . Age-specific correlation analysis of longitudinal blood pressure data. Am J Epidemiol. 1977;106(4):306–13. Exclusion Code: X3.910798
197 Roulet C, Bovet P, Brauchli T, . Secular trends in blood pressure in children: a systematic review. J Clin Hypertens (Greenwich). 2017 May;19(5):488–97. doi: 10.1111/jch.12955. PMID: 28097834. Exclusion Code: X4.27982505
198 Roy NB, Fortin PM, Bull KR, . Interventions for chronic kidney disease in people with sickle cell disease. Cochrane Database Syst Rev. 2017(7) doi: 10.1002/14651858.CD012380.pub2. PMID: CD012380. Exclusion Code: X3.
199 Ruggenenti P, Cravedi P, Chianca A, . Achieving remission of proteinuria in childhood CKD. Pediatr Nephrol. 2017 Feb;32(2):321–30. doi: 10.1007/s00467-016-3495-1. PMID: 27745591. Exclusion Code: X3.27704256
200 Rumman RK, Nickel C, Matsuda-Abedini M, . Disease beyond the arch: a systematic review of middle aortic syndrome in childhood. Am J Hypertens. 2015 Jul;28(7):833–46. doi: 10.1093/ajh/hpu296. PMID: 26969751. Exclusion Code: X3.25631383
201 Sadiq M, Ur Rehman A, Qureshi AU, . Covered stents in the management of native coarctation of the aorta-intermediate and long-term follow-up. Catheter Cardiovasc Interv. 2013 Oct 1;82(4):511–8. doi: 10.1002/ccd.24945. PMID: 23821694. Exclusion Code: X5.23592275
202 Sahu MK, Manikala VK, Singh SP, . Use of dexmedetomidine as an adjunct in the treatment of paradoxical hypertension after surgical repair of coarctation of the aorta in infants. Ann Card Anaesth. 2015 Jul–Sep;18(3):437–40. doi: 10.4103/0971-9784.159826. PMID: 26139648. Exclusion Code: X3.26139759
203 Sakalli H, Baskin E, Bayrakci US, . Acidosis and hyperkalemia caused by losartan and enalapril in pediatric kidney transplant recipients. Exp Clin Transplant. 2014 Aug;12(4):310–3. doi: 10.6002/ect.2013.0172. PMID: 27129124. Exclusion Code: X4.24447308
204 Samuel JP, Samuels JA, Brooks LE, . Comparative effectiveness of antihypertensive treatment for older children with primary hypertension: study protocol for a series of n-of-1 randomized trials. Trials. 2016 Jan 8;17:16. doi: 10.1186/s13063-015-1142-y. PMID: 26259808. Exclusion Code: X2.26746195
205 Santi M, Simonetti BG, Leoni-Foglia CF, . Arterial hypertension in children. Curr Opin Cardiol. 2015 Jul;30(4):403–10. doi: 10.1097/hco.0000000000000191. PMID: 24603455. Exclusion Code: X2.26049390
206 Schaefer F, Coppo R, Bagga A, . Efficacy and safety of valsartan in hypertensive children 6 months to 5 years of age. J Hypertens. 2013 May;31(5):993–1000. doi: 10.1097/HJH.0b013e32835f5721. PMID: 23852483. Exclusion Code: X3.23511339
207 Schaefer F, van de Walle J, Zurowska A, . Efficacy, safety and pharmacokinetics of candesartan cilexetil in hypertensive children from 1 to less than 6 years of age. J Hypertens. 2010;28(5):1083–90. Exclusion Code: X4.20160654
208 Seeman T, Dostálek L, Gilík J. Control of hypertension in treated children and its association with target organ damage. Am J Hypertens. 2012;25(3):389–95. Exclusion Code: X4.22089110
209 Seeman T, Gilik J. Long-term control of ambulatory hypertension in children: improving with time but still not achieving new blood pressure goals. Am J Hypertens. 2013 Jul;26(7):939–45. doi: 10.1093/ajh/hpt048. PMID: 23610239. Exclusion Code: X3.23645323
210 Sekgala MD, Monyeki KD, Mogale MA, . Performance of blood pressure to height ratio as a screening tool for elevated blood pressure in rural children: Ellisras Longitudinal Study. J Hum Hypertens. 2017 Sep;31(9):591–5. doi: 10.1038/jhh.2017.25. PMID: 27022808. Exclusion Code: X5.28382960
211 Sethna CB, Gipson DS. Treatment of FSGS in children. Adv Chronic Kidney Dis. 2014 Mar;21(2):194–9. doi: 10.1053/j.ackd.2014.01.010. PMID: 24326147. Exclusion Code: X3.24602468
212 Shen W, Zhang T, Li S, . Race and sex differences of long-term blood pressure profiles from childhood and adult hypertension: The Bogalusa Heart Study. Hypertension. 2017;70(1):66–74. Exclusion Code: X3.28533330
213 Silverberg DS, Nostrand CV, Juchli B, . Screening for hypertension in a high school population. Can Med Assoc J. 1975;113(2):103–8. PMID: 124624. Exclusion Code: X9.124624
214 Singh S, Kaur J, Thumburu KK, . Predictors of childhood obesity and adulthood blood pressure levels. Cardiology (Switzerland). 2016;134:63. doi: 10.1159/000447505. Exclusion Code: X10.
215 Sinha A, Saha A, Kumar M, . Extending initial prednisolone treatment in a randomized control trial from 3 to 6 months did not significantly influence The course of illness in children with steroid-sensitive nephrotic syndrome. Kidney Int. 2015;87(1):217–24. doi: 10.1038/ki.2014.240. PMID: CN-01040288. Exclusion Code: X3.25029428
216 Sladowska-Kozlowska J, Litwin M, Niemirska A, . Oxidative stress in hypertensive children before and after 1 year of antihypertensive therapy. Pediatr Nephrol. 2012 Oct;27(10):1943–51. doi: 10.1007/s00467-012-2193-x. PMID: 22585950. Exclusion Code: X7.22660895
217 Slark J, Khan MS, Bentley P, . Knowledge of blood pressure in a U.K. general public population. J Hum Hypertens. 2014 Aug;28(8):500–3. doi: 10.1038/jhh.2013.136. PMID: 24430705. Exclusion Code: X2.24430705
218 Smyth RM, Gargon E, Kirkham J, . Adverse drug reactions in children-a systematic review. PLoS One. 2012;7(3) doi: 10.1371/journal.pone.0024061. Exclusion Code: X3.
219 Snauwaert E, Vande Walle J, De Bruyne P. Therapeutic efficacy and safety of ACE inhibitors in the hypertensive paediatric population: a review. Arch Dis Child. 2017 Jan;102(1):63–71. doi: 10.1136/archdischild-2016-310582. PMID: 27357057. Exclusion Code: X7.27682140
220 Stabouli S, Kotsis V, Karagianni C, . Blood pressure and carotid artery intima-media thickness in children and adolescents: the role of obesity. Hellenic J Cardiol. 2012 Jan–Feb;53(1):41–7. PMID: 22275742. Exclusion Code: X9.22275742
221 Stabouli S, Kotsis V, Rizos Z, . Left ventricular mass in normotensive, prehypertensive and hypertensive children and adolescents. Pediatr Nephrol. 2009 Aug;24(8):1545–51. doi: 10.1007/s00467-009-1165-2. PMID: 19444486. Exclusion Code: X9.19444486
222 Stabouli S, Kotsis V, Toumanidis S, . White-coat and masked hypertension in children: association with target-organ damage. Pediatr Nephrol. 2005 Aug;20(8):1151–5. doi: 10.1007/s00467-005-1979-5. PMID: 15947982. Exclusion Code: X9.15947982
223 Stabouli S, Sideras L, Vareta G, . Hypertension screening during healthcare pediatric visits. J Hypertens. 2015 May;33(5):1064–8. doi: 10.1097/hjh.0000000000000505. PMID: 25955627. Exclusion Code: X4.25668354
224 Steinberger J, Moran A, Hong CP, . Adiposity in childhood predicts obesity and insulin resistance in young adulthood. J Pediatr. 2001;138(4):469–73. Exclusion Code: X3.11295707
225 Stenn PG, Noce A, Buck C. A study of the labelling phenomenon in school children with elevated blood pressure. Clin Invest Med. 1981;4(3–4):179–81. PMID: 7337989. Exclusion Code: X3.7337989
226 Stergiou G, Stambolliu E, Bountzona I, . Home blood pressure monitoring in children and adolescents: systematic review of evidence on clinical utility. Curr Hypertens Rep. 2019;21(8) doi: 10.1007/s11906-019-0967-2. Exclusion Code: X7.
227 Stergiou GS, Boubouchairopoulou N, Kollias A. Accuracy of automated blood pressure measurement in children: evidence, issues, and perspectives. Hypertension. 2017 Jun;69(6):1000–6. doi: 10.1161/hypertensionaha.116.08553. PMID: 27050239. Exclusion Code: X2.28438903
228 Stergiou GS, Nasothimiou E, Giovas P, . Diagnosis of hypertension in children and adolescents based on home versus ambulatory blood pressure monitoring. J Hypertens. 2008 2008/08;26(8):1556–62. doi: 10.1097/hjh.0b013e328301c411. Exclusion Code: X12.18622232
229 Stern B, Heyden S, Miller D, . Intervention study in high school students with elevated blood pressures. Dietary experiment with polyunsaturated fatty acids. Nutr Metab. 1980;24(3):137–47. Exclusion Code: X7.7443094
230 Stone ML, Kelly J, Mistry M, . Use of nicardipine after cardiac operations is safe in children regardless of age. Ann Thorac Surg. 2018 Jan;105(1):181–5. doi: 10.1016/j.athoracsur.2017.05.035. PMID: 29621144. Exclusion Code: X3.28987396
231 Subasinghe AK, Wark JD, Gorelik A, . The association between inflammation, obesity and elevated blood pressure in 16-25-year-old females. J Hum Hypertens. 2017 Sep;31(9):580–4. doi: 10.1038/jhh.2017.33. PMID: 28662937. Exclusion Code: X3.28447628
232 Suh I, Nam CM, Jee SH, . Twelve-year tracking of blood pressure in Korean school children: the Kangwha Study. Yonsei Med J. 1999;40(4):383–7. Exclusion Code: X9.10487143
233 Sullivan JE, Keefe D, Zhou Y, . Pharmacokinetics, safety profile, and efficacy of aliskiren in pediatric patients with hypertension. Clin Pediatr (Phila). 2013 Jul;52(7):599–607. doi: 10.1177/0009922813483875. PMID: 24246011. Exclusion Code: X7.23610239
234 Sun D, Wang T, Heianza Y, . A history of asthma from childhood and left ventricular mass in asymptomatic young adults: The Bogalusa Heart Study. JACC Heart Fail. 2017 Jul;5(7):497–504. doi: 10.1016/j.jchf.2017.03.009. PMID: 28902162. Exclusion Code: X3.28662937
235 Sun J, Steffen LM, Ma C, . Definition of pediatric hypertension: are blood pressure measurements on three separate occasions necessary? Hypertens Res. 2017 May;40(5):496–503. doi: 10.1038/hr.2016.179. PMID: 28284520. Exclusion Code: X4.28077857
236 Tabatabaie M, Hooman N, Arjmandi-Rafsanjani K, . Ambulatory blood pressure monitoring for children with beta-thalassemia major: a preliminary report. Iran J Kidney Dis. 2013 Jul;7(4):299–303. PMID: 23428013. Exclusion Code: X3.23880807
237 Tabbutt S, Nicolson SC, Adamson PC, . The safety, efficacy, and pharmacokinetics of esmolol for blood pressure control immediately after repair of coarctation of the aorta in infants and children: a multicenter, double-blind, randomized trial. J Thorac Cardiovasc Surg. 2008;136(2):321–8. Exclusion Code: X8.18692637
238 Thompson M, Dana T, Bougatsos C, . Screening for hypertension in children and adolescents to prevent cardiovascular disease. Pediatrics. 2013 Mar;131(3):490–525. doi: 10.1542/peds.2012-3523. PMID: 27531686. Exclusion Code: X12.23439904
239 Tkaczyk M, Stanczyk M, Miklaszewska M, . What has changed in the prevalence of hypertension in dialyzed children during the last decade? Ren Fail. 2017 Nov;39(1):283–9. doi: 10.1080/0886022x.2016.1260033. PMID: 28240622. Exclusion Code: X3.27882810
240 Toprak A, Wang H, Chen W, . Relation of childhood risk factors to left ventricular hypertrophy (eccentric or concentric) in relatively young adulthood (from the Bogalusa Heart Study). Am J Cardiol. 2008;101(11):1621–5. Exclusion Code: X3.18489940
241 Trachtman H, Frymoyer A, Lewandowski A, . Pharmacokinetics, pharmacodynamics, and safety of lisinopril in pediatric kidney transplant patients: implications for starting dose selection. Clin Pharmacol Ther. 2015 Jul;98(1):25–33. doi: 10.1002/cpt.127. PMID: 25631221. Exclusion Code: X3.25807932
242 Trevisan M, Cooper R, Ostrow D, . Dietary sodium, erythrocyte sodium concentration, sodium-stimulated lithium efflux and blood pressure. Clin Sci (Lond). 1981;61: Suppl 7:29s–32s. Exclusion Code: X3.7318331
243 Trudeau F, Shephard RJ, Arsenault F, . Tracking of physical fitness from childhood to adulthood. Can J Appl Physiol. 2003;28(2):257–71. Exclusion Code: X3.12825334
244 Tucker DT, Smothers M, Lewis C, . Effects of decreased dietary salt intake on blood pressure in preschool children. J Natl Med Assoc. 1989;81(3):299–302. Exclusion Code: X3.2709432
245 Tullus K. Safety concerns of angiotensin II receptor blockers in preschool children. Arch Dis Child. 2011;96(9):881–2. Exclusion Code: X2.21690106
246 Urbina EM, de Ferranti S, Steinberger J. Observational studies may be more important than randomized clinical trials: weaknesses in US Preventive Services Task Force recommendation on blood pressure screening in youth. Hypertension. 2014 Apr;63(4):638–40. doi: 10.1161/hypertensionaha.113.02662. PMID: 28827377. Exclusion Code: X2.24366081
247 Urbina EM, Khoury PR, McCoy CE, . Comparison of mercury sphygmomanometry blood pressure readings with oscillometric and central blood pressure in predicting target organ damage in youth. Blood Press Monit. 2015;20(3):150–6. Exclusion Code: X3.25647284
248 Valvo E, Bedogna V, Casagrande P. Ambulatory blood pressure measurement in assessing the antihypertensive effect of benazepril plus hydrochlorothiazide in a fixed combination. Clin Ther. 1993;15(4):650–6. Exclusion Code: X3.8221814
249 Van Horn L, Vincent E. The CHILD 1 and DASH diets: rationale and translational applications. Pediatr Ann. 2013 Sep;42(9):372–4. doi: 10.3928/00904481-20130823-11. PMID: 24205227. Exclusion Code: X2.23992218
250 Vandongen R, Jenner DA, Thompson C, . A controlled evaluation of a fitness and nutrition intervention program on cardiovascular health in 10- to 12-year-old children. Prev Med. 1995;24(1):9–22. Exclusion Code: X3.7740021
251 Vieira da Silva MA, Mendes da Silva AP, Artigas Giorgi DM, . Successive blood pressure measurements to evaluate suspected and treated hypertension. Blood Press Monit. 2016 Apr;21(2):69–74. doi: 10.1097/mbp.0000000000000161. PMID: 26859736. Exclusion Code: X3.26484743
252 Voiculescu A, Heusch A, Duppers P, . Duplex ultrasound findings before and after surgery in children and adolescents with renovascular hypertension. Ultrasound Med Biol. 2014 Dec;40(12):2786–93. doi: 10.1016/j.ultrasmedbio.2014.07.011. PMID: 24125483. Exclusion Code: X3.25308948
253 Waguespack SG, Rich T, Grubbs E, . A current review of the etiology, diagnosis, and treatment of pediatric pheochromocytoma and paraganglioma. J Clin Endocrinol Metab. 2010 May;95(5):2023–37. doi: 10.1210/jc.2009-2830. PMID: 20230240. Exclusion Code: X2.20215394
254 Walczak-Galezewska M, Szulinska M, Miller-Kasprzak E, . The effect of nebivolol and ramipril on selected biochemical parameters, arterial stiffness, and circadian profile of blood pressure in young men with primary hypertension: a 12-week prospective randomized, open-label study trial. Medicine (Baltimore). 2018 Jul;97(30):e11717. doi: 10.1097/md.0000000000011717. PMID: 27384018. Exclusion Code: X3.30045336
255 Wang J, Qiu B, Du JL, . The effects of a low-salt diet on the efficacy of different antihypertensive drug regimens. J Clin Pharmacol. 2015 Dec;55(12):1362–8. doi: 10.1002/jcph.559. PMID: 25991503. Exclusion Code: X3.26053853
256 Webb NJ, Lam C, Shahinfar S, . Efficacy and safety of losartan in children with Alport syndrome-results from a subgroup analysis of a prospective, randomized, placebo- or amlodipine-controlled trial. Nephrol Dial Transplant. 2011 Aug;26(8):2521–6. PMID: CN-00812687 NEW. Exclusion Code: X3.21285125
257 Webb NJ, Wells T, Tsai M, . Single-dose pharmacokinetics and safety of azilsartan medoxomil in children and adolescents with hypertension as compared to healthy adults. Eur J Clin Pharmacol. 2016 Apr;72(4):447–57. doi: 10.1007/s00228-015-1987-8. PMID: 26997629. Exclusion Code: X7.26725367
258 Webb NJ, Wells TG, Shahinfar S, . A randomized, open-label, dose-response study of losartan in hypertensive children. Clin J Am Soc Nephrol. 2014 Aug 7;9(8):1441–8. doi: 10.2215/cjn.11111113. PMID: 25336550. Exclusion Code: X3.24875194
259 Wells TG, Blowey DL, Sullivan JE, . Pharmacokinetics of olmesartan medoxomil in pediatric patients with hypertension. Paediatr Drugs. 2012 Dec 1;14(6):401–9. doi: 10.2165/11631450-000000000-00000. PMID: 22949530. Exclusion Code: X7.22880942
260 Williams KM, Shah AN, Morrison D, . Hypertensive retinopathy in severely hypertensive children: demographic, clinical, and ophthalmoscopic findings from a 30-year British cohort. J Pediatr Ophthalmol Strabismus. 2013;50(4):222–8. Exclusion Code: X9.23521027
261 Wingen AM, Fabian-Bach C, Schaefer F, . Randomised multicentre study of a low-protein diet on the progression of chronic renal failure in children. European Study Group of Nutritional Treatment of Chronic Renal Failure in Childhood. Lancet. 1997;349(9059):1117–23. Exclusion Code: X3.9113009
262 Wu B, Xu T, Li Y, . Interventions for reducing inflammation in familial Mediterranean fever. Cochrane Database Syst Rev. 2018(10) doi: 10.1002/14651858.CD010893.pub3. PMID: CD010893. Exclusion Code: X3.
263 Yin X, Liu Q, Bovet P, . Performance of blood pressure-to-height ratio as a screening tool for elevated blood pressure in pediatric population: a systematic meta-analysis. J Hum Hypertens. 2016 Nov;30(11):697–702. doi: 10.1038/jhh.2016.12. PMID: 27432869. Exclusion Code: X7.26935285
264 Yip GW, So HK, Li AM, . Validation of A&D TM-2430 upper-arm blood pressure monitor for ambulatory blood pressure monitoring in children and adolescents, according to the British Hypertension Society protocol. Blood Press Monit. 2012;17(2):76–9. doi: 10.1097/MBP.0b013e328351d4a4. Exclusion Code: X5.22391521
265 Yong LC, Kuller LH. Tracking of blood pressure from adolescence to middle age: the Dormont High School Study. Prev Med. 1994;23(4):418–26. Exclusion Code: X3.7971868
266 Yong LC, Kuller LH, Rutan G, . Longitudinal study of blood pressure: changes and determinants from adolescence to middle age. The Dormont High School follow-up study, 1957-1963 to 1989-1990. Am J Epidemiol. 1993;138(11):973–83. Exclusion Code: X3.8256782
267 Yoon EY, Kopec K, McCool B, . Differences in blood pressure monitoring for children and adolescents with hypertension among pediatric cardiologists and pediatric nephrologists. Clin Pediatr (Phila). 2014 Sep;53(10):1008–12. doi: 10.1177/0009922813512176. PMID: 25280976. Exclusion Code: X6.24322955
268 Zocalo Y, Curcio S, Garcia-Espinosa V, . Comparative analysis of arterial parameters variations associated with inter-individual variations in peripheral and aortic blood pressure: cross-sectional study in healthy subjects aged 2-84 years. High Blood Press Cardiovasc Prev. 2017 Dec;24(4):437–51. doi: 10.1007/s40292-017-0231-2. PMID: 27619066. Exclusion Code: X3.28948506