# Appendix B Inclusion Criteria

## Detailed PubMed Search Strategy

Appendix B Table 1 Combined KQs PubMed (September 3, 2019)

| Terms | Results
#1 | Search ((((“Hypertension “[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match | 459266
#5 | Search ((((“Hypertension”[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match Filters: Publication date from 2012/06/01; Humans; English; Child: birth-18 years | 8522; 8 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 | Search “Mass Screening”[Mesh] Sort by: Best Match | 122515
#7 | Search (#5 AND #6) Sort by: Best Match | 121
#8 | Search “Blood Pressure Determination”[Mesh] Sort by: Best Match | 36787
#9 | Search (#5 OR #8) Sort by: Best Match | 82693
#13 | Search (#5 OR #8) Sort by: Best Match Filters: Publication date from 2012/06/01; Humans; English; Child: birth-18 years | 8665
#14 | Search “Sensitivity and Specificity”[Mesh] OR sensitivity [tw] OR specificity [tw] Sort by: Best Match | 1806029
#15 | Search (#13 AND #14) Sort by: Best Match | 826
#1 | Search ((((“Hypertension”[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match | 459266
#6 | Search ((((“Hypertension”[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match Filters: Publication date from 2012/06/01; Humans; English; Child: birth-18 years | 8526
#7 | Search “Longitudinal Studies”[Mesh] Sort by: Best Match | 126104
#8 | Search (#6 AND #7) Sort by: Best Match | 336
#9 | Search (((((“Atherosclerosis”[Mesh]) OR “Vascular Diseases”[Mesh]) OR “Albuminuria”[Mesh]) OR “Cerebrovascular Disorders”[Mesh]) OR “Hypertrophy, Left Ventricular”[Mesh]) OR “Hypertension”[Mesh] Sort by: Best Match | 1625304
#10 | Search (#8 AND #9) Sort by: Best Match | 196
#11 | Search (“pregnancy”) OR “infant” Sort by: Best Match | 1899814
#12 | Search (#10 NOT #11) Sort by: Best Match | 146
#2 | Search (“Hypertension/diet therapy”[Mesh] OR “Hypertension/drug effects”[Mesh] OR “Hypertension/drug therapy”[Mesh] OR “Hypertension/prevention and control”[Mesh] OR “Hypertension/radiotherapy”[Mesh] OR “Hypertension/rehabilitation”[Mesh] OR “Hypertension/surgery”[Mesh] OR “Hypertension/therapy”[Mesh]) Sort by: Best Match | 95121
#3 | Search ((((“Weight Loss”[Mesh]) OR “Exercise”[Mesh]) OR “Feeding Behavior”[Mesh]) OR “dietary modification” [tw] OR “Diet, Sodium-Restricted”[Mesh]) Sort by: Best Match | 379923
#4 | Search ((((((((((“Angiotensin II Type 2 Receptor Blockers”[Mesh]) OR “Angiotensin-Converting Enzyme Inhibitors”[Mesh]) OR “Labetalol”[Mesh]) OR “Adrenergic beta-Antagonists”[Mesh]) OR “Atenolol”[Mesh]) OR “Bisoprolol”[Mesh]) OR “Metoprolol”[Mesh]) OR “Propranolol”[Mesh]) OR “Calcium Channel Blockers”[Mesh]) OR “Amlodipine”[Mesh]) OR “Felodipine”[Mesh] Sort by: Best Match | 133073
#5 | Search (((((((((“Isradipine”[Mesh]) OR “Nifedipine”[Mesh]) OR ““[Mesh]) OR “Diuretics”[Mesh]) OR “Hydrochlorothiazide”[Mesh]) OR “Chlorthalidone”[Mesh]) OR “Furosemide”[Mesh]) OR “Spironolactone”[Mesh]) OR “Triamterene”[Mesh]) OR “Amiloride”[Mesh] Sort by: Best Match | 112507
#6 | Search “Vasodilator Agents”[Mesh]) OR ““[Mesh]) OR ““[Mesh]) OR ““[Mesh]) OR “Captopril”[Mesh]) OR “Enalapril”[Mesh]) OR “Fosinopril”[Mesh]) OR “Lisinopril”[Mesh]) OR “Losartan”[Mesh]) OR “benazepril” [Supplementary Concept]) OR “quinapril” [Supplementary Concept]) OR “irbesartan” [Supplementary Concept]) Sort by: Best Match | 106836
#7 | Search (#4 OR #5 OR #6) Sort by: Best Match | 278715
#8 | Search (((“administration and dosage” [Subheading]) OR “adverse effects” [Subheading]) OR “therapeutic use” [Subheading]) OR “toxicity” [Subheading] Sort by: Best Match | 4583527
#9 | Search (#7 AND #8) Sort by: Best Match | 142368
#10 | Search (#3 OR #9) Sort by: Best Match | 519578
#11 | Search ((((“Hypertension”[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match | 459266
#12 | Search (#10 AND #11) Sort by: Best Match | 58883
#13 | Search (#2 OR #12) Sort by: Best Match | 119758
#17 | Search (#2 OR #12) Sort by: Best Match Filters: Publication date from 2012/06/01; Humans; English; Child: birth-18 years | 1925
#1 | Search ((((“Hypertension “[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match | 450839
#2 | Search ((((“Hypertension “[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match Filters: Systematic Reviews | 5902
#6 | Search ((((“Hypertension “[Mesh]) OR “Prehypertension”[Mesh]) OR “Blood Pressure”[Mesh])) OR “persistently elevated blood pressure” Sort by: Best Match Filters: Systematic Reviews; Publication date from 2012/06/01; Humans; English; Child: birth-18 years | 230
#1 | Search “secondary hypertension” Sort by: Best Match | 1793
#2 | Search (“Hypertension”[Mesh]) AND “secondary”[Title/Abstract] Sort by: Best Match | 7800
#3 | Search (((((((“Aortic Coarctation”[Mesh]) OR “Cushing Syndrome”[Mesh]) OR “Hyperthyroidism”[Mesh]) OR “Mineralocorticoid Excess Syndrome, Apparent”[Mesh]) OR “Sleep Apnea, Obstructive”[Mesh]) OR “Pheochromocytoma”[Mesh]) OR “Renal Artery Obstruction”[Mesh]) OR “Collagen Diseases”[Mesh] Sort by: Best Match | 128680
#4 | Search “Hypertension”[Mesh] Sort by: Best Match | 247097
#5 | Search (#3 AND #4) Sort by: Best Match | 10950
#6 | Search (((((((“Hypertension, Renovascular”[Mesh]) OR “Williams Syndrome”[Mesh]) OR “Turner Syndrome”[Mesh]) OR “Endocrine System Diseases”[Mesh]) OR “Neurodegenerative Diseases”[Mesh]) OR “Aldosterone”[Mesh]) OR “Pheochromocytoma”[Mesh]) OR “Tuberous Sclerosis”[Mesh] Sort by: Best Match | 1246427
#7 | Search (#4 AND #6) Sort by: Best Match | 45321
#8 | Search (#1 OR #2) Sort by: Best Match | 8302
#9 | Search (#8 OR #5 OR #7) Sort by: Best Match | 55650
#12 | Search (#8 OR #5 OR #7) Sort by: Best Match Filters: Humans; English; Child: birth-18 years | 5850
#13 | Search “Pregnancy”[Mesh] Sort by: Best Match | 868479
#14 | Search (#12 NOT #13) Sort by: Best Match | 5226
#15 | Search (#12 NOT #13) Sort by: Best Match Filters: Systematic Reviews | 64

PubMed Unduplicated Total=2,984; unique in database=2,941

## Other Data Sources

- Cochrane Total=158
- Cochrane Reviews=54
- Cochrane Trials=104
- Embase=325
- ClinicalTrials.gov=19
- Health Services Research Projects in Process (HSRProj)=8
- World Health Organization International Clinical Trials Registry Platform=26
- Total Unduplicated Database=3, 290

Appendix B Table 2 Secondary Hypertension Gap Search PubMed (Inception Through September 3, 2019)

| Terms | Results
#15 | Search ((((“Aortic Coarctation”[Mesh]) OR “Hyperthyroidism”[Mesh]) OR “Pheochromocytoma”[Mesh]) OR “Renal Artery Obstruction”[Mesh]) OR “Polycystic Ovary Syndrome”[Mesh] Sort by: Best Match | 90495 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#16 | Search “Renal parenchymal disease”[tw] OR “Renovascular disease”[tw] Sort by: Best Match | 1204
#17 | Search (#15 OR #16) Sort by: Best Match | 91198 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#18 | Search “Pregnancy”[Mesh] Sort by: Best Match | 868479 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#19 | Search (#17 NOT #18) Sort by: Best Match | 85135
#23 | Search (#17 NOT #18) Sort by: Best Match Filters: Publication date from 2010/01/01; Humans; English; Child: birth-18 years | 3088
#24 | Search (#17 NOT #18) Sort by: Best Match Filters: Systematic Reviews; Publication date from 2010/01/01; Humans; English; Child: birth-18 years | 56
#15 | Search ((((“Aortic Coarctation”[Mesh]) OR “Hyperthyroidism”[Mesh]) OR “Pheochromocytoma”[Mesh]) OR “Renal Artery Obstruction”[Mesh]) OR “Polycystic Ovary Syndrome”[Mesh] Sort by: Best Match | 88886
#16 | Search “Renal parenchymal disease”[tw] OR “Renovascular disease”[tw] Sort by: Best Match | 14
#17 | Search (#15 OR #16) Sort by: Best Match | 88895
#18 | Search “Pregnancy”[Mesh] Sort by: Best Match | 844812
#19 | Search (#17 NOT #18) Sort by: Best Match | 83015
#23 | Search (#17 NOT #18) Sort by: Best Match Filters: Publication date from 2010/01/01; Humans; English; Child: birth-18 years | 2912
#24 | Search (#17 NOT #18) Sort by: Best Match Filters: Systematic Reviews; Publication date from 2010/01/01; Humans; English; Child: birth-18 years | 58

PubMed Secondary Hypertension=58; unique in database=55

Appendix B Table 3 Study Selection Criteria Based on Population, Interventions, Comparators, Outcomes, Timing, and Study Design

Criteria | Include | Exclude
Populations | KQs 1-3: Asymptomatic children and adolescents age 3 to 18 years with no known diagnosis of elevated blood pressure or hypertension; KQs 4-8: Studies in which all participants have elevated blood pressure or hypertension | Pregnant adolescents; populations in which the majority of children or adolescents have high risk for developing high blood pressure and are being treated in a specialty clinic for the underlying condition (e.g., children and adolescents with obesity, neurofibromatosis, chronic kidney disease, cardiac abnormalities, specific genetic disorders)
Interventions | KQs 1, 3: Screening for high blood pressure with three separate measurements, using auscultatory or oscillometric devices (based on established normative thresholds); KQ 2: Index test consisting of at least one blood pressure measurement, using auscultatory or oscillometric devices (based on established normative thresholds); KQs 5-8: Antihypertension medications that are currently approved by the U.S. Food and Drug Administration for use in children, adolescents, or both; Lifestyle modifications, including diet and exercise; Combinations of drug and lifestyle interventions | KQs 1, 3: Screening that cannot be implemented in primary care settings; Screening with fewer than three separate blood pressure measurements; KQ 2: Diagnostic tests not used for screening in primary care settings; KQs 5-8: Interventions that treat underlying causes of secondary hypertension (these interventions will be addressed in CQ 3); Interventions for which treatment of high blood pressure is not the primary objective of the study (i.e., diet and physical activity interventions for weight loss or prevention of weight gain); interventions for the primary prevention of high blood pressure
Comparator | KQs 1, 3: No screening; KQ 2: Diagnosis of elevated blood pressure or hypertension after additional diagnostic workup (e.g., 24-hour or ambulatory blood pressure measurement); KQs 5-8: Placebo, delayed intervention, or other inactive interventions | KQ 2: Any reference test not specified in the inclusion criteria; studies with no reference test; KQs 5-8: Active interventions or usual care
Outcomes | Left ventricular hypertrophy (defined using left ventricular mass index, measures of left ventricular geometry, or both); Urinary albumin excretion (microalbuminuria); IMT (measured at carotid, femoral, or both arteries); Retinal vascular changes; KQ 2: Measures of test accuracy (e.g., positive and negative predictive value, likelihood ratios, sensitivity, specificity, receiver operating characteristic curves); KQ 3: Labeling, anxiety, and school absenteeism; KQ 4: Predictive and prognostic validity (e.g., positive and negative predictive value, likelihood ratios, sensitivity, specificity); measures of association (e.g., odds ratio, risk ratio, correlation or regression coefficient); KQ 8: Harms of drug and nondrug interventions for high blood pressure | KQs 5, 6: Measures of cognitive function; Blood pressure variability, such as diurnal variation, or nocturnal blood pressure dipping; Arterial wall dysfunction, including measures of arterial stiffness, pulse wave velocity, and augmentation index; Metabolic measures, namely glucose tolerance or other measures of impaired glucose tolerance, insulin level, lipid profile, and homocysteine level; Uric acid level; Inflammatory markers, including C-reactive protein; Changes in weight or BMI
Settings | KQs 1, 3: Primary care clinics, well-child/adolescent visits, or ambulatory settings; school- or community-based screening; KQ 4: All settings; KQs 5-8: Pediatric and family practices, pediatric specialty/subspecialty clinics, inpatient or long-term care settings, emergency or urgent care facilities, or ambulatory settings; school- or community-based treatment | KQs 1-3: Pediatric specialty/subspecialty clinics, emergency or urgent care facilities; KQs 5-8: Settings that are not comparable to or referable from primary care
Study Designs | KQ 1: Randomized, controlled trials, controlled clinical trials, observational studies with a comparison group (e.g., comparative cohort and case-control studies), and systematic reviews; KQ 2: Studies of diagnostic test accuracy; KQs 3, 8: Randomized, controlled trials, controlled clinical trials, observational studies with a comparison group (e.g., cohort and case-control studies), and systematic reviews; if none identified, will accept uncontrolled before-after studies; KQ 4: Longitudinal cohort studies; KQs 5-7: Randomized, controlled trials, controlled clinical trials, observational studies with a comparison group (e.g., large [sample size >1,000] cohort and case-control studies), and systematic reviews

Abbreviations: BMI=body mass index; CQ=contextual questions; CVD=cardiovascular disease; ESRD=end-stage renal disease; IMT=intima-media thickness; KQ=key question.