# Appendix A Contextual Questions

## Contextual Question 1 What Is the Prevalence of Primary and Secondary Hypertension in Asymptomatic Children and Adolescents in Primary Care Settings?

### Summary

Four large, retrospective observational studies addressed the prevalence of hypertension in children and adolescents in primary care in the United States in various settings. The observational studies recruited children from a large primary care network,^13^ a Defense Health Insurance Program,^14^ a single health care system^16^ and a school.^15^ Together, these studies provide data on more than 1.7 million participants. The prevalence of hypertension (both primary and secondary) estimates in these studies ranged from 0.54 percent^14^ to 3.7 percent.^16^ These estimates are consistent with those from a systematic review that assessed global hypertension trends in children and adolescents. In the following sections, we describe these studies in more detail.^13–17^

### Detailed Findings

A 2016 retrospective cohort study by Kaelber et al^13^ included data from electronic health records of 196 primary care clinics and 398,079 children across the United States. Clinic encounters occurred between 1999 and 2014. The study enrolled children and adolescents age 3 to 18 years of age who had three separate visits. The study recorded blood pressure, height, weight, visit diagnosis (ICD-9), prescriptions, race, sex, ethnicity, and insurance status. Stage I hypertension was defined by three or more blood pressure readings at or above the 95th percentile and below the 99th percentile for age, height, and sex. Stage II hypertension was defined by blood pressure readings greater than or equal to the 99th percentile for age, height, and sex. The prevalence of hypertension in this cohort was 3.3 percent. Hypertension was more common in females than males (52.6% vs. 47.4%). More children who were overweight/obese had hypertension than children classified as normal weight (54.5% vs. 45.5%, respectively).

The second observational study from 2015 published by Dobson et al^14^ described the prevalence of pediatric hypertension among children in the United States enrolled in the Department of Defense’s health insurance program (TRICARE). The study design was a retrospective cohort study using data from a military health database from 2006 through 2011. Hypertension was defined by two separate clinic encounters with a diagnosis code of “hypertension” of a single visit with a cardiologist or nephrologist who assigned the diagnosis code. Prevalence was calculated for the overall cohort and for pre-pubertal (age 2 to 11 years) and post-pubertal subjects (age 1 to 18 years). Overall, 1,363,626 subjects between age 2 and18 years were enrolled in TRICARE annually during the course of the study. Of those, 16,322 were diagnosed with hypertension; males represented 61 percent of those diagnosed. The prevalence of hypertension in 2011 was 1.6 percent. When stratified by age, the prevalence in children age 2 to 11 years was 0.54 percent. Among children age 12 to 18 years, the prevalence was 3.3 percent.

A retrospective cohort study by Hansen et al^16^ of children and adolescent (age 3 to 18 years) from a single U.S.-based health system found a similar prevalence of hypertension of 3.6 percent.^16^

A prospective cohort study conducted by McNiece et al^15^ from 2003 to 2005 described the prevalence of hypertension among adolescents recruited from secondary schools in Houston, Texas. Demographic information was collected as well as weight, height, and arm circumference. BMI was calculated and defined per Centers for Disease Control and Prevention standard percentile per age and sex. Each subject had blood pressure measured on three occasions with oscillometric blood pressure readings. The average of the three blood pressure measurements was used to determine blood pressure status according to the Fourth Report.^1^ A total of 6,790 students participated in the study. The overall prevalence of hypertension was 3.2 percent. In adjusted analysis, “overweight” was associated with increased odds of hypertension 4.26 (OR, 95% CI, 3.12 to 5.83). No difference in associations was noted in hypertension with males 1.18 (OR, 95% CI, 0.89 to 1.57) compared with females or black and Hispanic subjects compared with white subjects, 1.07 (OR, 95% CI, 0.76 to 1.50) and 0.96 (OR, 95% CI, 0.76 to 1.36), respectively).

An international study by Flynn et al^18^ reported the prevalence of primary and secondary hypertension among children with hypertension who participated in two pharmaceutical studies.^87,^ ^120^ One trial enrolled children <6 years of age with systolic blood pressure ≥95 percent.^120^ Subjects were excluded if the SBP was greater than ≥25 percent of 95th SBP percentile for age, height, and sex. A second trial recruited children between 6-16 years of age with a SBP ≥95% percentile for age, sex, and weight and less than 5 percent above 99 percent percentile for height, weight, and sex.^87^ The inclusion and exclusion criteria were similar between the two studies and included children with a history of aortic coarctation with a gradient of ≥30mmHg, bilateral renal artery stenosis, nonheart or renal transplantation, and use of investigational drug within 30 days or known sensitivity to angiotensin II receptor blockers. Descriptive and bivariate analyses were used to describe differences between subjects with primary hypertension and subjects with secondary hypertension. A total of 351 subjects were enrolled in the studies. Overall, approximately half of the sample had primary hypertension. Prevalence of primary hypertension increased with increasing age, 17 percent in children <6 year of age, 62 percent in children 6 to <12 years of age, and 60 percent among adolescents. The difference was statistically significant (p<0.0001).

A systematic review published in 2016 by Roulet et al^17^ addressed global blood pressure trends in children and adolescents. Studies were included if they reported on mean blood pressure at two time points, involved children 0 to 19 years of age, were conducted in a defined region, and used a cross-sectional design and population or school-based sampling. The review included 18 studies published between 1963 and 2012. The majority of studies were conducted in “high income” countries, and three were from the United States (Appendix A Table 1). Thirteen studies were school based, and the remaining were population analyses. The total number of subjects was 2,042,470 with an age range of 4 to 19 years. Of the studies conducted in the United States, the reported overall prevalence of hypertension ranged between 1.6 percent and 3.7 percent. Two studies stratified prevalence of hypertension by sex and found the prevalence of hypertension among females to range between 1.9 percent and 5.8 percent and among males between 1.8 percent and 4.4 percent. Appendix A Table 1 summarizes prevalence estimates of the four U.S.-based observational studies and individual studies classified as “high-income,^17^ as well as the other studies previously discussed.^13^

## Contextual Question 2 What Are the Optimal Ages at Which to Start Screening for High Blood Pressure and the Optimal Time Intervals at Which to Repeat Screening in Children and Adolescents?

We did not find any studies that directly identified optimal ages to start blood pressure screening or optimal time intervals to repeat such screening.

Some small studies suggest that screening may be less reliable in younger ages.^127^ Conversely, treatment of secondary causes of hypertension at younger ages may be associated with reduced risk of hypertension at followup (see CQ 4 for more on treatment outcomes of causes of secondary hypertension).

Screening in younger age groups is complicated by patient size and level of cooperation. Measurements are more accurate with an appropriately sized cuff and when the patient is calm and still. From a practical standpoint, these conditions that are more difficult to consistently obtain for smaller and younger children and may vary by screeners’ skill level and experience. Unpublished data from Kulaga and Litwin found that 41 percent of blood pressure readings for infants age 1 to 12 months were unreliable,^127^ 20 percent of those readings in children under age 3 years were unreliable, and 9 percent of those readings in children age 3 to 6 years were unreliable. Similarly, 24-hour ABPM is not reliable in children under age 5 years.^127^

## Contextual Question 3 What Are the Associations Between Intermediate Outcomes Related to High Blood Pressure in Children and Adolescents and Health Outcomes Related to High Blood Pressure in Children, Adolescents, and Adults?

### Summary

Hypertension can damage key organs and lead to increased morbidity and mortality. Specifically, we found evidence from large longitudinal cohort studies indicating that hypertension in adolescents and young adults is associated with ESRD and mortality from cerebrovascular events during adulthood.^116–119^ The relevant studies are described in more detail below.

### Detailed Findings

A 2019 retrospective study by Leiba et al^117^ explored the association between hypertension in adolescence and risk of ESRD. Data for the study came from the Israel Defense Forces regional recruitment centers between January 1, 1967, and December 31, 2013. The cohort included males and females between the ages of 16 and 19 years. The Israel Defense Forces data was linked with the ESRD registry. The median followup was 19.6 years. Unadjusted and adjusted Cox proportional hazards models were conducted to estimate the risk of ERSD. A total of 2,658, 238 subjects were included in the analysis, of whom 7,997 had a diagnosis of hypertension. Ninety percent of those with hypertension were male, and approximately half were diagnosed with overweight or obesity. In adjusted analyses, hypertension was associated with an almost twofold (HR, 1.98 [95% CI, 1.42 to 2.77]) risk of ESRD compared with nonhypertensive individuals.

A 2016 retrospective cohort study by Leiba et al^118^ explored the risk of hypertension diagnosed in adolescence and cardiovascular mortality in adulthood. The cohort consisted of 2, 298, 130 subjects. The cohort included males and females between age 16 and 19 years who presented for mandatory Israeli military service. Examinations occurring between January 1, 1967, and December 2010 were included in the cohort. Individuals with a diagnosis code of “essential hypertension” were classified as having hypertension. The outcomes of interest were death secondary to cerebrovascular disease, coronary heart disease, death of unclear etiology, and total cerebrovascular death (i.e., the sum of deaths from cerebral vascular disease, coronary artery disease, and sudden death). The mean followup time was 19.9 years. Information on the outcomes of interest was obtained through the Israel Ministry of Health and linked to an individual’s record. Cox proportional hazard models were used to estimate risk and were adjusted for BMI. Males and subjects with higher BMI were more likely to be hypertensive. Individuals with hypertension had a HR of 3.12 (95% CI, 1.76 to 5.54, p<0.001) of cerebrovascular death. Individuals with hypertension, however, did not have an increase in risk of death from coronary artery disease or sudden death. In the adjusted model, hypertension was not associated with mortality from CVD mortality.

A retrospective cohort study by Gray et al^119^ from 2011 explored the risk of mortality from CVD among men with a diagnosis of hypertension. Males enrolling in Harvard University undergraduate programs between 1916 and 1950 and who completed a health survey in 1962 or 1966 were included in the study. Mean age of enrollment was 18.3 (1.7) years. Median followup time was 60 years. The cohort was approximately 80 percent complete. Information on blood pressure was obtained during routine medical examination. Blood pressure was classified according to the 7th Report on the Joint National Committee on Prevention, Detection, Evaluation and Treatment of High Blood Pressure.^72^ The outcome of interest was overall mortality, mortality from CVD, coronary artery disease, and stroke. Information on outcome measures was obtained from the Harvard Alumni Office, which collects copies of death certificates of its alumni. A total of 18,881 men were included in the study. Men with prehypertension had an increased risk of death from cardiovascular mortality (HR, 1.13 [95% CI, 1.04 to 1.24]) and coronary heart disease (HR, 1.21 [95% CI, 1.07 to 1.36]) compared with men with normal blood pressure. No association was seen between overall mortality or mortality secondary to stroke in men with a diagnosis of prehypertension compared with men with normal blood pressure. Men with Stage 1 or 2 hypertension at the time of university entry had increased risk for all-cause mortality (Stage 1 hypertension HR, 1.14 [95% CI, 1.06 to 1.18]; Stage 2 hypertension HR, 1.28 [95% CI, 1.11 to 1.48]), mortality from CVD (Stage 1 hypertension HR, 1.28 [95% CI, 1.14 to 1.44]; Stage 2 hypertension HR, 1.51 [95% CI, 1.23 to 1.86]), and mortality from coronary heart disease (Stage 1 hypertension HR, 1.46 [95% CI, 1.25 to 1.70]); Stage 2 hypertension 1.89 (95% CI, 1.46 to 2.45) compared with men with normal blood pressure. No association was seen between hypertension at the time of university entry and risk for stroke.

To clarify the association between CVD in childhood and adult outcomes, the i3C was developed.^116^ The consortium includes seven international and U.S.-based longitudinal studies.^128^ Two of the specific aims for the study are to evaluate the relationship between childhood cardiovascular risk factors and adult cardiovascular endpoints and determine the association of cardiovascular risk score trajectories on adult cardiovascular endpoints.^116^ The Consortium is an ongoing study and is funded through November 2019.

## Contextual Question 4 What Are the Effectiveness and Adverse Effects of Drug, Nondrug, and Combination Interventions for Treating the Underlying Conditions of Secondary Hypertension in Children and Adolescents?

### Summary

Treatment of underlying etiologies is largely successful in reducing blood pressure in a large proportion of children and adolescents with secondary hypertension. Treatment success varies somewhat by etiology of secondary hypertension and sometimes by patient age at the time of treatment. For most causes of secondary hypertension, evidence is limited by relatively small case series and retrospective cohort studies.

### Detailed Findings

#### Renal Disease

The most frequent causes of pediatric secondary hypertension are renal parenchymal and renovascular disease. A prospective longitudinal cohort study followed 20 children with proteinuria from chronic nephropathy that were treated with an ACE inhibitor with or without an ARB from 2002 to 2014 and found that nine (45%) had achieved remission at the 48-month followup. Eight children (40%) required decreases in doses due to hypotension (n=6) or hyperkalemia (n=2); no children had severe refractory hyperkalemia, anemia, or other serious adverse events related to treatment.^129^

A number of recent retrospective chart reviews have found that treatment of renovascular disease with percutaneous transluminal angioplasty (PTA), surgery, and/or medications generally improves or resolves hypertension.^130–133^ One chart review found that of 46 children having been treated with PTA, surgery, and/or medication, most (86%) had normal or improved blood pressure at median 6.5 years followup.^130^ Another case series of 28 patients undergoing a total of 42 PTAs found that 10 patients (36%) were deemed cured with sustained normal blood pressures and an additional eight (32%) had improved blood pressures. Three patients (11%) had major complications as a result of PTA (renal loss, false aneurysm requiring additional surgery, seizure and burst balloon with fragmentation of guidewire). Eighteen PTAs (43%) in an unclear number of patients resulted in minor complications.^131^ Another looked at outcomes of 78 children who underwent PTA for renovascular hypertension. Thirty-six (46%) were asymptomatic at baseline and diagnosed with renovascular hypertension only after investigation of underlying cause of incidentally found hypertension. This study found that blood pressure improved in 49 patients (63%) after PTA, of whom 18 (23%) had complete resolution of their hypertension. Complications occurred in 13 (11%) of 114 procedures, including one patient death from hemorrhage.^132^ In another study of 24 patients with renovascular hypertension treated with medication, PTA, and/or surgery, nine were well controlled at followup, while five developed chronic kidney disease.^133^

#### Aortic Disease

Aortic coarctation is a less frequent but serious etiology of secondary hypertension that can lead to cardiac failure and death if left untreated. A 2012 Cochrane review aimed at assessing the effectiveness and safety of PTA compared with surgery in aortic coarctation examined the full text of only five potential studies, all of which were excluded for lack of an eligible comparator.^134^ One retrospective review of 87 patients undergoing surgical correction for aortic coarctation found that most did not need long-term antihypertensive medications and that the proportion of patients needing them was higher if surgical correction occurred after 12 months of age (40%) compared with between 1 and 12 months of age (29%) or less than 1 month of age (7%).^135^ A prospective, 19-site study of children with hypertension from aortic coarctation in the Coarctation of the Aorta Stent Trial also found that younger age at time of treatment correlated with better long-term outcomes. At the 24-month followup, 53 percent (n=21) of those who had been on antihypertensive medications at baseline no longer required them, while 10 percent (n=4) were using a decreased number of antihypertensives and 3 percent (n=1) were on a higher number of antihypertensive medications. Continued use of antihypertensive medications was associated with older age at the time of stent implantation. Of the total 105 patients with aortic coarctation that were included, 104 had successful stent placement, of which all had immediate reduction in blood pressure and sustained improvement at followup. There were no reported procedural deaths or adverse events and a total of 11 stent fractures over the 2-year followup.^136^ Another study examined 31 patients who had undergone stent management for aortic coarctation a mean of 5.3 years after correction. Investigators asked participants to engage in exercise while being monitored with 24-hour ABPM and found that 45 percent of participants had hypertension. This study excluded younger children that investigators felt were unable to engage in the exercise component; given other studies’ associations between better outcomes with younger age of repair, this may overestimate the proportion of children with hypertension at followup.^137^

Two studies examined treatments of midaortic syndrome or narrowing of the abdominal aorta. One systematic review of patients with midaortic syndrome looked at 184 articles about 630 individual cases.^138^ Most were hypertensive at the time of presentation (87%), and most cases were idiopathic (64%). They were treated with medications, surgery, and/or PTA with or without stenting. Of the 68 percent of cases that reported followup data, 119 cases (19%) were normotensive without antihypertensive medications, 167 (26.5%) were normotensive on antihypertensive medications, 48 (8%) were uncontrolled, and 121 (19%) were normotensive without mention of whether on medications. Of those cases reporting mortality data, 2.3 percent of PTA cases and 2.9 percent of surgical cases led to death related to intervention with higher rates of complications in those with associated arteritis.^138^ One retrospective chart review of 53 children with midaortic syndrome treated with PTA, surgery, and/or medications found that 69 percent were normotensive at most recent followup. Thirteen of the 22 patients who had left ventricular hypertrophy at presentation (59%) had resolution at followup. All five patients who had left ventricular dysfunction at presentation recovered function completely at followup. There were 16 complications in 59 catheterization procedures, including one death, and five complications in 22 surgical procedures.^139^

#### Other Causes of Secondary Hypertension

A retrospective chart review of 10 pediatric patients with pheochromocytoma treated with alpha blockade and beta blockade medications before surgery found that all patients were able to discontinue all blood pressure medications.^140^

A meta-analysis of treatments for polycystic ovarian syndrome reviewed four randomized, controlled trials comparing metformin to oral contraceptive pill treatment.^141^ The meta-analysis did not comment on blood pressure outcomes. It did find that treatment with metformin better reduced BMI and dysglycemia, oral contraceptive pills better improved menstrual cycle frequency and acne, and the two medication types improved hirsuitism similarly. Adverse events included gastrointestinal upset, headache, mastalgia, and mood changes.^141^

Appendix A Table 1 Study Characteristics and Prevalence of Hypertension

Author, Year of Publication | Setting | Study Period | Number of Participants | Age (years) | Prevalence of HTN (SD)
Din-Dzietham et al, 2007^a^,^121^ | United States | 1963-2002 | 26,405 | 8-17 | 3.7% (0.4)
Dobson et al, 2015^14^ | United States/military health system | 2006-2011 | Average of 1,363,626 enrolled each year | 2-18 | Overall: 1.6% (NR); Age 2-11: 0.54% (NR); Age 12-18: 3.3% (NR)
Freedman et al, 2012^a^,^122^ | United States | 1974-1993 | 11,478 | 5-17 | Boys: 4.1% (NR); Girls: 5.8% (NR)
Hansen et al, 2007^16^ | United States/single health care system | 1999-2006 | 14, 187 | 3-18 | 3.6% (NR)
Kaelber et al, 2016^13^ | United States/CER consortium | 1999-2014 | >1.2 million | 3-18 | 3.3% (NR)
Khang et al, 2011^a^,^123^ | South Korea | 1998-2008 | 5,905 | 10-19 | Boys: 4.4% (NR); Girls: 1.9% (NR)
Lin, et al, 2012^a^,^124^ | Taiwan | 1996-2006 | 2,557 | 12-14 | Boys: 29.7 (NR); Girls: 20.7 (NR)
McCrindle et al, 2010^a^,^125^ | Canada | 2002-2008 | 20,719 | 14-15 | 9% (NR)
McNiece et al, 2007^15^ | United States/school based | 2003-2005 | 6,790 | 11-17 | 3.2% (NR)
Xi et al, 2016^a^,^126^ | United States | 1999-2012 | 14, 270 | 6-17 | 1.6% (0.3); Boys: 1.8% (0.5); Girls: 1.4% (0.2)

a AStudy was reported in systematic review by Roulet et al.

Abbreviations: HTN=hypertension; NR=not reported; SD=standard deviation.