# References

1 Centers for Disease Control and Prevention. Sexually Transmitted Diseases Treatment Guidelines, 2015. Atlanta, GA: U.S. Department of Health and Human Services; 2015. PMID: None.
2 World Health Organization. Sexually transmitted infections (STIs). http://www.who.int/mediacentre/factsheets/fs110/en/. Accessed April 3, 2019. PMID.
3 Centers for Disease Control and Prevention. Gonorrhea - CDC Fact Sheet (Detailed Version). https://www.cdc.gov/std/gonorrhea/stdfact-gonorrhea-detailed.htm. Accessed April 3, 2019. PMID: None.
4 Centers for Disease Control and Prevention. Syphilis - CDC Fact Sheet (Detailed). https://www.cdc.gov/std/syphilis/stdfact-syphilis-detailed.htm. Accessed April 3, 2019. PMID.
5 DynaMed Plus. Acute hepatitis B virus (HBV) infection. http://www.dynamed.com/topics/dmp~AN~T913216/Acute-hepatitis-B-virus-HBV-infection. Accessed April 3, 2019. PMID.
6 National Cancer Institute. HPV and Cancer. https://www.cancer.gov/about-cancer/causes-prevention/risk/infectious-agents/hpv-and-cancer. Accessed April 3, 2019. PMID: None.
7 Centers for Disease Control and Prevention. Chlamydia - CDC Fact Sheet (Detailed). https://www.cdc.gov/std/chlamydia/stdfact-chlamydia-detailed.htm. Accessed April 3, 2019. PMID.
8 Korenromp EL, Sudaryo MK, de Vlas SJ, . What proportion of episodes of gonorrhoea and chlamydia becomes symptomatic? International journal of STD & AIDS. 2002;13(2):91–101.11839163
9 Farley TA, Cohen DA, Elkins W. Asymptomatic sexually transmitted diseases: the case for screening. Preventive medicine. 2003;36(4):502–9.12649059
10 Centers for Disease Control and Prevention. Trichomoniasis - CDC Fact Sheet. https://www.cdc.gov/std/trichomonas/stdfact-trichomoniasis.htm. Accessed Jan 16, 2018. PMID.
11 Committee on a National Strategy for the Elimination of Hepatitis B, Board on Population H, Public Health P, . Eliminating the Public Health Problem of Hepatitis B and C in the United States: Phase One Report. The National Academies Press. 2016. PMID: 2733611327336113. 10.17226/23407
12 Centers for Disease Control and Prevention. Pelvic Inflammatory Disease (PID) - CDC Fact Sheet. https://www.cdc.gov/std/pid/stdfact-pid-detailed.htm. Accessed Jan 16, 2018. PMID.
13 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2017. Atlanta, GA: U.S. Department of Health and Human Services; 2018. PMID: None.
14 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2018. Atlanta, GA: U.S. Department of Health and Human Services; 2019. PMID: None.
15 Centers for Disease Control and Prevention. CDC Fact Sheet: Reported STDs in the United States. 2016.
16 Haggerty CL, Gottlieb SL, Taylor BD, . Risk of sequelae after Chlamydia trachomatis genital infection in women. The Journal of infectious diseases. 2010;201(Supplement_2):S134–S55.20470050
17 Oakeshott P, Kerry S, Aghaizu A, . Randomised controlled trial of screening for Chlamydia trachomatis to prevent pelvic inflammatory disease: the POPI (prevention of pelvic infection) trial. Bmj. 2010;340:c1642.20378636
18 Centers for Disease Control Prevention. Antibiotic resistance threats in the United States. 2013.
19 Sutton M, Sternberg M, Koumans EH, . The prevalence of Trichomonas vaginalis infection among reproductive-age women in the United States, 2001–2004. Clinical Infectious Diseases. 2007;45(10):1319–26.17968828
20 Glynn K, Daugherty M, Byler T. Prevalence of Trichomonas vaginalis Infection Among US Males, 2013–2016. Clinical Infectious Diseases. 2018;68(3):460–5. 10.1093/cid/ciy499
21 Kissinger P. Epidemiology and treatment of trichomoniasis. Current infectious disease reports. 2015;17(6):31.
22 Silver BJ, Guy RJ, Kaldor JM, . Trichomonas vaginalis as a cause of perinatal morbidity: a systematic review and meta-analysis. Sexually transmitted diseases. 2014;41(6):369–76.24825333
23 HIV.gov. U.S. Statistics https://www.hiv.gov/hiv-basics/overview/data-and-trends/statistics. Accessed Jan 16, 2018. PMID.
24 Centers for Disease Control and Prevention. HIV Surveillance Report, 2017; vol 29. https://www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-report-2017-vol-29.pdf. Accessed April 3, 2019. PMID: None.
25 Centers for Disease Control and Prevention. About HIV/AIDS. https://www.cdc.gov/hiv/basics/whatishiv.html. Accessed April 24, 2019. PMID.
26 Centers for Disease Control and Prevention. Genital HPV Infection - Fact Sheet. https://www.cdc.gov/std/hpv/HPV-FS-July-2017.pdf. Accessed April 24, 2019. PMID: None.
27 McQuillan G, Kruszon-Moran D, Markowitz LE, . Prevalence of HPV in adults aged 18–69: United States, 2011–2014. NCHS data brief. 2017;280:1–8.
28 Centers for Disease Control and Prevention. How Many Cancers Are Linked with HPV Each Year? https://www.cdc.gov/cancer/hpv/statistics/cases.htm. Accessed April 24, 2019. PMID: None.
29 Centers for Disease Control and Prevention. Basic Information about HPV and Cancer. https://www.cdc.gov/cancer/hpv/basic_info/index.htm. Accessed April 24, 2019. PMID.
30 Williams WW. Surveillance of Vaccination Coverage Among Adult Populations—United States, 2015. MMWR Surveillance Summaries. 2017;66.
31 Walker TY, Elam-Evans LD, Singleton JA, . National, regional, state, and selected local area vaccination coverage among adolescents aged 13–17 years—United States, 2016. MMWR Morbidity and mortality weekly report. 2017;66(33):874.28837546
32 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance, 2016. Atlanta, GA: U.S. Department of Health and Human Services; 2017. PMID: None.
33 Hirth J, McGrath CJ, Kuo YF, . Impact of human papillomavirus vaccination on racial/ethnic disparities in vaccine-type human papillomavirus prevalence among 14-26year old females in the U.S. Vaccine. 2018;36(50):7682–8. 10.1016/j.vaccine.2018.10.075 30377066
34 Centers for Disease Control and Prevention. Genital Herpes - CDC Fact Sheet (Detailed). https://www.cdc.gov/std/herpes/stdfact-herpes-detailed.htm. Accessed April 24, 2019. PMID.
35 Wald A. Genital HSV-1 infections. Sex Transm Infect. 2006;82(3):189–90. 10.1136/sti.2006.019935 16731663
36 Wald A, Zeh J, Selke S, . Reactivation of genital herpes simplex virus type 2 infection in asymptomatic seropositive persons. New England Journal of Medicine. 2000;342(12):844–50.10727588
37 James SH, Kimberlin DW. Neonatal herpes simplex virus infection. Infectious Disease Clinics. 2015;29(3):391–400.26154662
38 Freeman EE, Weiss HA, Glynn JR, . Herpes simplex virus 2 infection increases HIV acquisition in men and women: systematic review and meta-analysis of longitudinal studies. Aids. 2006;20(1):73–83.16327322
39 V Barnabas R, Celum C. Infectious co-factors in HIV-1 transmission herpes simplex virus type-2 and HIV-1: new insights and interventions. Current HIV research. 2012;10(3):228–37.22384842
40 Corey L, Wald A, Celum CL, . The effects of herpes simplex virus-2 on HIV-1 acquisition and transmission: a review of two overlapping epidemics. JAIDS Journal of Acquired Immune Deficiency Syndromes. 2004;35(5):435–45.15021308
41 Roberts H, Kruszon-Moran D, Ly KN, . Prevalence of chronic hepatitis B virus (HBV) infection in U.S. households: National Health and Nutrition Examination Survey (NHANES), 1988-2012. Hepatology (Baltimore, Md). 2016;63(2):388–97. PMID: 26251317. 10.1002/hep.28109 26251317
42 Dionne-Odom J, Tita AT, Silverman NS. #38: Hepatitis B in pregnancy screening, treatment, and prevention of vertical transmission. Am J Obstet Gynecol. 2016;214(1):6–14. PMID: 26454123. 10.1016/j.ajog.2015.09.100 26454123
43 Schillie S, Vellozzi C, Reingold A, . Prevention of Hepatitis B Virus Infection in the United States: Recommendations of the Advisory Committee on Immunization Practices. MMWR Recomm Rep. 2018;67(1):1–31. 10.15585/mmwr.rr6701a1
44 Baral S, Logie CH, Grosso A, . Modified social ecological model: a tool to guide the assessment of the risks and risk contexts of HIV epidemics. BMC Public Health. 2013;13:482. 10.1186/1471-2458-13-482 23679953
45 Hogben M, Leichliter JS. Social determinants and sexually transmitted disease disparities. Sex Transm Dis. 2008;35:(12 Suppl):S13–8. 10.1097/OLQ.0b013e31818d3cad 18936725
46 Ford JV, Ivankovich MB, Douglas JM, Jr., . The Need to Promote Sexual Health in America: A New Vision for Public Health Action. Sex Transm Dis. 2017;44(10):579–85. 10.1097/OLQ.0000000000000660 28876308
47 Ward H. Prevention strategies for sexually transmitted infections: importance of sexual network structure and epidemic phase. Sexually transmitted infections. 2007;83(suppl 1):i43–i9.17389716
48 Tobian AA, Kacker S, Quinn TC. Male circumcision: a globally relevant but under-utilized method for the prevention of HIV and other sexually transmitted infections. Annu Rev Med. 2014;65:293–306. PMID: 24111891. 10.1146/annurev-med-092412-090539 24111891
49 Gray RH, Kigozi G, Serwadda D, . Male circumcision for HIV prevention in men in Rakai, Uganda: a randomised trial. Lancet. 2007;369(9562):657–66. PMID: 17321311. 10.1016/S0140-6736(07)60313-4 17321311
50 Bailey RC, Moses S, Parker CB, . Male circumcision for HIV prevention in young men in Kisumu, Kenya: a randomised controlled trial. Lancet. 2007;369(9562):643–56. PMID: 17321310. 10.1016/S0140-6736(07)60312-2 17321310
51 Auvert B, Taljaard D, Lagarde E, . Randomized, controlled intervention trial of male circumcision for reduction of HIV infection risk: the ANRS 1265 Trial. PLoS Med. 2005;2(11):e298. 10.1371/journal.pmed.0020298 16231970
52 World Health Organization. Male circumcision for HIV prevention. http://www.who.int/hiv/topics/malecircumcision/en/. Accessed Jan 29, 2018. PMID.
53 Tobian AA, Serwadda D, Quinn TC, . Male circumcision for the prevention of HSV-2 and HPV infections and syphilis. N Engl J Med. 2009;360(13):1298–309. 10.1056/NEJMoa0802556 19321868
54 Falasinnu T, Gilbert M, Hottes TS, . Predictors identifying those at increased risk for STDs: a theory-guided review of empirical literature and clinical guidelines. Int J STD AIDS. 2015;26(12):839–51. 10.1177/0956462414555930 25324350
55 Shannon CL, Klausner JD. The growing epidemic of sexually transmitted infections in adolescents: a neglected population. Curr Opin Pediatr. 2018;30(1):137–43. 10.1097/MOP.0000000000000578 29315111
56 Mustanski B, Morgan E, D’Aquila R, . Individual and Network Factors Associated With Racial Disparities in HIV Among Young Men Who Have Sex With Men: Results From the RADAR Cohort Study. J Acquir Immune Defic Syndr. 2019;80(1):24–30. 10.1097/QAI.0000000000001886 30365451
57 Herbst JH, Jacobs ED, Finlayson TJ, . Estimating HIV prevalence and risk behaviors of transgender persons in the United States: a systematic review. AIDS Behav. 2008;12(1):1–17. 10.1007/s10461-007-9299-3 17694429
58 Nuttbrock L, Hwahng S, Bockting W, . Lifetime risk factors for HIV/sexually transmitted infections among male-to-female transgender persons. J Acquir Immune Defic Syndr. 2009;52(3):417–21. 10.1097/QAI.0b013e3181ab6ed8 19550351
59 Sevelius J. “There’s no pamphlet for the kind of sex I have”: HIV-related risk factors and protective behaviors among transgender men who have sex with nontransgender men. The Journal of the Association of Nurses in AIDS Care : JANAC. 2009;20(5):398–410. 10.1016/j.jana.2009.06.001 19732698
60 Medina-Perucha L, Family H, Scott J, . Factors Associated with Sexual Risks and Risk of STIs, HIV and Other Blood-Borne Viruses Among Women Using Heroin and Other Drugs: A Systematic Literature Review. AIDS Behav. 2019;23(1):222–51. 10.1007/s10461-018-2238-7 30073636
61 Centers for Disease Control and Prevention. HIV Among Incarcerated Populations. https://www.cdc.gov/hiv/group/correctional.html. Accessed Jan 16, 2018. PMID.
62 Centers for Disease Control and Prevention. HIV Risk Among Persons Who Exchange Sex for Money or Nonmonetary Items. https://www.cdc.gov/hiv/group/sexworkers.html. Accessed. PMID.
63 Pulerwitz J, Amaro H, De Jong W, . Relationship power, condom use and HIV risk among women in the USA. AIDS Care. 2002;14(6):789–800. PMID: 12511212. 10.1080/0954012021000031868 12511212
64 Koblin BA, Grant S, Frye V, . HIV Sexual Risk and Syndemics among Women in Three Urban Areas in the United States: Analysis from HVTN 906. J Urban Health. 2015;92(3):572–83. PMID: 25743100. 10.1007/s11524-015-9944-5 25743100
65 Swan H, O’Connell DJ. The impact of intimate partner violence on women’s condom negotiation efficacy. J Interpers Violence. 2012;27(4):775–92. 10.1177/0886260511423240 21987514
66 Minton HAM, Mittal M, Elder H, . Relationship factors and condom use among women with a history of intimate partner violence. AIDS and Behavior. 2016;20(1):225–34.26354519
67 Senn TE, Carey MP, Vanable PA, . Partner dependence and sexual risk behavior among STI clinic patients. Am J Health Behav. 2010;34(3):257–66. PMID: PMC2920615.20001183
68 Fontenot HB, Fantasia HC, Lee-St John TJ, . The Effects of Intimate Partner Violence Duration on Individual and Partner-Related Sexual Risk Factors Among Women. Journal of Midwifery & Women’s Health. 2014;59(1):67–73.
69 Centers for Disease Control and Prevention. STDs during Pregnancy - CDC Fact Sheet (Detailed). https://www.cdc.gov/std/pregnancy/stdfact-pregnancy-detailed.htm. Accessed Jan 16, 2018. PMID.
70 Prevention CfDCa. A Guide to Taking a Sexual History. Atlanta, GA: Centers for Disease Control and Prevention; 2011. PMID.
71 Centers for Disease Control and Prevention NCfHVHSaTP. A Guide to Taking a Sexual History. https://www.cdc.gov/std/treatment/SexualHistory.pdf. Accessed April 24, 2019. PMID: None.
72 Committee on A. Contraception for adolescents. Pediatrics. 2014;134(4):e1244–56. PMID: 25266430. 10.1542/peds.2014-2299 25266430
73 Physicians AAoF. Clinical Preventive Services Recommendation: Sexually Transmitted Infections. https://www.aafp.org/patient-care/clinical-recommendations/all/stis.html. Accessed January 2, 2018. PMID.
74 ACOG Committee Opinion no. 598: Committee on Adolescent Health Care: The initial reproductive health visit. Obstet Gynecol. 2014;123(5):1143–7. PMID: 24785880. 10.1097/01.AOG.0000446826.46833.c0 24785880
75 Committee on Gynecologic P. Committee opinion No. 534: well-woman visit. Obstet Gynecol. 2012;120(2 Pt 1):421–4. PMID: 22825111. 10.1097/AOG.0b013e3182680517 22825111
76 Altarum Institute. Sexual Health and Your Patients: A Provider’s Guide. Washington, DC: Altarum Institute; 2016. PMID.
77 Brookmeyer KA, Hogben M, Kinsey J. The Role of Behavioral Counseling in Sexually Transmitted Disease Prevention Program Settings. Sex Transm Dis. 2016;43(2 Suppl 1):S102–12. 10.1097/OLQ.0000000000000327 26779681
78 Prevention CfDCa. Effective Interventions: HIV Prevention that Works. https://effectiveinterventions.cdc.gov/. Accessed January 2, 2017. PMID.
79 ACOG Committee on Health Care for Underserved Women. ACOG Committee Opinion No. 525: Health care for lesbians and bisexual women. Obstet Gynecol. 2012;119(5):1077–80. PMID: 22525932. 10.1097/AOG.0b013e3182564991 22525932
80 Oakeshott P, Graham A. NICE guidance on one-to-one interventions to reduce sexually transmitted infections and under-18 conceptions: a view from general practice. Sex Transm Infect. 2007;83(2):171–2. PMID: 17435056. 10.1136/sti.2007.025106 17435056
81 Miller KS, Wyckoff SC, Lin CY, . Pediatricians’ role and practices regarding provision of guidance about sexual risk reduction to parents. J Prim Prev. 2008;29(3):279–91. PMID: 18461458. 10.1007/s10935-008-0137-9 18461458
82 Goyal MK, Witt R, Hayes KL, . Clinician adherence to recommendations for screening of adolescents for sexual activity and sexually transmitted infection/human immunodeficiency virus. J Pediatr. 2014;165(2):343–7. PMID: 24840761. 10.1016/j.jpeds.2014.04.009 24840761
83 Clark JK, Brey RA, Banter AE, . The Delivery of Sexuality-related Patient Education to Adolescent Patients: A Preliminary Study of Family Practice Resident Physicians. J Family Med Prim Care. 2012;1(1):34–8. PMID: 24478998. 10.4103/2249-4863.94449 24478998
84 Ashton MR, Cook RL, Wiesenfeld HC, . Primary care physician attitudes regarding sexually transmitted diseases. Sex Transm Dis. 2002;29(4):246–51. PMID: 11912468.11912468
85 Sobecki JN, Curlin FA, Rasinski KA, . What we don’t talk about when we don’t talk about sex: results of a national survey of U.S. obstetrician/gynecologists. J Sex Med. 2012;9(5):1285–94. PMID: 22443146. 10.1111/j.1743-6109.2012.02702.x 22443146
86 Chung PJ, Lee TC, Morrison JL, . Preventive care for children in the United States: quality and barriers. Annu Rev Public Health. 2006;27:491–515. PMID: 16533127. 10.1146/annurev.publhealth.27.021405.102155 16533127
87 Mark H, Irwin K, Sternberg M, . Providers’ perceived barriers to sexually transmitted disease care in 2 large health maintenance organizations. Sex Transm Dis. 2008;35(2):184–9. PMID: 18046264. 10.1097/OLQ.0b013e31815a9f7e 18046264
88 Wiesenfeld HC, Dennard-Hall K, Cook RL, . Knowledge about sexually transmitted diseases in women among primary care physicians. Sex Transm Dis. 2005;32(11):649–53. PMID: 16254537.16254537
89 Bull SS, Rietmeijer C, Fortenberry JD, . Practice patterns for the elicitation of sexual history, education, and counseling among providers of STD services: results from the gonorrhea community action project (GCAP). Sex Transm Dis. 1999;26(10):584–9. PMID: 10560723.10560723
90 U. S. Preventive Services Task Force, Curry SJ, Krist AH, . Screening for Syphilis Infection in Pregnant Women: US Preventive Services Task Force Reaffirmation Recommendation Statement. JAMA. 2018;320(9):911–7. 10.1001/jama.2018.11785 30193283
91 U. S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Screening for Syphilis Infection in Nonpregnant Adults and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;315(21):2321–7. 10.1001/jama.2016.5824 27272583
92 Tanksley A, Cifu AS. Screening for Gonorrhea, Chlamydia, and Hepatitis B. JAMA. 2016;315(12):1278–9. 10.1001/jama.2016.0223 27002450
93 U. S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Serologic Screening for Genital Herpes Infection: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(23):2525–30. 10.1001/jama.2016.16776 27997659
94 Screening for Gynecologic Conditions with Pelvic Examination: Recommendation Statement. Am Fam Physician. 2017;96(4):Online.
95 LeFevre ML, Force USPST. Behavioral counseling interventions to prevent sexually transmitted infections: U.S. PreventiveServices Task Force recommendation statement. Ann Intern Med. 2014;161(12):894–901. PMID: 25244227. 10.7326/M14-1965 25244227
96 O’Connor E, Lin JS, Burda BU, . Behavioral Sexual Risk Reduction Counseling in Primary Care to Prevent Sexually Transmitted Infections: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2014. PMID: 2535644725356447.
97 United Nations Development Programme. 2016 Human Development Report: Human Development for Everyone 1 UN Plaza, New York, NY 10017 USA: 2016. PMID.
98 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID.
99 Brockwell SE, Gordon IR. A comparison of statistical methods for meta-analysis. Stat Med. 2001;20(6):825–40. 10.1002/sim.650 11252006
100 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. 10.1136/bmj.315.7109.629 9310563
101 Sterne JAC, Harbord RM. Funnel plots in meta-analysis. The Stata Journal. 2004;4(2):127–41. 10.1177/1536867X0400400204
102 Ehrhardt AA, Exner TM, Hoffman S, . A gender-specific HIV/STD risk reduction intervention for women in a health care setting: short- and long-term results of a randomized clinical trial. AIDS Care. 2002;14(2):147–61. PMID: 11940275. 10.1080/09540120220104677 11940275
103 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
104 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
105 Bailey JV, Webster R, Hunter R, . The Men’s Safer Sex project: intervention development and feasibility randomised controlled trial of an interactive digital intervention to increase condom use in men. Health Technology Assessment (Winchester, England). 2016;20(91):1–124. PMID: 27966409. 10.3310/hta20910 27966409
106 Benner TA. SiHLE: Health workshops for young black women. Model Programs for Adolescent Sexual Health: Evidence-based HIV, STI and Pregnancy Prevention Interventions. 2008:253–60. PMID: None. None
107 Berenson AB, Rahman M. A randomized controlled study of two educational interventions on adherence with oral contraceptives and condoms. Contraception. 2012;86(6):716–24. PMID: 22840278. 10.1016/j.contraception.2012.06.007 22840278
108 Berkman A, Pilowsky DJ, Zybert PA, . HIV prevention with severely mentally ill men: a randomised controlled trial. AIDS Care. 2007;19(5):579–88. PMID: 17505917. 10.1080/09540120701213989 17505917
109 Besera GT, Cox S, Malotte CK, . Assessing Patient Exposure to a Video-Based Intervention in STD Clinic Waiting Rooms: Findings From the Safe in the City Trial. Health promotion practice. 2016;17(5):731–8. PMID: 27091608. 10.1177/1524839916631537 27091608
110 Billings DW, Leaf SL, Spencer J, . A Randomized Trial to Evaluate the Efficacy of a Web-Based HIV Behavioral Intervention for High-Risk African American Women. AIDS Behav. 2015;19(7):1263–74. PMID: 25616838. 10.1007/s10461-015-0999-9 25616838
111 Carey MP, Carey KB, Maisto SA, . Reducing HIV-risk behavior among adults receiving outpatient psychiatric treatment: results from a randomized controlled trial. J Consult Clin Psychol. 2004;72(2):252–68. PMID: 15065959. 10.1037/0022-006X.72.2.252 15065959
112 Carey MP, Senn TE, Vanable PA, . Brief and intensive behavioral interventions to promote sexual risk reduction among STD clinic patients: results from a randomized controlled trial. AIDS & Behav. 2010;14(3):504–17. PMID: 19590947. 10.1007/s10461-009-9587-1 19590947
113 Carey MP, Senn TE, Walsh JL, . Evaluating a Brief, Video-Based Sexual Risk Reduction Intervention and Assessment Reactivity with STI Clinic Patients: Results from a Randomized Controlled Trial. AIDS Behav. 2015;19(7):1228–46. PMID: 25433653. 10.1007/s10461-014-0960-3 25433653
114 Carey MP, Vanable PA, Senn TE, . Evaluating a two-step approach to sexual risk reduction in a publicly-funded STI clinic: rationale, design, and baseline data from the Health Improvement Project-Rochester (HIP-R). Contemp Clin Trials. 2008;29(4):569–86. PMID: 18325853. 10.1016/j.cct.2008.02.001 18325853
115 Champion JD. Behavioural interventions and abuse: secondary analysis of reinfection in minority women. Int J STD AIDS. 2007;18(11):748–53. PMID: 18005508. 10.1258/095646207782212180 18005508
116 Champion JD, Collins JL. Comparison of a theory-based (AIDS Risk Reduction Model) cognitive behavioral intervention versus enhanced counseling for abused ethnic minority adolescent women on infection with sexually transmitted infection: results of a randomized controlled trial. Int J Nurs Stud. 2012;49(2):138–50. PMID: 21937041. 10.1016/j.ijnurstu.2011.08.010 21937041
117 Costa EC, McIntyre T, Trovisqueira A, . Comparison of two psycho-educational interventions aimed at preventing HIV and promoting sexual health among Portuguese women. International Journal of Sexual Health. 2017;29(3):258–72. PMID: 2017-42146-006. 10.1080/19317611.2017.1307300
118 Crosby R, DiClemente RJ, Charnigo R, . A brief, clinic-based, safer sex intervention for heterosexual African American men newly diagnosed with an STD: a randomized controlled trial. Am J Public Health. 2009;99:(Suppl 1):S96–S103. PMID: 19218185. 10.2105/AJPH.2007.123893 19218185
119 DiClemente RJ, Wingood GM, Harrington KF, . Efficacy of an HIV prevention intervention for African American adolescent girls: a randomized controlled trial. JAMA. 2004;292(2):171–9. PMID: 15249566. 10.1001/jama.292.2.171 15249566
120 Dworkin SL, Beckford ST, Ehrhardt AA. Sexual scripts of women: a longitudinal analysis of participants in a gender-specific HIV/STD prevention intervention. Arch Sex Behav. 2007;36(2):269–79. PMID: 17186128. 10.1007/s10508-006-9092-9 17186128
121 Enrhardt AA, Exner TM, Hoffman S, . HIV/STD risk and sexual strategies among women family planning clients in New York: Project FIO. AIDS Behav. 2002;6(1):1–13. PMID: None.
122 Free C, McCarthy O, French RS, . Can text messages increase safer sex behaviours in young people? Intervention development and pilot randomised controlled trial. Health Technology Assessment (Winchester, England). 2016;20(57):1–82. PMID: 27483185. 10.3310/hta20570 27483185
123 Gallo MF, Margolis AD, Malotte CK, . Sexual abstinence and other behaviours immediately following a new STI diagnosis among STI clinic patients: Findings from the Safe in the City trial. Sexually Transmitted Infections. 2016;92(3):206–10. PMID: 26670913. 10.1136/sextrans-2014-051982 26670913
124 Gift TL, O’Donnell LN, Rietmeijer CA, . The Program Cost of a Brief Video Intervention Shown in Sexually Transmitted Disease Clinic Waiting Rooms. Sexually Transmitted Diseases. 2016;43(1):61–4. PMID: 26650999. 10.1097/OLQ.0000000000000388 26650999
125 Guilamo-Ramos V, Bouris A, Jaccard J, . A parent-based intervention to reduce sexual risk behavior in early adolescence: building alliances between physicians, social workers, and parents. J Adolesc Health. 2011;48(2):159–63. PMID: 21257114. 10.1016/j.jadohealth.2010.06.007 21257114
126 Hoffman S, Exner TM, Leu CS, . Female-condom use in a gender-specific family planning clinic trial. Am J Public Health. 2003;93(11):1897–903. PMID: 14600063.14600063
127 Jemmott JB, III, Jemmott LS, Braverman PK, . HIV/STD risk reduction interventions for African American and Latino adolescent girls at an adolescent medicine clinic: a randomized controlled trial. Arch Pediatr Adolesc Med. 2005;159(5):440–9. PMID: 15867118. 10.1001/archpedi.159.5.440 15867118
128 Jemmott LS, Jemmott JB, III, O’Leary A. Effects on sexual risk behavior and STD rate of brief HIV/STD prevention interventions for African American women in primary care settings. Am J Public Health. 2007;97(6):1034–40. PMID: 17463391. 10.2105/AJPH.2003.020271 17463391
129 Kershaw TS, Magriples U, Westdahl C, . Pregnancy as a window of opportunity for HIV prevention: effects of an HIV intervention delivered within prenatal care. Am J Public Health. 2009;99(11):2079–86. PMID: 19762662. 10.2105/AJPH.2008.154476 19762662
130 Kirby D. An HIV-prevention intervention for African American adolescent girls significantly increased condom use. Evidence-based Obstetrics Gynecology. 2005. PMID: None.
131 Lang DL, DiClemente RJ, Hardin JW, . Threats of cross-contamination on effects of a sexual risk reduction intervention: fact or fiction. Prev Sci. 2009;10(3):270–5. PMID: 19241171. 10.1007/s11121-009-0127-z 19241171
132 Lewis MA, Rhew IC, Fairlie AM, . Evaluating Personalized Feedback Intervention Framing with a Randomized Controlled Trial to Reduce Young Adult Alcohol-Related Sexual Risk Taking. Prev Sci. 2018. PMID: 29511966. 10.1007/s11121-018-0879-4 29511966
133 Marrazzo JM, Thomas KK, Agnew K, . Prevalence and risks for bacterial vaginosis in women who have sex with women. Sex Transm Dis. 2010;37(5):335–9. PMID: 20429087.20429087
134 Marrazzo JM, Thomas KK, Fiedler TL, . Relationship of specific vaginal bacteria and bacterial vaginosis treatment failure in women who have sex with women. Ann Intern Med. 2008;149(1):20–8. PMID: 18591634.18591634
135 Marrazzo JM, Thomas KK, Ringwood K. A behavioural intervention to reduce persistence of bacterial vaginosis among women who report sex with women: results of a randomised trial. Sex Transm Infect. 2011;87(5):399–405. PMID: 21653935. 10.1136/sti.2011.049213 21653935
136 Melendez RM, Hoffman S, Exner T, . Intimate partner violence and safer sex negotiation: effects of a gender-specific intervention. Arch Sex Behav. 2003;32(6):499–511. PMID: 14574094.14574094
137 Metsch LR, Feaster DJ, Gooden L, . Effect of risk-reduction counseling with rapid HIV testing on risk of acquiring sexually transmitted infections: the AWARE randomized controlled trial. JAMA. 2013;310(16):1701–10. PMID: 24150466. 10.1001/jama.2013.280034 24150466
138 Milhausen RR, DiClemente RJ, Lang DL, . Frequency of sex after an intervention to decrease sexual risk-taking among African-American adolescent girls: Results of a randomized, controlled clinical trial. Sex Education. 2008;8:47–57. PMID: None.
139 Miller S, Exner TM, Williams SP, . A gender-specific intervention for at-risk women in the USA. AIDS Care. 2000;12(5):603–12. PMID: 11218546. 10.1080/095401200750003789 11218546
140 Mittal M, Senn TE, Carey MP. Mediators of the relation between partner violence and sexual risk behavior among women attending a sexually transmitted disease clinic. Sex Transm Dis. 2011;38(6):510–5. PMID: 21258269. 10.1097/OLQ.0b013e318207f59b 21258269
141 Mittal M, Senn TE, Carey MP. Fear of violent consequences and condom use among women attending an STD clinic. Women & Health. 2013;53(8):795–807. PMID: 24215273. 10.1080/03630242.2013.847890 24215273
142 Mittal M, Thevenet-Morrison K, Landau J, . An Integrated HIV Risk Reduction Intervention for Women with a History of Intimate Partner Violence: Pilot Test Results. AIDS & Behavior. 2017;21(8):2219–32. PMID: 27172976. 10.1007/s10461-016-1427-5 27172976
143 Morrison-Beedy D, Crean HF, Passmore D, . Risk reduction strategies used by urban adolescent girls in an HIV prevention trial. Current HIV Research. 2013;11(7):559–69. PMID: 24476350.24476350
144 Morrison-Beedy D, Jones SH, Xia Y, . Reducing sexual risk behavior in adolescent girls: results from a randomized controlled trial. Journal of Adolescent Health. 2013;52(3):314–21. PMID: 23299011. 10.1016/j.jadohealth.2012.07.005 23299011
145 Neumann MS, O’Donnell L, Doval AS, . Effectiveness of the VOICES/VOCES sexually transmitted disease/human immunodeficiency virus prevention intervention when administered by health department staff: does it work in the “real world”? Sex Transm Dis. 2011;38(2):133–9. PMID: 20729794. 10.1097/OLQ.0b013e3181f0c051 20729794
146 O’Leary A, Jemmott LS, Jemmott JB. Mediation analysis of an effective sexual risk-reduction intervention for women: the importance of self-efficacy. Health Psychol. 2008;27:(2 Suppl):S180–S4. PMID: 18377160. 10.1037/0278-6133.27.2(Suppl.).S180 18377160
147 Peipert J, Redding CA, Blume J, . Design of a stage-matched intervention trial to increase dual method contraceptive use (Project PROTECT). Contemp Clin Trials. 2007;28(5):626–37. PMID: 17374567. 10.1016/j.cct.2007.01.012 17374567
148 Peipert JF, Redding CA, Blume JD, . Tailored intervention to increase dual-contraceptive method use: a randomized trial to reduce unintended pregnancies and sexually transmitted infections. Am J Obstet Gynecol. 2008;198(6):630–8. PMID: 18395692. 10.1016/j.ajog.2008.01.038 18395692
149 Petersen R, Albright J, Garrett JM, . Pregnancy and STD prevention counseling using an adaptation of motivational interviewing: a randomized controlled trial. Perspect Sex Reprod Health. 2007;39(1):21–8. PMID: 17335378.17355378
150 Proude EM, D’Este C, Ward JE. Randomized trial in family practice of a brief intervention to reduce STI risk in young adults. Fam Pract. 2004;21(5):537–44. PMID: 15367476.15367476
151 Recto P, Champion JD. Psychological Distress and Associated Factors Among Mexican American Adolescent Females. Hisp Health Care Int. 2016;14(4):170–6. PMID: 27852947. 10.1177/1540415316676224 27852947
152 Sales JM, Lang DL, Hardin JW, . Efficacy of an HIV prevention program among African American female adolescents reporting high depressive symptomatology. J Womens Health (Larchmt). 2010;19(2):219–27. PMID: 20109119. 10.1089/jwh.2008.1326 20109119
153 Sanci L, Chondros P, Sawyer S, . Responding to Young People’s Health Risks in Primary Care: A Cluster Randomised Trial of Training Clinicians in Screening and Motivational Interviewing. PLoS ONE. 2015;10(9):e0137581. PMID: 26422235. 10.1371/journal.pone.0137581 26422235
154 Scholes D, McBride CM, Grothaus L, . A tailored minimal self-help intervention to promote condom use in young women: results from a randomized trial. AIDS. 2003;17(10):1547–56. PMID: 12824793. 10.1097/01.aids.0000076280.54156.51 12824793
155 Shain RN, Piper JM, Holden AE, . Prevention of gonorrhea and Chlamydia through behavioral intervention: results of a two-year controlled randomized trial in minority women. Sex Transm Dis. 2004;31(7):401–8. PMID: 15215694.15215694
156 Warner L, Klausner JD, Rietmeijer CA, . Effect of a brief video intervention on incident infection among patients attending sexually transmitted disease clinics. PLoS Med. 2008;5(6):e135. PMID: 18578564. 10.1371/journal.pmed.0050135 18578564
157 Wingood GM, DiClemente RJ, Harrington KF, . Efficacy of an HIV prevention program among female adolescents experiencing gender-based violence. Am J Public Health. 2006;96(6):1085–90. PMID: 16670238. 10.2105/AJPH.2004.053595 16670238
158 Wingood GM, DiClemente RJ, Robinson-Simpson L, . Efficacy of an HIV intervention in reducing high-risk human papillomavirus, nonviral sexually transmitted infections, and concurrency among African American women: a randomized-controlled trial. JAIDS. 2013;63:(Suppl 1):S36–S43. PMID: 23673884. 10.1097/QAI.0b013e3182920031 23673884
159 Ybarra ML, Prescott TL, Phillips GL, 2nd, . Pilot RCT Results of an mHealth HIV Prevention Program for Sexual Minority Male Adolescents. Pediatrics. 2017;140(1). PMID: 28659456. 10.1542/peds.2016-2999 28659456
160 Bai S, Zeledon LR, D’Amico EJ, . Reducing health risk behaviors and improving depression in adolescents: A randomized controlled trial in primary care clinics. J Pediatr Psychol. 2018;43(9):1004–16. PMID: 30016473 10.1093/jpepsy/jsy048 30016473
161 Peragallo Montano N, Cianelli R, Villegas N, . Evaluating a Culturally Tailored HIV Risk Reduction Intervention Among Hispanic Women Delivered in a Real-World Setting by Community Agency Personnel. Am J Health Promot. 2019;33(4):566–75. PMID: 30354190. 10.1177/0890117118807716 30354190
162 O’Cleirigh C, Safren SA, Taylor SW, . Cognitive Behavioral Therapy for Trauma and Self-Care (CBT-TSC) in Men Who have Sex with Men with a History of Childhood Sexual Abuse: A Randomized Controlled Trial. AIDS Behav. 2019;23(9):2421–31. PMID: 30993478. 10.1007/s10461-019-02482-z 30993478
163 Redding C, Prochaska J, Armstrong K, . Randomized trial outcomes of a TTM-tailored condom use and smoking intervention in urban adolescent females. Health Educ Res. 2015;30(1):162–78. PMID: 24794584 10.1093/her/cyu015 24794584
164 Shafii T, Benson S, Morrison D, . Results from e-KiSs: electronic-KIOSK Intervention for Safer Sex: a pilot randomized controlled trial of an interactive computer-based intervention for sexual health in adolescents and young adults. PLoS ONE. 2019;14(1):1–17. PMID: 30673710. 10.1371/journal.pone.0209064 30673710
165 Tzilos Wernette G, Plegue M, Kahler CW, . A Pilot Randomized Controlled Trial of a Computer-Delivered Brief Intervention for Substance Use and Risky Sex During Pregnancy. Journal of Women’s Health. 2018;27(1):83–92. PMID: 28981379. 10.1089/jwh.2017.6408 28981379
166 Whiteley LB, Brown LK, Curtis V, . Publicly Available Internet Content as a HIV/STI Prevention Intervention for Urban Youth. Journal of Primary Prevention. 2018;39(4):361–70. PMID: 30003459. 10.1007/s10935-018-0514-y 30003459
167 Cianelli R, Ferrer L, Norr KF, . Mano a Mano-Mujer: an effective HIV prevention intervention for Chilean women. Health Care Women Int. 2012;33(4):321–41. PMID: 22420675.22420675
168 Cortes-Bordoy J, Vidart JA, Coll-Capdevila C, . Usefulness of an educational leaflet to modify sexual risk behaviour in women with external genital warts. Eur J Dermatol. 2010;20(3):339–44. PMID: 20146965.20146965
169 Marion LN, Finnegan L, Campbell RT, . The Well Woman Program: a community-based randomized trial to prevent sexually transmitted infections in low-income African American women. Res Nurs Health. 2009;32(3):274–85. PMID: 19373824.19373824
170 Boekeloo BO, Schamus LA, Simmens SJ, . A STD/HIV prevention trial among adolescents in managed care. Pediatrics. 1999;103(1):107–15. PMID: 9917447.9917447
171 Boyer CB, Barrett DC, Peterman TA, . Sexually transmitted disease (STD) and HIV risk in heterosexual adults attending a public STD clinic: evaluation of a randomized controlled behavioral risk-reduction intervention trial. AIDS. 1997;11(3):359–67. PMID: 9147428.9147428
172 Danielson R, Marcy S, Plunkett A, . Reproductive health counseling for young men: what does it do? Fam Plann Perspect. 1990;22(3):115–21. PMID: 2379568.2379568
173 Kamb ML, Fishbein M, Douglas JM, Jr., . Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: a randomized controlled trial. Project RESPECT Study Group. JAMA. 1998;280(13):1161–7. PMID: 9777816.9777816
174 Shain RN, Piper JM, Newton ER, . A randomized, controlled trial of a behavioral intervention to prevent sexually transmitted disease among minority women. N Engl J Med. 1999;340(2):93–100. PMID: 9887160.9887160
175 Wenger NS, Greenberg JM, Hilborne LH, . Effect of HIV antibody testing and AIDS education on communication about HIV risk and sexual behavior. A randomized, controlled trial in college students. Ann Intern Med. 1992;117(11):905–11. PMID: 1443951.1443951
176 Magill M, Hallgren KA. Mechanisms of behavior change in motivational interviewing: do we understand how MI works? Curr Opin Psychol. 2018;30:1–5. 10.1016/j.copsyc.2018.12.010 30677627
177 Magill M, Apodaca TR, Borsari B, . A meta-analysis of motivational interviewing process: Technical, relational, and conditional process models of change. J Consult Clin Psychol. 2018;86(2):140–57. 10.1037/ccp0000250 29265832
178 Wenzel A. Basic Strategies of Cognitive Behavioral Therapy. Psychiatr Clin North Am. 2017;40(4):597–609. 10.1016/j.psc.2017.07.001 29080588
179 Fisher JD, Fisher WA, Williams SS, . Empirical tests of an information-motivation-behavioral skills model of AIDS-preventive behavior with gay men and heterosexual university students. Health Psychol. 1994;13(3):238–50.8055859
180 Walsh JL. Applying the Information-Motivation-Behavioral Skills Model to Understand PrEP Intentions and Use Among Men Who Have Sex with Men. AIDS Behav. 2018. 10.1007/s10461-018-2371-3
181 Bandura A. Social Foundations of Thought & Action: A Social Cognitive Theory. 1st ed1986. PMID.
182 Prochaska JO, Velicer WF. The transtheoretical model of health behavior change. Am J Health Promot. 1997;12(1):38–48. 10.4278/0890-1171-12.1.38 10170434
183 Glanz K RB, Viswanath K. Health Behavior and Health Education: Theory, Research, and Practice. 4th ed2008. PMID.
184 Wingood GM, Scd, DiClemente RJ. Application of the theory of gender and power to examine HIV-related exposures, risk factors, and effective interventions for women. Health Educ Behav. 2000;27(5):539–65. 10.1177/109019810002700502 11009126
185 Catania JA, Kegeles SM, Coates TJ. Towards an understanding of risk behavior: an AIDS risk reduction model (ARRM). Health Educ Q. 1990;17(1):53–72.2318652
186 Petrova D, Garcia-Retamero R. Effective Evidence-Based Programs For Preventing Sexually-Transmitted Infections: A Meta-Analysis. Current HIV Research. 2015;13(5):432–8.26149164
187 Ruiz-Perez I, Murphy M, Pastor-Moreno G, . The Effectiveness of HIV Prevention Interventions in Socioeconomically Disadvantaged Ethnic Minority Women: A Systematic Review and Meta-Analysis. American Journal of Public Health. 2017;107(12):e13–e21. 10.2105/AJPH.2017.304067
188 Marcell AV, Gibbs S, Lehmann HP. Brief condom interventions targeting males in clinical settings: a meta-analysis. Contraception. 2016;93(2):153–63. 10.1016/j.contraception.2015.09.009 26410175
189 Covey J, Rosenthal-Stott HE, Howell SJ. A synthesis of meta-analytic evidence of behavioral interventions to reduce HIV/STIs. Journal of behavioral medicine. 2016;39(3):371–85. 10.1007/s10865-016-9714-1 26831053
190 Flowers P, Wu O, Lorimer K, . The clinical effectiveness of individual behaviour change interventions to reduce risky sexual behaviour after a negative human immunodeficiency virus test in men who have sex with men: systematic and realist reviews and intervention development. Health Technology Assessment (Winchester, England). 2017;21(5):1–164.
191 Protogerou C, Johnson BT. Factors underlying the success of behavioral HIV-prevention interventions for adolescents: a meta-review. AIDS & Behavior. 2014;18(10):1847–63. 10.1007/s10461-014-0807-y 24903669
192 Noar SM, Zimmerman RS. Health Behavior Theory and cumulative knowledge regarding health behaviors: are we moving in the right direction? Health Educ Res. 2005;20(3):275–90. 10.1093/her/cyg113 15632099
193 Hunter P, Dalby J, Marks J, . Screening and prevention of sexually transmitted infections. Prim Care. 2014;41(2):215–37. 10.1016/j.pop.2014.02.003 24830606
194 Leichliter JS, Seiler N, Wohlfeiler D. Sexually Transmitted Disease Prevention Policies in the United States: Evidence and Opportunities. Sex Transm Dis. 2016;43(2 Suppl 1):S113–21. 10.1097/OLQ.0000000000000289 26779683
195 Rao A, Tobin K, Davey-Rothwell M, . Social Desirability Bias and Prevalence of Sexual HIV Risk Behaviors Among People Who Use Drugs in Baltimore, Maryland: Implications for Identifying Individuals Prone to Underreporting Sexual Risk Behaviors. AIDS Behav. 2017;21(7):2207–14. 10.1007/s10461-017-1792-8 28509997
196 Rose E, Diclemente RJ, Wingood GM, . The validity of teens’ and young adults’ self-reported condom use. Arch Pediatr Adolesc Med. 2009;163(1):61–4. 10.1001/archpediatrics.2008.509 19124705
197 DiClemente RJ, Wingood GM, Rose ES, . Efficacy of sexually transmitted disease/human immunodeficiency virus sexual risk-reduction intervention for african american adolescent females seeking sexual health services: a randomized controlled trial. Arch Pediatr Adolesc Med. 2009;163(12):1112–21. 10.1001/archpediatrics.2009.205 19996048
198 Guilamo-Ramos V, Benzekri A, Thimm-Kaiser M, . A Triadic Intervention for Adolescent Sexual Health: A Randomized Clinical Trial. Pediatrics. 2020;145(5). 10.1542/peds.2019-2808
199 DiClemente RJ, Wingood GM, Sales JM, . Efficacy of a telephone-delivered sexually transmitted infection/human immunodeficiency virus prevention maintenance intervention for adolescents: a randomized clinical trial. JAMA Pediatr. 2014;168(10):938–46. 10.1001/jamapediatrics.2014.1436 25155070
200 Crosby RA, Charnigo RJ, Salazar LF, . Enhancing condom use among Black male youths: a randomized controlled trial. Am J Public Health. 2014;104(11):2219–25. 10.2105/AJPH.2014.302131 25211749
201 Kennedy SB, Nolen S, Pan Z, . Effectiveness of a brief condom promotion program in reducing risky sexual behaviours among African American men. J Eval Clin Pract. 2013;19(2):408–13. 10.1111/j.1365-2753.2012.01841.x 22435646
202 Hidalgo MA, Kuhns LM, Hotton AL, . The MyPEEPS randomized controlled trial: a pilot of preliminary efficacy, feasibility, and acceptability of a group-level, HIV risk reduction intervention for young men who have sex with men. Arch Sex Behav. 2015;44(2):475–85. 10.1007/s10508-014-0347-6 25135064
203 Koblin BA, Bonner S, Powell B, . A randomized trial of a behavioral intervention for black MSM: the DiSH study. AIDS. 2012;26(4):483–8. PMID: 22156967.22156967
204 Kurtz SP, Stall RD, Buttram ME, . A randomized trial of a behavioral intervention for high risk substance-using MSM. AIDS & Behavior. 2013;17(9):2914–26. 10.1007/s10461-013-0531-z 23732957
205 Parsons JT, Lelutiu-Weinberger C, Botsko M, . A randomized controlled trial utilizing motivational interviewing to reduce HIV risk and drug use in young gay and bisexual men. J Consult Clin Psychol. 2014;82(1):9–18. 10.1037/a0035311 24364800
206 Mustanski B, Garofalo R, Monahan C, . Feasibility, acceptability, and preliminary efficacy of an online HIV prevention program for diverse young men who have sex with men: the keep it up! intervention. AIDS & Behavior. 2013;17(9):2999–3012. 10.1007/s10461-013-0507-z 23673793
207 Harawa NT, Williams JK, McCuller WJ, . Efficacy of a culturally congruent HIV risk-reduction intervention for behaviorally bisexual black men: results of a randomized trial. AIDS. 2013;27(12):1979–88.24180003
208 Lauby J, Milnamow M, Joseph HA, . Evaluation of Project RISE, an HIV Prevention Intervention for Black Bisexual Men Using an Ecosystems Approach. AIDS & Behavior. 2018;22(1):164–77. 10.1007/s10461-017-1892-5 28871506
209 Operario D, Gamarel KE, Iwamoto M, . Couples-Focused Prevention Program to Reduce HIV Risk Among Transgender Women and Their Primary Male Partners: Feasibility and Promise of the Couples HIV Intervention Program. AIDS & Behavior. 2017;21(8):2452–63. 10.1007/s10461-016-1462-2 27334464
210 Thompson RG, Jr., Elliott JC, Hu MC, . Short-term effects of a brief intervention to reduce alcohol use and sexual risk among homeless young adults: Results from a randomized controlled trial. Addict Res Theory. 2017;25(1):24–31. 10.1080/16066359.2016.1193165 28620272
211 Rhodes SD, Alonzo J, Mann L, . Small-Group Randomized Controlled Trial to Increase Condom Use and HIV Testing Among Hispanic/Latino Gay, Bisexual, and Other Men Who Have Sex With Men. American Journal of Public Health. 2017;107(6):969–76. 10.2105/AJPH.2017.303814 28426301
212 Globerman J, Mitra S, Gogolishvili D, . HIV/STI Prevention Interventions: A Systematic Review and Meta-analysis. Open Med (Wars). 2017;12:450–67. 10.1515/med-2017-0064 29318192
213 Mbuagbaw L, Aves T, Shea B, . Considerations and guidance in designing equity-relevant clinical trials. Int J Equity Health. 2017;16(1):93. 10.1186/s12939-017-0591-1 28583125
214 Harvey SM, Beckman LJ, Gerend MA, . A conceptual model of women’s condom use intentions: Integrating intrapersonal and relationship factors. AIDS Care. 2006;18(7):698–709. 10.1080/13548500500294435 16971278
215 Kraft JM, Harvey SM, Thorburn S, . Intervening with couples: assessing contraceptive outcomes in a randomized pregnancy and HIV/STD risk reduction intervention trial. Womens Health Issues. 2007;17(1):52–60. 10.1016/j.whi.2006.10.006 17321948
216 Harvey SM, Kraft JM, West SG, . Effects of a health behavior change model--based HIV/STI prevention intervention on condom use among heterosexual couples: a randomized trial. Health Educ Behav. 2009;36(5):878–94. 10.1177/1090198108322821 18784350
217 El-Bassel N, Witte SS, Gilbert L, . The efficacy of a relationship-based HIV/STD prevention program for heterosexual couples. Am J Public Health. 2003;93(6):963–9.12773363