# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Kathleen Irwin, MD, MPH, and Tina Fan, MD, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Dr. Jennifer Lin for mentoring and project oversight; and Smyth Lai, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.