# Chapter 4 Discussion

## Summary of Evidence

The literature included in this systematic review provides evidence that among populations with increased risk for STI based on a range of factors, behavioral counseling interventions can be effective (Table 8). Thirty-nine trials, including 17 identified since the previous review, tested the effectiveness of 54 intervention arms for reducing sexual risk behaviors and STI infections. Quantitative pooling of intervention effects on STI prevention indicated that the interventions were associated with reduced odds of incident infections (pooled OR 0.66, 95% CI 0.54, 0.81, I^2^ 74%). Effects were generally consistent; most studies reported lower STI incidence associated with assignment to the intervention condition, and these differences were statistically significant in nine of the studies (Table 9). Statistical heterogeneity was substantial, however, as was clinical heterogeneity. Interventions’ effects on sexual risk behaviors were consistent with STI results among the studies reporting both outcomes. Overall, 34 studies reported behavioral outcomes, but the specific measures varied and were not consistently reported. The most commonly reported outcomes were condom use (18 trials, n=9,205) and unprotected intercourse (21 trials, n=13,665). The reported numbers of sexual partners and sexual abstinence were also reported in ten trials, including four aimed at delaying or reducing sexual activity among adolescents.^125,^ ^127,^ ^144,^ ^164^

Table 8 Summary of Evidence for Behavioral Counseling Interventions to Prevent Sexually Transmitted Infections

Key Question | No. of Studies (No. of observations) Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ1. Effectiveness of Behavioral Counseling Interventions for Reducing STI; a. By study subpopulations; b. By intervention characteristics | k = 21 studies (n= 59,328) [12 newly identified since previous review] | Behavioral interventions delivered to individuals at increased risk for STI were effective in pooled analysis (pooled OR 0.66, 95% CI 0.54, 0.81, I^2^ 74%; k = 19, n = 52,072).; Substantial statistical heterogeneity could not be attributed to specific factors since the most effective interventions generally shared similar characteristics. Larger preventive effects tended to be observed for interventions that included group counseling sessions, involved high contact times (>120 minutes), and focused on adolescent girls at increased risk for STI. | Reasonably consistent; Reasonably precise | Seven trials were assessed good quality with low risk of bias and the remainder were deemed fair quality due to modest risk of bias associated mainly with modest loss to followup and incomplete outcome ascertainment.; Statistical heterogeneity could not be readily explained by any independent factor as there was considerable overlap in the features of effective interventions (e.g., group counseling, higher contact times, age group, sex/gender of participants) | Moderate for benefit | Most trials were conducted in the US among populations at increased risk for STI. Increased risk populations were defined by STI clinic attendance or history (highest risk), sexual risk behaviors, or demographic characteristics.; Most studies focused on specific subpopulations defined by race/ethnicity, sexual orientation, age, gender, pregnancy, or other factors.; More than half of the studies were limited to girls or women (k=11). Two studies were limited to men.
KQ2. Effectiveness of Behavioral Counseling Interventions for Reducing Sexual Risk Behaviors; a. By study subpopulations; b. By intervention characteristics | k = 34 (n= 21,417) | Among 18 studies reporting a variety of condom use measures and 21 studies reporting unprotected intercourse, there was evidence of intervention effectiveness.; Intervention was associated with increased odds of reported condom use for dichotomous measures (pooled OR 1.31, 95% CI 1.10 to 1.56, I^2^ 40%; k = 13, n = 5,253) and a decrease in reported unprotected intercourse measured as counts (pooled MD −0.94, 95%CI −1.40 to −0.48, I^2^ 16%; k = 14, n = 9,183).; Studies reporting STI and behavioral outcomes were internally consistent suggesting reductions in sexual risk behaviors contributed to lower STI incidence.; One study of adolescents (mostly not yet sexually active) found reduced reports of vaginal sex associated with the intervention. | Reasonably consistent; Imprecise due to variability in reported measures and effect sizes across measures | Measures of behavioral outcomes were heterogeneous and inconsistently reported, limiting the ability to quantitatively summarize intervention effects on sexual risk behaviors.; Self-reported behavioral outcomes are subject to respondent recall and social desirability bias which can lead to overestimation of intervention effects. | Low for benefit | Most trials were conducted in the US among populations at increased risk for STI. Increased risk populations were defined by STI clinic attendance or history (highest risk), sexual risk behaviors, or demographic characteristics.; Most studies focused on specific subpopulations defined by race/ethnicity, sexual orientation, age, gender, pregnancy, or other factors.
KQ3. Harms of Behavioral Counseling Interventions | k = 7 (n = 3,458) | No evidence of harms in the few studies reporting adverse events or possible harms related to unintended pregnancy risk or mental health. One study reported car crashes associated with text messages to evaluate this potential adverse effect of the intervention, but numbers were too small for inference. | Imprecise; Consistency NA | Very limited reporting of potential adverse effects of behavioral counseling intervention to prevent STI. | Insufficient | Most trials were conducted in the US among populations at increased risk for STI. Increased risk populations were defined by STI clinic attendance or history (highest risk), sexual risk behaviors, or demographic characteristics.; Most studies focused on specific subpopulations defined by race/ethnicity, sexual orientation, age, gender, pregnancy, or other factors.

Abbreviations: CI = confidence interval; K = number of studies; KQ = key question; MD = mean difference; N = number of participants; NA = not applicable; No. = number; OR = odds ratio; STI = sexually transmitted infection; US = United States.

Table 9 Overall Direction of Intervention Effects on Health and Behavioral Outcomes, by Author^*^

| | | | Direction of Intervention Effects
Author, Year | Participant Age Groups^†^ | Participant Gender/Sex | Intervention contact time^‡^ | KQ1 | KQ2: Behavioral Outcomes^§ǁ^
Author, Year | Participant Age Groups^†^ | Participant Gender/Sex | Intervention contact time^‡^ | STI incidence | Condom use^¶^ | Unprotected intercourse | Number of sexual partners
Bai, 2018^160^ | Adol | F-M | High | | | ↔
Bailey, 2016^105^ | Adult | M | Low | ↑
Berenson, 2012^107^ | Adol-YA | F | High | ↑ | ↔
Berkman, 2007^108^ | Adult | M | High | | ↑
Billings, 2015^110^ | Adult | F | Moderate | | ↑↑ | ↑^#^
Carey, 2004^111^ | Adult | F-M | High | | | ↑↑ | ↑↑
Carey, 2010^112^ | Adult | F-M | High | ↔^**^ | | ↓ | ↔
Carey, 2015^113^ | Adult | F-M | Moderate | ↓ | | ↔ | ↔
Champion, 2012^116^ | Adol | F | High | ↑↑
Costa, 2017^117^ | Adol-YA | F | High | | ↑↑^**^
Crosby, 2009^118^ | YA | M | Moderate | ↑↑ | ↑↑ | ↑ | ↑↑
DiClemente, 2004^119^ | Adol | F | High | ↑↑ | ↑↑ | ↑↑
Ehrhardt, 2002^102^ | YA | F | High | | ↔^††^ | ↑^**^
Free, 2016^122^ | Adol-YA | F-M | Moderate | ↑ | ↑ | | ↔
Guilamo-Ramos, 2011^125^ | Adol | F-M | Moderate | | | | ↑↑^‡‡^
Jemmott, 2005^127^ | Adol | F | High | ↑↑ | | ↑↑ | ↑↑
Jemmott, 2007^128^ | Adult | F | High | ↑↑ | ↑↑ | ↑
Kershaw, 2009^129^ | Adol-YA | F | High | ↑ | ↑↑ | ↑↑
Lewis, 2018^132^ | YA | F-M | Low | | ↓
Marrazzo, 2011^135^ | Adult | F | Moderate | ↔
Metsch, 2013^137^ | YA | F-M | Moderate | ↔ | | ↔
Mittal, 2017^142^ | Adult | F | High | | | ↑^**^
Morrison-Beedy, 2013^144^ | Adol | F | High | | ↔ | ↔ | ↑
Neumann, 2011^145^ | Adult | F-M | Moderate | ↑↑
O’Cleirigh, 2019^162^ | Adult | M | High | | | ↑↑
Peipert, 2008^148^ | Adol-YA | F | Moderate | ↔ | ↔
Peragallo Montano, 2019^161^ | Adult | F | High | | ↔
Petersen, 2007^149^ | Adult | F | Moderate | ↔^**^ | ↔^**^
Proude, 2004^150^ | YA | F-M | Low | | ↔
Redding, 2014^163^ | Adol | F | High | | ↑↑
Sanci, 2015^153^,^§§^ | Adol-YA | F-M | High
Scholes, 2003^154^ | YA | F | Low | | ↔
Shafii, 2019^164^ | Adol-YA | F-M | Low | ↑ | | ↑ | ↔
Shain, 2004^155^ | Adol-YA | F | High | ↑↑ | | ↑↑ | ↑↑
Tzilos Wernette, 2018^165^ | Adult | F | Moderate | ↔ | | ↔
Warner, 2008^156^ | Adult | F-M | Low | ↑↑
Whiteley, 2018^166^ | Adol-YA | F-M | Low | | | ↑↑
Wingood, 2013^158^ | YA | F | High | ↑↑ | | | ↑↑
Ybarra, 2017^159^ | Adol | M | High^ǁǁ^ | | | ↔

Symbol Legend:

- ↑↑ = Statistically significant between-group difference in favor of intervention group
- ↑ = Between-group difference in favor of intervention group (OR, RR, or Hedges’ g > 0.15 or 1.15 of null); difference not statistically significant
- ↔ = No clear between-group difference (OR, RR, or Hedges’ g within 0.15 of null).
- ↓ = Between-group difference in favor of control group (OR, RR or Hedges’ g > 0.15 or 1.15 of null); difference not statistically significant
- ↓↓= Statistically significant between-group difference in favor of control group

* All studies were randomized control trials, except: Sanci, 2015 = cluster randomized controlled trial; Neumann, 2011 = nonrandomized controlled clinical trial; Warner, 2008 = nonrandomized controlled clinical trial

† Age groups: Adol: Study participants ranged in age from 12 to 19 years; Adol-YA: Study participants ranged in age from 12 to 25 or study included adolescents and adults with population mean age < 25 years; YA: Study participants ranged in age from 18 to 25 only or study enrolled adults of all ages with population mean age <25 years; Adults: Study participants ages 18 and older or enrolled broad age range population with mean age ≥25 years

‡ Intervention contact time: Low: <30 min; Moderate contact: ≥30 to ≤120 min; High contact: >120 min

§ For majority of outcomes. See Appendix E, Table 3, Table 4, Table 5, Table 6, Table 7, Table 8 for all detailed outcome results.

ǁ Self-reported

¶ Condom use = Condom-protected sexual intercourse or condom-protected sexual acts

# Based on study reported p-value

** Not included in meta-analysis

†† First time female condom use, all other outcomes are male condom use

‡‡ Any vaginal intercourse

§§ Study outcome was STI risk measured as self-report of frequency of “safe sex practices”; there was not a statistically significant difference between groups at 12-month followup but the effect estimate favored the intervention group (↑)

ǁǁ Based on assumed 15 minutes per text so this likely is an upper estimate, but with assumptions of shorter text message contact, the intervention involved over 2.5 hours of texting contact and was therefore considered a high-contact time intervention

Abbreviations: Adol = adolescent; F = female; KQ = key question; M = male; OR = odds ratio; RR = relative risk; STI = sexually transmitted infection; YA = young adult.

For STI prevention, the largest effect sizes were observed for intensive group counseling interventions for adolescent girls identifying as African American and Mexican American,^116,^ ^119,^ ^127^ and analysis of intervention characteristics across the body of evidence supports the benefit of group counseling interventions, which was also sometimes paired with individual counseling. Looking at the evidence across studies not limited to adolescents suggests a more modest, but statistically significantly lower odds of STI (Table 5). Overall, the included study populations reporting KQ1 outcomes were mostly at increased risk for STI, including some at highest risk based on STI clinic visits or history, and skewed toward participants who were young and female and represented racial or ethnic minorities. In addition, most were focused on reducing STI from heterosexual contact, with a few exceptions.

The findings of this review are consistent with the conclusions from our previous review for the USPSTF, despite the addition of 17 new studies evaluating the evidence of effectiveness for behavioral counseling to prevent STIs. The effect size found for STI incidence in this review (pooled OR = 0.66, 95% CI 0.54, 0.81) is similar both to the findings of the previous review conducted for the USPSTF and other more recent reviews of sexual risk reduction counseling. The previous USPSTF review reported pooled ORs ranging from 0.38 (95% CI 0.24 to 0.60) for five trials of adolescents for interventions with more than 2 hours of estimated contact to 0.85 (95% CI 0.66 to 1.10) for six trials of interventions for adults with between 30 minutes and 2 hours of estimate contact.^96^ Other reviews covering a wide range of settings have reported effects on STI incidence in a comparable range, such as a pooled RR of 0.70 (95% CI NR) for interventions that involved skill-building or communication and negotiation skills in a broad-based review of 289 interventions to reduce STI and sexual risk behavior in adolescents^186^ and a pooled RR of 0.59 (95% CI 0.46 to 0.75) in a review of 43 interventions targeting ethnic minority and economically disadvantaged women.^187^ One review found a slightly smaller pooled effect when looking only at brief interventions (up to 60 minutes) in trials limited to males, with a pooled OR of 0.82 (95% CI 0.67 to 0.99).^188^

Of the 17 additional studies contributing evidence to this update, only five reported STI outcomes ^105,^ ^113,^ ^122,^ ^164,^ ^165^ and twelve reported only behavioral outcomes. Among the five new studies reporting STI outcomes, none were statistically significant but three recruiting from STI clinics had similar effect sizes in the direction of a preventive benefit;^105,^ ^122,^ ^164^ two of these were low-to-moderate contact time interventions using tailored computer-based^164^ or text-messages^122^ delivered to male and female adolescent and young adult populations and the other was a small trial in Great Britain that evaluated a 10-minute website visit intervention for adult men (Men’s Safer Sex).^105^ Behavioral change outcomes reported for these trials were consistent with the effects for STI. Among the most effective previously included trials, statistically significant effects^116,^ ^118,^ ^119,^ ^127,^ ^128,^ ^145,^ ^155,^ ^156,^ ^158^ were reported for several. Most of these were high contact time interventions focused on somewhat narrowly defined populations at risk for STI, mainly delivering group counseling sessions to adolescent or young adult girls and women.

Five of the twelve added trials reporting behavioral outcomes reported statistically significant main effects for behavioral changes^110,^ ^117,^ ^162,^ ^163,^ ^166^ and the remainder had null findings with small differences between groups and mixed directions of the intervention effects. Among the statistically significant effective interventions added to the body of evidence, one reported increases in condom use and lower counts of unprotected sex with a moderate contact time, web-based intervention for African American women (Safe Sistah).^110^ Another email-based intervention that sent links to internet content was associated with reduced unprotected intercourse among participating adolescents and young adults.^166^ These lower contact time interventions involving computer-based intervention that were effective for self-reported improvements in behavioral outcomes warrant further study to evaluate their effectiveness for STI prevention. Higher contact time intervention were also effective in three trials; one providing ten individual counseling sessions was effective for reducing reports of unprotected anal intercourse for MSM with a history of childhood sexual abuse,^162^ another pairing computer sessions with ongoing individual counseling was effective for increasing reported condom use among disadvantaged adolescent girls,^163^ and another conducted in Portugal increased condom use among adolescent girls and young women,^117^ highlighting the need for further research to identify the approaches and modalities that are effecting changes to prevent STI for different populations.

## Intervention Approaches for Sexual Risk Reduction

The evidence included a diversity of literature in terms of included intervention components, modes of delivery, and settings represented (Appendix E Table 10 and Appendix F Table 1). The interventions evaluated tended to be designed for and targeted to specific subpopulations defined by age, gender, STI risk behaviors, and STI history. Overall, the included studies were more heavily composed of participants who were young (two-thirds of studies focused on adolescent and young adult populations) and female (more than half of studies enrolled only women) and included high percentages of racial/ethnic minorities. Just as the study populations varied, the interventions tested were highly variable in terms of the amount of contact time with participants, the number of contacts, the duration of the intervention, the guiding theories and therapeutic approaches, and providers or modalities for intervention delivery. Given that the statistical and clinical heterogeneity of the included evidence was substantial, our ability to identify specific study or intervention characteristics associated with differences in intervention effects was limited. Nevertheless, a few broad conclusions can be drawn based on the body of evidence we reviewed.

Overall, we found that interventions among individuals at increased risk for STIs tended to have large preventive effects if they involved more contact time, included group counseling sessions, and were conducted in more narrowly focused populations with respect to age, gender, and race/ethnicity. Other reviews have proposed moderators of effect size, including matching the gender or ethnicity of the facilitator to the intervention recipients,^77,^ ^189^ targeting or tailoring and intervention to a particular ethnic or sociodemographic group^77,^ ^189^ having theory-based interventions,^189,^ ^190^ and providing skills training, such as regarding the use of condoms or strengthening interpersonal relations.^77,^ ^186,^ ^189,^ ^190^ One of these reviews explored the efficacy of brief (1 or 2 sessions and no more than 60 minutes of contact), individual, face-to-face STI prevention interventions that took place in clinical settings in the United States, and found that many were effective and that the study populations primarily included high-risk heterosexuals, most of whom had STIs at the time of or prior to their participation in the studies.^77,^ ^191^ Our review had similar findings despite the different scope and included many of the same trials.

Individuals were identified for the interventions as being at increased risk for STIs based on medical history (e.g., current or recent STI) or health care site (e.g., STI clinic), reported sexual risk behaviors such as unprotected sexual intercourse with multiple partners, or demographic characteristics associated with higher STI prevalence. There is evidence that behavioral interventions can be effective in reducing incident STIs in the populations included in the trials identified for inclusion in this review. In general, larger intervention effect estimates were observed in trials focused on a single-gender population (often for specific subpopulations defined by race/ethnicity) and involving group counseling and higher contact times. There were exceptions, however: Less intensive interventions targeting more broadly defined populations were also effective,^145,^ ^156^ and given the diversity of study populations and intervention approaches, general conclusions about the necessary components of interventions were not drawn. In general, interventions among individuals at high risk for an STI that involved more contact time, included group counseling sessions, and were conducted in more narrowly focused populations with respect to age, gender, and race/ethnicity tended to have larger preventive effects. For example, the HORIZONS and Project SAFE and interventions were effective for minority adolescent girls and young women, and these were designed with specific demographic populations in mind; adolescent African American girls and African American and Mexican American girls and women, respectively.

Fourteen of the included trials evaluated interventions delivered to populations of men and women, rather than on a single gender. Of these, seven reported an STI outcome^112,^ ^113,^ ^122,^ ^137,^ ^145,^ ^156,^ ^164^ and seven reported only behavioral outcomes.^111,^ ^125,^ ^132,^ ^150,^ ^153,^ ^160,^ ^166^ Four of these trials reported statistically significant effects. Two conducted among individuals presenting for care at STI clinics^145,^ ^156^ reported lower STI incidence. The other two trials (one among adult psychiatric outpatients^111^ and one among adolescents and young adults^166^) reported reductions in unprotected intercourse and number of sexual partners.^111^ In the STI clinic studies, the VOICES/VOCES counseling intervention,^145^ and Safe in the City, the provision of condoms and a short video intervention^156^ were both effective, but there may have been gender differences in effectiveness based on exploratory analyses, with women possibly obtaining more benefit in VOICES/VOCES and men more than women from the Safe in the City intervention. The more modest effects of these mixed-gender studies and the stratified gender analyses support the overall conclusion that sexual risk reduction counseling interventions are likely more effective when they are attentive to ways that the relational, social, and sexual context may differ for men and women.

Only eleven of 54 intervention arms (8 studies) evaluated low contact interventions (<30 minutes), and only two reported statistically significant effects. Statistically significant findings of reduced STI were reported for the nonrandomized trial of Safe in the City^156^ and reduced unprotected vaginal and anal sex associated with an intervention consisting of emails with links to internet content.^166^ There was evidence that interventions involving more than 2 hours of contact time, often taking place over weeks or months, and interventions involving group counseling were more effective than low and moderate contact time interventions. These higher contact time interventions tended to focus on specific populations defined by personal characteristics such as sex/gender, race/ethnicity, sexual orientation, and age. Several of the low and moderate contact time interventions were extended to broader populations of men and women visiting STI clinics. These included the Safe in the City intervention,^156^ the VOICES/VOCES intervention,^145^ a text messaging intervention in Great Britain,^122^ and the e-KISS computer-based intervention.^164^ As noted, the confounding of intervention characteristics and study populations limited our ability to draw strong conclusions about specific behaviorally intervention features associated with preventive benefit from the body of literature we reviewed to evaluate efficacy.

### Behavior Change Theories and Strategies

A broad body of literature suggests that interventions based on a theoretical model are more effective than those that lack one.^189^ The most widely used theoretical models of health behavior are the Health Belief Model, the Transtheoretical Model, and Social Cognitive Theory. Additional theoretical or interventional approaches used specifically in the STI prevention literature include^176–178^ the Information-Motivational-Behavioral Skills Model,^179,^ ^180^ the Theory of Gender and Power,^184^ and the AIDs Risk Reduction Model.^185^ Many of these theories share overlapping concepts that are a focus of intervention, such as attitudinal beliefs about positive and negative aspects of behavior, self-efficacy, normative beliefs, risk-related beliefs, and intentions.^192^ We did not identify any specific approaches or theories that independently accounted for differences in effect sizes. As noted above, however, other reviews designed to investigate the theories informing interventions have found evidence that theory-based interventions are more effective for sexual behavioral change and STI prevention.^77,^ ^189–191^

Several studies relied on specific therapeutic counseling approaches, such as cognitive behavioral therapy,^178^ family therapy, and motivational interviewing^176,^ ^177^ Cognitive behavioral therapy (CBT) is a problem-focused therapy approach designed to address maladaptive thoughts (cognitions) and behaviors. CBT was originally developed to help patients manage psychological distress such as depression and anxiety. However, CBT strategies have also been applied more broadly for promoting healthy behavior and self-care.^178^ Common therapeutic strategies include cognitive restructuring (identifying and modifying maladaptive thoughts), behavioral activation (activity monitoring and scheduling), and problem-solving. Given that many of the extended high-contact-time counseling interventions used CBT, we cannot quantify the importance of this aspect of the interventions. There is extensive literature, however, supporting the effectiveness of CBT for improving a wide range of health and mental health conditions.^178^ Motivational interviewing is a behavior change technique that is used to increase motivation and commitment to change, help patients identify the problematic behaviors that the individual is most willing and able to change, help patients feel a sense of agency for promoting their own health.^176,^ ^177^ This technique was used in seven trials, including the group and individual counseling intervention for adolescent girls evaluated by Champion and colleagues (2012), which had the largest effect size for STI prevention reported among the included studies.

## Applicability of the Evidence to U.S.-Based Primary Care

Most of the included studies were conducted in the United States, and four studies were conducted in somewhat comparable international settings (Great Britain, Portugal, Australia). Nearly all of the interventions took place in clinical settings, with STI clinics most heavily represented, along with clinics delivering family planning and women’s health services. Very few trials were conducted in general primary care settings. A group counseling intervention conducted in a primary care setting and led by health educators was effective in preventing STI among young adult Black women in a trial by Wingood and colleagues.^158^ Three other interventions conducted in general primary care settings found no difference in reported behavioral outcomes between study groups.^148,^ ^150,^ ^153^ One was a brief intervention provided by physicians and aimed at young adult men and women,^150^ another evaluated in Australia taught primary care clinicians motivational interviewing techniques for use in engaging with their adolescent and young adult patients,^153^ and the third offered individual counseling with health educators during primary care visits to girls and women at risk for unintended pregnancy,^148^ and focused primarily on increasing effective contraceptive use.

The high contact, group counseling interventions that were found effective in this review tended to be tailored to specific subpopulations at increased risk for STI. Similar patients to those enrolled in these interventions can be identified in routine care (e.g., presenting for STI testing). The ongoing, facilitated, group counseling that appears to be most effective will require extra resources to implement in primary care settings that do not have established behavioral health programs. In particular, maintenance of inclusive, effective programs for diverse patient populations may be most important in health systems and settings serving the most low-resourced and vulnerable populations. Usual care comparators may differ depending on the site of care. For example, interventions conducted at STI clinics may provide condoms to all visitors and engage in partner treatment services and counseling with people in the control condition as the standard of care. Group differences between study arms may therefore not reflect what would be seen if interventions were implemented in general primary care settings where usual care would not necessarily offer this standard of care. Furthermore, attendees at STI clinics may be more motivated to change behaviors following an STI diagnosis or an exposure that led them to seek care in a specialized setting. We did not find evidence that intervention effects differed according to the recruitment setting, possibly because of attenuated effects from to enhanced control conditions were offset by higher motivation of study participants. There is a need for evidence from replication studies of effective interventions evaluated in STI clinics. This would help to ascertain their transferability to primary care settings that see patients at increased and even highest risk for infection but are not solely focused on this health concern.

Other important primary care settings for women and men at risk of STIs and unintended pregnancy were represented in this body of evidence. In addition to STI clinics, much of the evidence on intervention effectiveness comes from studies in focused reproductive health provision centers, such as family planning clinics and women’s health centers. One included trial was implemented in a pediatric health care setting and was found to be effective for delaying self-reported initiation of sexual intercourse. The Families Talking Together intervention enrolled mother-child dyads and was designed for African-American and Hispanic youth before they became sexually active.^125^ Few studies in the review attempted to identify and recruit individuals at increased STI risk from large health care systems. Instead, the studies selected settings based on the presence of specific increased risk or vulnerable populations. It remains to be seen whether the intensive interventions, often involving multiple group counseling encounters and focused on specific populations at risk, can be made available and will be effective in other clinical settings or among more with heterogeneous populations.

The review was limited to interventions evaluated over the past 20 years, and over one-third were published more than a decade ago. Population changes in sexual risk behaviors and risks over this time period may have implications for the applicability of evidence. Specifically, the development of effective treatments and a prophylactic agent for HIV infection may have shifted population risk perceptions. In addition, the emergence of social networking and dating app platforms has altered the landscape that defines sexual networks and sexual practices.^193^ Research is needed to better understand risk factors and to develop interventions that can attend to current sexual, social and interpersonal contexts that adolescents and young adults most at risk for STIs must navigate.

Because we limited our review to this time frame, interventions that were evaluated for efficacy prior to 2000 were not included. Notably, a large multicenter trial of Project RESPECT that was included in the previous USPSTF review, published in 1998 by Kamb and colleagues,^173^ was not included in the current review. This large trial of heterosexual men and women (including some adolescents) making STI clinic visits evaluated high- and moderate-duration individual counseling interventions. The counseling interventions evaluated were effective compared with STI clinic standard-of-care didactic messages. The study results were consistent with the overall results of the current review. For individuals making visits to STI clinics, there are evidence-based interventions to prevent future STIs.

The emergence of new pathogens (e.g., treatment-resistant gonorrhea) and reemergence of old ones (e.g., syphilis) necessitates ongoing efforts to strengthen public health initiatives to prevent STIs. Preventive strategies for individuals are similar for sexually transmitted infections, although the risk of transmission of different pathogens is affected by sexual activities and the amount of exposure. In addition to the individual protective behaviors that can be addressed with behavioral interventions, public policy and medical practices also have important bearing on the prevalence of disease and risk of exposure. Access to health care, to adequate sexual history-taking and STI screening, and to effective treatments and followup are critical for reducing the scope of the STI epidemic in the United States.^194^ While interventions targeting individual sexual behaviors are important, the unequal risks of STI borne by vulnerable subpopulations are in part owing to social inequality in the distribution of health and community resources.

## Limitations of the Literature

The diverse behavioral outcome measures and reporting inconsistency among the studies was the main shortcoming of the included literature. The inconsistency in measures of condom use reported across the body of evidence meant that we combined outcomes that have qualitatively different effects on STI prevention; specifically, STI prevention requires consistent condom use, but many studies reported condom use at last sex or any condom use. Further, behavioral outcomes were self-reported and subject to recall bias, Hawthorne effects, and social desirability bias. For the very intensive interventions that tended to be more effective, participants who invested substantial time and developed relationships with the study staff may have felt more acute pressure to conform to socially desirable sexual behaviors. There is evidence that social desirability effects can bias trial results.^195^ It was reassuring, nevertheless, that in studies reporting the incidence of diagnosed STI, results for behavioral measures were generally consistent in the degree and direction of effects with the findings for reported STI outcomes; higher levels of condom use or lower levels of unprotected intercourse occurred alongside reduced STI acquisition. This is reassuring with respect to the validity of self-reported behavioral measures available in the included literature. Other observational studies also have shown that self-reported sexual behaviors are often associated with reductions in STI risk,^186^ but that self-report of condom use is not always valid.^196^ A study by Rose and colleagues (2015)^196^ among African American teens and young adults sought to validate condom use self-reports. Considerable discordance between participants’ reports and actual condom use validated with testing for sperm in vaginal fluid was observed. The authors suggested that either incorrect use or social desirability bias could account for the result.

The number of studies, their heterogeneity, and correlations in study characteristics limited our ability to draw conclusions about the differential effects of interventions across important subpopulations. For the most part, the included literature evaluated intervention effectiveness within narrowly defined population groups, and it is uncertain whether the reported effect estimates would also be observed for these interventions if adapted to other populations. Overall, the studies tended to conduct stratified analyses comparing subpopulations, and did not often specify a priori primary and secondary outcomes or correct for multiple comparisons, which could increase the occurrence of statistical differences attributable to chance. Examination of intervention effectiveness for important subpopulation was also limited by scant included evidence; there were only two studies conducted among pregnant individuals. No studies focused on certain populations known to be at increased risk for STI, such as young heterosexual men with a history of unprotected sex and transgender individuals.

Relatively few of the included studies presented replications or adaptations of effective interventions.^145^ Once effectiveness has been established, replication often is conducted using comparative effectiveness study designs to ensure vulnerable patients at high STI risk receive the effective intervention. For example, the DiClemente trial (2004)^119^ included in this review and tested among adolescent African American girls, HORIZONS, has been further developed and evaluated, with additional evidence supporting its effectiveness relative to enhanced sexual health services.^197^ These types of studies were not included in this review however, because of our focus on efficacy studies without an active comparator. A trial replicating the Families Talking Together intervention^125^ for African-American and Hispanic youth being seen in pediatric care settings was identified during ongoing literature surveillance (published May 2020). The trial tested the intervention among a larger sample of Hispanic, African-American, and mixed race youth, providing additional evidence that the intervention was effective for reducing self-reported behavioral risk factors for STI (i.e., delayed sexual debut, increased condom use).^198^ Overall, however, there were few replication studies for the interventions summarized in this review, raising questions as to whether the evaluated interventions are likely to be effective when transferred to different times, places, or populations.

A majority of studies provided 12 or more months of followup, and several of these reported differences at 6 months that were no longer observed at one year. Among the studies reporting shorter followup times, it is possible that effects would have diminished if longer followup had occurred. For this reason, the sustainability of effects remains uncertain. Few of the studies evaluated the extent to which intervention effects last beyond the followup time periods reported. Establishing new sexual habits and skills may have lasting effects or may require reinforcement to have continued health benefits. The study by Shain and colleagues (2004)^155^ provided STI incidence data for 2 years of followup and found persistent reductions for standard and enhanced intervention arms. The study was a replication of the Project SAFE intervention that was found effective in an earlier trial for adolescent Mexican American and African American girls.^174^ The recent test of the intervention adaptation was designed to include eligible participants ages 15 to 45 years old but enrolled mostly adolescents and young adults. Interventions to bolster and extend intervention effects can be effective. A comparative effectiveness trial of a maintenance intervention involving ongoing telephone reinforcement found benefits for African American adolescents receiving the HORIZONS intervention.^197^ Improvements in ongoing effectiveness were observed with a telephone followup component added.^199^ The HORIZONS intervention is an adaptation of the group counseling intervention for adolescent African American girls included in this review and found to be effective for STI prevention and improving protective sexual practices.^119^

## Limitations of Our Approach

This review was conducted in accordance with USPSTF Procedures, and decisions about topic scope were made in advance of the review to include studies that would inform evidence-based clinical recommendations. The review was therefore limited to studies of effectiveness and did not evaluate studies designed to assess comparative effectiveness of different types of behavioral counseling interventions. Several studies that were excluded for this reason focused on high-risk populations that were not well-represented in the included body of evidence, such as African American boys and men,^200,^ ^201^ MSM,^202–206^ bisexual Black men,^207,^ ^208^ transgender women,^209^ and homeless young adults.^210^ Given the high STI risk, stigma, and vulnerability among some study populations, investigators may be hesitant to conduct randomized trials without an active STI prevention control condition. Further research aimed at demonstrating the effectiveness of these interventions, however, may be possible using study designs that ensure all identified participants eventually receive the active intervention (stepped wedge, waitlist, attention control addressing other health risks) conditions would be valuable for informing future USPSTF recommendations.

The scope of this review was defined to identify evidence for interventions that can be feasibly implemented in or referred from U.S.-based primary care health care settings. This excluded much of the rich evidence on STI prevention that has been generated in the United States and globally. Because our review was limited to settings applicable to primary care, we did not review evidence on interventions evaluated in among people affiliated through social groups or institutions (e.g., schools, churches, worksites). For example, an effective intervention with Latino MSM that recruited individuals from social settings such as bars or dance clubs and involving recruitment of friends, was not included.^211^ Importantly, this review does not provide a comprehensive examination of all effective interventions for STI prevention. Other resources and evidence-reviews, such as those provided through the Community Guide and the Community Preventive Services Task Force consider preventive interventions occurring in a broader range of community settings. The absence of studies included in this review for some at-risk populations does not mean other effective STI prevention programs are not available, but they are designed for application outside of primary health care.

We did not include studies limited to or primarily for HIV-positive patients, but evidence suggests that counseling approaches may help reduce high-risk behaviors. For example, a recent systematic review of STI prevention interventions targeting individuals living with HIV found a similarly modest intervention effect for behavioral counseling interventions to reduce sexual risk behaviors in HIV-positive populations (SMD −0.35, 95% CI −0.49, −0.20, k=14).^212^

## Future Research Needs

We identified only 17 eligible new trials of behavioral interventions without an active comparator that are feasible for primary care published since the previous review. There is a gap in the literature for behavioral interventions in primary care settings, where clinicians must address a range of health concerns and levels of STI risk. The existing evidence on behavioral counseling is, quite understandably, focused on prevention for patients most at risk for STIs, and trials have mostly been conducted in enriched populations with high baseline rates of STIs. There remains a need for research to develop and test lower-intensity behavioral interventions that might be applied in primary care settings serving patients with a range of levels of STI risk. For example, studies in large health systems could provide important evidence on intervening in the context of routine primary care, for example when patients screen positive for an STI or report sexual risk behaviors such as multiple concurrent partners and unprotected intercourse. Pragmatic trials might also be designed to strengthen the evidence base with respect to subpopulation effects. While there are several studies targeting specific groups in this review, and several presented exploratory stratified analyses, none was designed and powered to test interactions to ascertain what types of interventions are most effective for whom. Larger studies including heterogeneous populations, powered to test differences in effectiveness for different subpopulations could further inform clinical practice. The assignment of patients in primary care to interventions most effective for specific sociodemographic groups and personal STI risk factors may necessitate readily tailored interventions or a menu of interventions for clinicians to prescribe.^213^

Few studies tested web-enabled or interactive telemedicine modalities that could be used to extend the group counseling format found effective in this review to more remote or otherwise isolated settings. Interventions that included an ongoing group counseling format were associated with the largest effect sizes in this review, and research is needed to make this type of intensive contact intervention more widely available. Newer intervention modalities might be used to complement or boost in-person counseling and show promise for reaching broader patient populations.

Our review identified only one intervention focusing on dyads rather than individuals, in this case an intervention with mothers to reduce the risk for STI in their adolescent children.^125^ None of the included studies were conducted with sexual partnership dyads. For women, the primary means of STI prevention, condom use, requires negotiation and joint decision-making with a male partner. Condom use may depend on intrapersonal and relationship factors.^214^ These can be intervened upon in interventions with women only, as shown in the studies included in this review. Nevertheless, the absence of trials evaluating interventions with sexual partners suggests an area for future research. A comparative effectiveness trial conducted with young adult Latina women and their male partners found improvements in condom use over time for both study groups, suggesting possible benefits of couple interventions.^215,^ ^216^ However, there is evidence from another trial that included an arm delivering an intervention to women only versus to couples, and the effect was no different between these two groups.^217^

Clinician risk assessment is a necessary step for identifying patients who would be eligible for behavioral counseling interventions intended for patients at increased risk of STI, yet few of the included studies incorporated risk assessment by primary care providers into the study design. Tests of interventions among populations of patients identified using clearly defined sexual health risk assessment procedures could strengthen the applicability of evidence to primary care populations. Given that there may be considerable variation in sexual history-taking practices in primary care, the implementation of behavioral counseling interventions for increased risk populations will likely require greater attention to this aspect of provider training and health care delivery. Overall, there is a need for further research on how best to implement behavioral counseling interventions into the course of routine primary care. Pragmatic trials might include clinical identification of eligible patients using standardized approaches, and test different approaches for connecting patients to appropriate and effective interventions.

There are notable gaps in the included evidence. Two studies in this review were conducted among pregnant women, despite the clinical importance of preventing vertical transmission of STI and complications that can be associated with STI during delivery. Most studies primarily included heterosexual participants, and only two studies tested interventions for STI prevention among gay or bisexual populations. Despite considerable diversity within and across the body of evidence, several groups that also can experience increased risk for STIs where underrepresented, including older adults, gay boys and men, gender minority and transgender populations. This may reflect gaps in the evidence or the limitations related to our review scope discussed above, but the shortage of efficacy research on behavioral interventions for these populations is of concern given the public health imperative to prevent STI and the need for evidence-based resources for intervention.

## Conclusions

Our systematic review, which covered nearly two decades of published trials on behavioral counseling interventions that are primary-care feasible or referable, reiterated the findings of previous reviews. There are effective behavioral counseling interventions to prevent STIs by helping individuals increase condom use and reduce sexual risk behaviors. The diversity in study populations, interventions, and reported outcomes included in this evidence does not permit conclusions about the most effective or necessary components of interventions. For some populations at increased STI risk, there are focused interventions that have demonstrated benefit for the intended recipients. Intensive group-counseling interventions and individual counseling interventions were effective in some trials, particularly with young women at increased STI risk based on socioeconomic or racial/ethnic characteristic. There were, however, also trials showing modest intervention benefits for less intensive approaches, especially when tested among individuals presenting to STI clinics or with recent history of STI. The therapeutic approaches and theoretical underpinnings of effective interventions varied but generally included educational, skill development, motivational, and supportive elements. No intervention harms or unintended consequences were identified, although few studies reported potential adverse consequences. This review was designed to support the USPSTF recommendation for preventive clinical services and did not include behavioral counseling interventions that could not be provided in or referred from primary care. Thus, community-level interventions, school-based interventions, and other types of interventions taking place within established social networks were not included. Nevertheless, for some populations at increased risk for STI, there is clear evidence that behavioral counseling provided in the context of primary health care settings can improve sexual health.