# Chapter 3 Results

## Literature Search

We screened 4,649 abstracts and assessed 273 full-text articles for inclusion (Appendix A Figure 1). After screening the full-text articles, we included 39 studies (in 63 articles) in our systematic review.^102,^ ^105–159^ The full list of included studies and their ancillary articles are available in Appendix C. The list of excluded studies (with reasons for exclusion) are available in Appendix D. The most common reasons that studies were not included were that they did not contain relevant outcomes to the review, were conducted in settings not relevant to primary care, or employed an active intervention as the comparison intervention rather than usual care, no treatment, or attention control conditions.

## Description of Included Studies

Of the 39 included studies (n = 65,888) 22 are from the review conducted in 2014.^102,^ ^107,^ ^108,^ ^111,^ ^112,^ ^116,^ ^118,^ ^119,^ ^125,^ ^127–129,^ ^135,^ ^137,^ ^145,^ ^148–150,^ ^154–156,^ ^158^ These met the inclusion and exclusion criteria set forth for the current synthesis and are combined with 17 newly identified studies.^105,^ ^110,^ ^113,^ ^117,^ ^122,^ ^132,^ ^142,^ ^144,^ ^153,^ ^159–166^ Nine studies that were included in the previous review were dropped from the current review due to high risk of bias^167–169^ or having a publication date prior to 2000.^170–175^ Figure 2 shows the distribution of the included age groups, study population STI risk levels, intervention contact times, and key outcomes reported for the included studies. The newly available studies included four conducted among adolescents,^144,^ ^159,^ ^160,^ ^163^ five conducted among a mix of adolescents and young adults,^117,^ ^122,^ ^153,^ ^164,^ ^166^ and one focused solely on young adults.^132^ The remaining seven enrolled mostly adults and spanned a wider age range.^105,^ ^110,^ ^113,^ ^142,^ ^161,^ ^162,^ ^165^ Nearly all of the included evidence considers intervention effectiveness for individuals at an increased risk for STI, including some participants with recent STI diagnosis. Most provided high contact time interventions involving more than two hours of time spent engaging study participants. Tables 1 and 2 provide summary information on study population, setting, design, and intervention characteristics of the included studies, described below.

Figure 2 Studies Included in Evidence Review, by Subpopulation (k=39)

Figure 2 depicts the studies included in the evidence review, organized by age group and risk for sexually transmitted infection, as well as the intervention contact times and Key Question 1 outcome (STI).

| Adolescents^*^ | Adolescents & Young Adults^†^ | Young Adults^‡^ | Adults^§^
Increased STI Risk - Highest^ǁ^ | Champion, 2012^116^ (STI) | [underlined: Costa, 2017] ^117^; ^^[underlined: Free, 2016]^122^ (STI); Shain, 2004^155^ (STI) | ^^Crosby, 2009^118b^ (STI); ^^Metch, 2013^137b^ (STI) | ^[underlined: Bailey, 2016]^105^ (STI); ^Carey, 2010^112^ (STI); ^^[underlined: Carey, 2015]^113^ (STI); ^^Marrazzo, 2011^135^ (STI); [underlined: O’Cleirigh, 2019] ^162^; ^^Neumann, 2011^145^ (STI); ^Warner, 2008^156^ (STI)
Increased STI Risk^¶^ | [underlined: Bai, 2018] ^160^; DiClemente, 2004^119^ (STI); Jemmott, 2005^127^ (STI); [underlined: Morrison-Beedy, 2013] ^144^; Redding, 2014^163^ | Berenson, 2012^107^ (STI); Kershaw, 2009^129^ (STI); ^^Peipert, 2008^148^ (STI); ^[underlined: Shafii, 2019^164^ (STI)]; [underlined: ^Whiteley, 2018] ^166^ | Ehrhardt, 2002^102^; ^[underlined: Lewis, 2018]^132a^; ^Proude, 2004^150^; ^Scholes, 2003^154a^; Wingood, 2013^158^ (STI)^102^ | Berkman, 2007^108^; ^^[underlined: Billings, 2015]^110^; Carey, 2004^111^; ^Jemmott, 2007^128^ (STI); [underlined: Mittal, 2017] ^142^; [underlined: Peragallo Montano, 2019] ^161^; ^^[underlined: Tzilos Wernette, 2018^165^ (STI)]
Average STI Risk | ^^Guilamo-Ramos, 2011^125^; [underlined: Ybarra, 2017] ^159^ | [underlined: Sanci, 2015] ^153^ | | ^^Petersen, 2007^149^ (STI)

(STI) = Study reported at least one diagnosed sexually transmitted infection outcome by study group and is included for KQ1.

Study evaluated only high intervention contact times (>120 minutes) unless otherwise indicated: ^ included arms testing low contact intervention (<30 minutes) or ^^ arms testing moderate contact interventions (30-120 minutes).

Underline indicates newly identified study since prior evidence review

* Study participants ranged in age from 12 to 19 years

† Study participants ranged in age from 12 to 25 or study included adolescents and adults with population mean age < 25 years

‡ Study participants ranged in age from 18 to 25 only or study enrolled adults of all ages with population mean age <25 years

§ Study participants ages 18 and older or enrolled broad age range population with mean age ≥25 years

ǁ Recent STI history, diagnosis or visit to STI clinic

¶ Based on reported sexual risk behaviors and/or sociodemographic characteristics associated with higher community STI prevalence

Abbreviation: STI = sexually transmitted infection.

Table 1 Design and Baseline Population Characteristics of Included Studies—Adolescents and Young Adults^*^

Author, year Quality | Country Recruitment setting | Risk | N rand | Population description | Intervention name; Intervention description | Control condition | Mean age (range), yrs | % Female | % Race/Ethnicity | Sexual/STI history
Bai, 2018^160^; Good | US; Primary care clinic, community-based health clinic | Increased | 187 | Adolescents aged 13-18 yrs, with depressive symptoms | Healthy Teens; IG1: Ten 60 minute in-person sessions | Usual care | 16.06 (13-18) | 57 | White: 8.6; Black: 11.3; Hisp: 73.1; Other: 7.0 | NR
Berenson, 2012^107^; Fair | US; Prenatal or OBGYN | Increased | 1155 | Sexually active women, aged 16–24 yrs, not pregnant, seeking oral contraception | IG1: One 45 minute, individual, clinic-based counseling session + >6 phone calls; IG2: One 45 minute, individual, clinic-based counseling session | Usual care | 19.9 (16-24) | 100 | White: 24.8; Black: 18.6; Hisp: 54.2; Other: 2.3 | Mean sex partners in past 12 months: 1.6; Lifetime STI: 26.1%
Champion, 2012^116^; Fair | US; Community-based health clinic | High | 559 | African and Mexican American adolescent women, aged 14 to 18 yrs, history of abuse or STI | Project SAFE; Two 3-4-hour group counseling sessions, 2 or more individual counseling sessions, 3-5 optional support group sessions | Minimal intervention | 16.5 (14-18) | 100 | Black: 16.4; Hisp: 83.6 | Sexual abuse history: 58.9%; Mean age first intercourse: 13.8 yrs; Sex with IDU: 11%; Mean lifetime number male partners: 7.2; Lifetime STI^†^: ~100%
Costa, 2017^117^; Fair | Portugal; Family planning clinic | High | 177 | Women 16 to 26 yrs of age at high risk for STI | IG1: Six 120-minute group counseling sessions; IG2: Two 15-minute individual counseling sessions, informational | Waitlist | 20 (16-26) | 100 | White: 93.8 | Range in mean (SD) times condom used during last 4 sex acts: 1.7-2.1 (1.8-1.9)
Crosby, 2009^118^; Fair | US; STI clinic | High | 266 | African American men, aged 18-29 yrs, newly diagnosed with STI | Focus on the Future; One 45-50-minute individual counseling session, variety of condoms and water-based lubricant | Minimal intervention | 23.2 (18-29) | 0 | Black: 100 | Condom use at last sex: 48%; Current nonmonogamous sexual relationship: 42%; BL STI: 100%
DiClemente, 2004^119^; Good | US; Community-based health clinic | Increased | 522 | African American adolescent girls, aged 14-18 yrs, reported vaginal intercourse in past 6 mos | HORIZONS; Four 4-hour group counseling sessions | Attention control | 15.98 (14-18) | 100 | Black: 100.0 | History of nonconsexual sex: 13.9%; Condom use at last sex: 30.3%; BL CT: 17.4%; BL GC: 5.2%; BL Trich: 12.6%
Ehrhardt, 2002^102^; Good | US; Women’s health clinic | Increased | 360 | Sexually active women, aged 18 to 30 yrs | IG1: Eight 2-hour group counseling sessions; IG2: Four 2-hour group counseling sessions | None (risk assessment only) | 22.3 (18-30) | 100 | Black: 72.5; Hisp: 16.9; Other: 10.6 | >2 current male partners 23.4%; Never/sometimes used condom during sex in past 3 months.: 75.2%; STI past 3 months: 16.9%; Lifetime STI: 58.3%
Free, 2016^122^; Fair | GBR; STI clinic, University health clinic | High | 200 | People aged 16-24 yrs, diagnosed with STI or reporting >1 partner in past year and condomless sex | 49 to 63 text messages tailored to participant characteristics (gender, STI) | Attention control | 20.5 (16-24) | 70.0 | White: 57.0; Black: 26.5; Asian: 1.0; Other: 15.5 | Condom use at last sex: 33.5%; >2 sex partners in past 12 months.: 92.5%; BL STI: 44.5%
Guilamo-Ramos, 2011^125^; Fair | US; Community-based health clinic | Average | 264 | Mother-child dyads, African American or Latino/a adolescents aged 11-14 yrs, resident mother attending child’s healthcare visit | Mother received one 30-minute individual counseling session + program manual + 2 phone calls | Usual care | 12.9 (NR) | 52.3 | Black: 15.5; Hisp: 84.5 | Sexually active: 6.4%
Jemmott, 2005^127^; Good | US; Hospital-based adolescent medicine clinic | Increased | 682 | Sexually experienced African American and Latina adolescent women, aged 12-19 yrs | IG1: One 250 minutes group counseling session, skills-based; IG2: One 250-minute group counseling session, information-based | Attention control | 15.5 (12-19) | 100.0 | Black: 67.9; Hisp: 32.1 | Unprotected sex in past 3 months: 52%; Multiple sex partners in past 3 months.: 16%; BL STI: 21.6%
Kershaw, 2009^129^; Fair | US; Prenatal or OBGYN | Increased | 712 | Pregnant adolescent and young women without serious medical problems, aged 14 to 25 yrs | Centering Pregnancy Plus; Ten 120-minute group counseling sessions | Usual care | 20.4 (14-25) | 100.0 | White: 6.0; Black: 80.0; Hisp: 13.0; Other: 1.0 | NR
Lewis, 2018^132^; Fair | US; Advertisements or media, general community | Increased | 402 | Sexually active young adults aged 18-25 yrs, report drinking alcohol | IG1: One 5-minute computer web-based personalized feedback session; IG2: One 5-minute computer web-based integrated personalized feedback session | Attention control | 22.4 (18–25) | 54.0 | White: 68.0; Black: 11.0; Asian: 8.0; AI/NA: 1.0; Hisp: 14.0; Other: 12.0 | NR
Metsch, 2013^137^; Good | US; STI clinic | High | 5012 | Adults aged 18+ yrs | One 30-minute individual counseling session + HIV testing | Minimal intervention | NR (2 ranges: 18-25, 68.5%; 25+, 31.5%) | 34.0 | White: 31.8; Black: 41.9; Hisp: 15.3; Other: 11.1 | Predicted mean number unprotected sex acts in past 6 months.: 23.2; Predicted mean number of sex partners in past 6 months.: 4.65; BL STI: 44.3%; BL HIV: 1.1%
Morrison-Beedy, 2013^144^; Good | US; School health clinic, community-based health clinic, hospital-based adolescent medicine clinic, general community | Increased | 639 | Adolescent females aged 15-19 yrs, majority low-income African American | HIPTeens; Four 120-minute information-motivation-behavioral group counseling sessions + two 90-minute group counseling sessions | Attention control | 16.42 (15-19) | 100 | White: 8; Black: 73; Hisp: 16; Other: 20 | Sex in past 3 months: 100%; Mean age first sex, yrs: 14.4
Peipert, 2008^148^; Fair | US; Primary care clinic, Family planning clinic, Prenatal or OBGYN, Advertisements or media | Increased | 542 | Sexually active adolescent and young women aged 13-24 yrs and women aged 25-35 yrs at “high risk” for STI or unintended pregnancy; desire to avoid pregnancy next 2 yrs | Three 30 minute individually tailored computer web-based sessions | Minimal intervention | 22 (13-35) | 100 | White: 45; Black: 26; Hisp: 17; Other: 12 | >11 lifetime number sex partners: 28%; >2 sex partners in past 1 months: 15%; Forced sex in past 12 months: 10%; Lifetime STI: 47%
Proude, 2004^150^; Fair | AUS; Primary care clinic | Increased | 312 | Young adults aged 18-25 yrs | One 15-minute physician counseling session + informational resource pamphlets, 2 condoms, lubricant | Attention control | (18-25) | 71 | NR | Ever had sexual partner: 78%
Redding, 2015^163^; Good | US; Family planning clinic, Community-based health clinic | Increased | 828 | Adolescent females | Step by Step; IG1: Four 25-minute computer sessions followed by individual counseling | Minimal intervention | 16.4 (14-17) | 100 | White: 7.8; Black: 83.9; Asian: 0.8; AI/NA: 1.5; Hisp: 7.8 | Had vaginal or anal sex: 95.9%; Mean total number of sex partners: 5; BL Syph: 1.7%; BL GC: 10.4%; BL CT: 20.6%; BL hrHPV: 5.9%; BL Herpes: 1.8%
Sanci, 2015^153^; Fair | AUS; Primary care clinic | Average | 901 | Healthy youth aged 14-24 yrs | Clinicians received 9 hours of training + 2 practice visits | Minimal intervention | (14-24) | 75.7 | NR | NR
Scholes, 2003^154^; Fair | US; Primary care clinic | Increased | 1210 | Sexually active women aged 18-24 yrs, not sexually monogamous, at risk for HIV/AIDS | 2 tailored print mailings | Usual care | 21 (18-25) | 100 | White: 69; Black: 19; Other: 12 | >2 sex partners in past 12 months: 56.5%; Sex with nonprimary partner in past 3 months: 19%; Lifetime STI: 27%
Shafii, 2019^164^; Fair | US; STI clinic, advertisements or media | Increased | 272 | Adolescents and young adults aged 14-24 yrs with a history of risky sexual behavior | e-KISS (electronic-KIOSK Intervention for Safer Sex); IG1: One computer-based tailored feedback session | None | 21 (15-24) | 64.7 | White: 37.4; Black: 34.1; Asian: 10.0; AI/NA: 2.2; Hisp: 7.0; Other: 9.3 | NR
Shain, 2004^155^; Fair | US; STI clinic | High | 775 | Mexican-American and African American women aged 15-45 yrs, STI diagnosis | IG1: One individual counseling session + three 3-hour group counseling sessions + option to attend five 90-minute group counseling sessions; IG2: One individual counseling session + three 3-hour group counseling sessions | Minimal intervention | 21.0 (15-45) | 100 | Black: 23.2; Hisp: 76.8 | >1 sex partner in past 3 months: 25.7%; BL STI: 100%; BL CT: 77.8%; BL Syph: 4.6%
Whiteley, 2018^166^; Fair | US; General community | Increased | 60 | Sexually active adolescents aged 15-24 yrs | IG1: Eight emails containing 19 links to internet content | Waitlist | 18.6 (15-24) | 38 | Black: 52; Hisp: 36 | NR
Wingood, 2013^158^; Good | US; Primary care clinic | Increased | 848 | African American women aged 18-29 yrs | Two 4-hour group counseling sessions | Attention control | 22 (18-29) | 100 | Black: 100 | BL STI: 17%; BL CT: 10.4%; BL hrHPV:38.9%
Ybarra, 2017^159^; Good | US; Advertisements or media | Average | 302 | Adolescent cisgender males aged 14-18 yrs, identify as gay, bisexual, or queer | Guy2Guy Intervention Group; Text messages 5-10 times/day five consecutive weeks + text messages for one week | Attention control | NR (14-18) | 0.00 | White: 67.1; Black: 14.8; Other: 18.0 | Ever had sex: 70%

* All studies were randomized trials, except: Sanci, 2015 = Cluster RCT

† Participants recruited based on history of STI or abuse

Abbreviations: AI/NA = Alaska Native/Native American; AUS = Australia; BL = baseline; CT = chlamydia trachomatis; GBR = Great Britain; GC = gonorrhea; Hisp = Hispanic; HIV = human immunodeficiency virus; hrHPV = high-risk humanpapilloma virus; IDU = intravenous drug user; IG = intervention group; NR = not reported; OBGYN = obstetrics & gynecology; Rand = randomized; RESPECT = Recovery, Empowerment, Social Services, Prenatal care, Education, Community, and Treatment; RCT = randomized controlled trial; SD = standard deviation; STI = sexually transmitted infection; Syph = syphilis; Trich = trichomoniasis; US = United States; Yrs = years.

Table 2 Design and Baseline Population Characteristics of Included Studies—Adults^*^,^†^

Author, year Quality | Country Recruitment setting | Risk | N rand | Population description | Intervention name; Brief description | Control condition | Mean age (range), yrs | % Female | % Race/Ethnicity | Sexual/STI history
Bailey, 2016^105^; Good | GBR; STI clinic | High | 176 | Men aged ≥16 yrs | Men’s Safer Sex; One 10-minute website visit | Usual care | 29.4 (≥16) | 0 | White: 69.2; Black: 14.5; Asian: 7.5; Other: 8.2 | BL STI: 3.4%
Berkman, 2007^108^; Good | US; Behavioral health clinic | Increased | 149 | Men aged 18 to 59 yrs, psychiatric outpatients with severe mental illness diagnosis and history of psychosis | Enhanced SexG (E-SexG); Thirteen 60-minute, group counseling sessions | Attention control | 38.6 (18-56) | 0.0 | White: 11.0; Black: 54.0; Hisp: 28.0; Other: 7.0 | NR
Billings, 2015^110^; Fair | US; Community-based health clinic | Increased | 83 | African American women, aged 18-50 yrs, at high risk for STI | Safe Sistah; One computer-based educational session | Waitlist | 35.1 (18-50) | 100 | Black: 100 | >1 sexual partner in past 2 months: 34.5%
Carey, 2004^111^; Fair | US; Behavioral health clinic | Increased | 268 | Women and men, aged 18+ yrs, psychiatric outpatients with alcohol or drug use in the past year | Ten group counseling sessions | Usual care | 36.5 (≥18) | 54 | White: 67; Black: 21; Other: 12 | Lifetime STI: 38%
Carey, 2010^112^; Fair | US; STI clinic | High | 1,483 | Women and men, aged 18+ yrs, sexual risk behavior in past 3 months, willing to be tested for HIV | IG1: One 15-minute individual counseling session + 4-hour intensive motivational, behavioral, skills workshop; IG2: One 15-minute individual counseling session + 4-hour intensive informational workshop; IG3:One 15-minute individual counseling session; IG4:One 15-minute informational video + 4-hour intensive informational workshop; IG5: One 15-minute informational video + 4 hour intensive motivational, behavioral, skills workshop | Minimal intervention | 29.2 (≥18) | 46.4 | White: 24.3; Black: 63.9; Hisp: 8.7; Other: 11.9 | Condom use at last intercourse: 27%; Lifetime history of sex trade: 22%; Age at first intercourse <13 yrs: 18%; BL STI: 18.1%
Carey, 2015^113^; Fair | US; STI clinic | High | 1,010 | Men and women aged 16+ yrs, sexual risk behavior in past 3 months | IG1: One 22-minute video + sexual health questionnaire; IG2: One 22-minute video + general health questionnaire; IG3: One 22-minute video + sexual health questionnaire | Attention control | 28.5 (NR) | 44 | White: 19; Black: 69; Hisp: 8; Other: 13 | >1 concurrent sexual partners in past 3 months.: 47%
Jemmott, 2007^128^; Good | US; Women’s health clinic | Increased | 564 | Sexually experienced African American women, aged 18-45 yrs | Sister-to-Sister; IG1: One 200-minute group counseling session, skills-based; IG2: One 200-minute group counseling session, information-based; IG3: One 20-minute individual counseling session, skills-based; IG4: One individual, 20-minute counseling session, information-based | Attention control | 27.2 (18-45) | 100 | Black: 100 | Condom use at last sex: 38.7%; BL STI: 20.3%
Marrazzo, 2011^135^; Fair | US; Advertisements or media | High | 89 | WSW aged 16-30 yrs, positive BV diagnosis, reported sex with woman in past 60 days | One 30-minute individual counseling session | Minimal intervention | 25.4 (16-30) | 100 | Black: 8 | >1 female sex partner: 24.7%; BL BV: 100%
Mittal, 2017^142^; Fair | US; Community-based health clinic, women’s health clinic, community agencies | Increased | 55 | Women aged 18+ yrs, history of intimate partner violence | Supporting positive and healthy relationships (SUPPORT); Three 135-minute individual counseling sessions + five 135-minute group counseling sessions | Minimal intervention | 34.5 (18-49) | 100 | White: 33.0; Black: 51.0; Other: 16.0 | Median number lifetime sex partners: 19; Mean (SD) sex partners in past 3 months: 1.5 (1.2); Mean (SD) episodes unprotected sex in past 3 months: 21 (27.2)
Neumann, 2011^145^; Fair | US; STI clinic | High | 3,365 | Adults aged 18+ yrs | VOICES/VOCES; One 45-minute group counseling session | Usual care | 29.3 (18-71) | 51.5 | White: 0.8; Black: 40.1; Hisp: 50.9; Other: 8.2 | Ever used condoms: 80.8%; BL STI: 22.2%
O’Cleirigh, 2019^162^; Fair | US; Community-based health clinic, advertisements or media | High | 43 | Adult MSM with a history of childhood sexual abuse | IG1: HIV/STI counseling and testing plus 10 in-person therapy sessions | Usual care | 39.2 | 0 | White: 62.8; Black: 25.6; Hisp: 7.0; Other: 4.7 | NR
Peragallo Montano^161^; Fair | US; Community-based health clinic, advertisements or media, community agencies | Increased | 320 | Refugee and immigrant Hispanic women (>95% born outside U.S.) aged 18-50 yrs with any recent sexual activity | Salud, Educacion, Prevencion y Autocuidado (SEPA); IG1: Three 2.5-hour sessions | Waitlist | 35.5 (18-50) | 100 | Hisp: 100 | Any sexual activity in past 3 mos.: 100%
Petersen, 2007^149^; Fair | US; Primary care clinic | Average | 764 | Women aged 16-44 yrs at risk of unintended pregnancy | Women’s Reproductive Assessment Program (WRAP); One individual counseling + followup phone call or visit | Attention control | NR (16-44) | 100 | White: 62; Black: 27; Other: 10 | Sex in past 30 days: 70%
Tzilos Wernette, 2018^165^; Fair | US; Prenatal or OBGYN | Increased | 50 | Pregnant women at risk for STI/HIV and alcohol/drug use. | IG1: One 60-minute computer session plus a 15 min booster session | Attention control | 24.4 | 100 | White: 30; Black: 26; AI/NA: 4; Hisp: 32; Other: 40 | NR
Warner, 2008^156^; Good | US; STI clinic | High | 40,282 | Individuals making visits to STI clinics | Safe in the City; One 23-minute video + educational pamphlets and condoms | Usual care | NR (NR) | 30.0 | Black: 18.5; Hispanic: 25.0; White: 46; Other: 11.0 | BL STI: 15.5%

* Four studies did not exclude adolescents, but primarily recruited adults and the mean age in the study populations was above 25 years

† All studies were randomized trials, except: Neumann, 2011 = nonrandomized controlled trial; Warner, 2008 = nonrandomized controlled trial

Abbreviations: BL = baseline; BV = bacterial vaginosis; CT = chlamydia trachomatis; E-SexG = Enhanced Sex, Games, and Videotape intervention; GBR = Great Britain; Hisp = Hispanic; HIV = human immunodeficiency virus; IG = intervention group; NR = not reported; Rand = randomized; SD = standard deviation; STI = sexually transmitted infection; SWE = Sweden; US = United States; WSW = women who have sex with women; Yrs = years; VOICES/VOCES = Video Opportunities for Innovative Condom Education and Safer Sex.

### Population and Setting

Seventeen trials examined STI or behavioral outcomes in populations of adolescents only (k=8)^116,^ ^119,^ ^125,^ ^127,^ ^144,^ ^159,^ ^160,^ ^163^ or adolescents and young adults combined (k=9) (Table 3).^107,^ ^117,^ ^122,^ ^129,^ ^148,^ ^153,^ ^155^ ^164,^ ^166^ Others focused primarily on young adults (k=7).^102,^ ^118,^ ^132,^ ^137,^ ^150,^ ^154,^ ^158^ The remaining trials enrolled adults spanning broader age ranges (k=7)^108,^ ^110–112,^ ^128,^ ^142,^ ^145^ or an even broader range including some adolescents (k=8).^105,^ ^113,^ ^135,^ ^149,^ ^156,^ ^161,^ ^162,^ ^165^ Among the studies of adults and mixed-age population, the average age of participants was <30 years in most studies, and none reported an average age of 40 years or older. Thus, among studies that included adults, young adults (i.e., 18–25) were most commonly recruited. People age 40 and older are minimally represented in the body of evidence, and no trials focused on adults in older age ranges.

Table 3 Summary of Study Population Characteristics

Characteristics | No. studies | % studies
All studies | 39 | 100
Ages groups in studies
Adolescents^*^ | 8 | 21
Adolescents and Young Adults^†^ | 9 | 23
Young Adults^‡^ | 7 | 18
Adults^§^ | 15 | 38
Sex or gender of study population
Women only | 20 | 51
Men only | 5 | 13
Men & Women | 14 | 36
Majority of study population racial or ethnic minority^ǁ^ | 27 | 69
Defined STI Risk Populations
Unselected, average risk populations^¶^ | 4 | 10
Increased STI risk^#^ | 22 | 56
Increased STI risk - Highest^**^ | 13 | 33
Reported at least 10% of study population were not heterosexual (e.g., gay, bisexual, lesbian, MSM, WSW) | 10 | 26

* Study participants ranged in age from 12 to 19 years

† Study participants ranged in age from 12 to 25 or study included adolescents and adults with population mean age < 25 years

‡ Young Adults – Study participants ranged in age from 18 to 25 only or study enrolled adults of all ages with population mean age <25 years

§ Adults – Study participants ages 18 and older or enrolled broad age range population with mean age ≥25 years

ǁ Of the 27 studies conducted in the United States

¶ General risk population, attending primary care or family planning clinic, not targeting specific sexual risk behaviors or people in high STI prevalence communities. Includes studies with a mix of abstinent and sexually active adolescents

# Increased STI risk population defined based on study enrollment of individuals belonging to a population known to have higher rates of STI (sexually active adolescent and young adult populations) or engaging in sexual behaviors associated with higher STI risk (e.g., unprotected intercourse, multiple concurrent partners). Many studies in this category enrolled participants with several risk factors.

** High STI risk population defined as individuals seeking care at STI clinic or having recent, suspected, or current STI

Abbreviations: CCT = controlled clinical trial; MSM = men who have sex with men; MSW = men who have sex with women; No. = number; RCT = randomized controlled trial; STI = sexually transmitted infection; US = United States; WSM = women who have sex with men; WSW = women who have sex with women.

Over half of the included studies were among women or girls only (k=20)— including one focused on pregnant individuals—^129^ or mostly women (k=3). Only seven studies targeted men or primarily men, and another seven studies enrolled similar numbers of men and women. Most studies were conducted in the United States (k=34), and among these three-quarters (k=27) enrolled study populations in which a majority of participants identified as a racial or ethnic minority.

Most of the included studies enrolled participants at increased risk of an STI (Figure 2, k=35). Several studies recruited individuals at increased risk for STI based on their sociodemographic characteristics (e.g., age, member of low-resource or high STI prevalence community), reported sexual behaviors, or personal history associated with higher STI risk (k=22). Among the increased risk study populations, those recruited from STI clinics or based on their recent STI history were considered highest risk (k=13). Only four included studies recruited populations at average risk for STI, as follows. One study conducted among individuals across the age spectrum did not have specific criteria aimed at enrolling the participants based on risk characteristics.^149^ Two studies enrolled adolescent populations that include large proportions of sexually inexperienced or sexually inactive participants and were therefore considered to have low to average STI risk.^125,^ ^159^ One newly added study included a mix of sexually active and non-sexually active, average-risk adolescents and young adults making primary care visits.^153^

Study reported STI and sexual history characteristics of participants reflected the aim of most of the trials to provide interventions for individuals at increased risk for STI. Three studies recruited individuals presenting with a current STI,^118,^ ^135,^ ^155^ and nine additional studies reported rates of STIs at baseline greater than 15 percent.^112,^ ^119,^ ^122,^ ^127,^ ^128,^ ^137,^ ^145,^ ^156,^ ^158,^ ^163,^ ^164^ Self-reported sexual risk behaviors were also used to identify high-risk populations for study recruitment.

Only one study specifically reported the sex and gender of participants; this study enrolled adolescent cisgender males (e.g., gender identity matches sex assigned at birth) (Table 3).^159^ In this study, the sexual orientation of study participants was a key recruitment criterion and the intervention was designed for individuals identifying as gay, bisexual or queer (72% identified as gay). A few studies recruited participants based on their sexual partnerships or orientation. For example, one study recruited WSW with a diagnosis of BV;^135^ others limited the study population to heterosexual women.^117,^ ^143^ In describing the study participants, a few studies described whether participants engaged in sex with the same-sex or same-gender partners or identified as gay or bisexual.^122,^ ^137,^ ^145,^ ^150,^ ^156,^ ^162,^ ^164,^ ^166^ Only one study reported that the study population included transgender participants (<1% of sample).^156^ The remainder did not report sexual identity or sexual orientation characteristics of the included populations, although several specified sexual practices in their inclusion/exclusion criteria (e.g., vaginal intercourse in previous 3 months).

### Intervention Characteristics

Tables 1 and 2 provide brief descriptions of the interventions, and further detail is provided in (Appendix E Tables 1 and 2; Table 9). In total there were 54 intervention arms tested across the 39 studies. Most were conducted in health care settings including general primary care, obstetrics and gynecology, STI clinics, women’s health clinics, adolescent medicine, and family planning clinics (Table 4). Eleven of the interventions tested involved low contact times (<30 minutes), and about half involved high contact times (over 2 hours), ranging from 165 minutes to 1,750 minutes. Nine studies^105,^ ^112,^ ^128,^ ^132,^ ^150,^ ^154,^ ^156,^ ^164,^ ^166^ included a low-contact time intervention arm (<30 minutes), 13^107,^ ^110,^ ^113,^ ^117,^ ^118,^ ^122,^ ^125,^ ^135,^ ^137,^ ^145,^ ^148,^ ^149,^ ^165^ included a moderate contact time intervention arm (30-120 minutes), and over half^102,^ ^107,^ ^108,^ ^111,^ ^112,^ ^116,^ ^117,^ ^119,^ ^127–129,^ ^142,^ ^144,^ ^153,^ ^155,^ ^158–163^ (21/39; 54%) tested a high-contact time intervention arm (over 2 hours)..

Table 4 Summary of Study Design Characteristics

Characteristics | No. studies | % studies
All studies | 39 | 100
Study design
RCT | 36 | 92
Cluster RCT | 1 | 3
Nonrandomized CCT | 2 | 5
Quality Rating^*^
Good | 13 | 33
Fair | 26 | 67
Included in previous review (2014) | 22 | 56
Conducted in US | 34 | 87
Conducted more than 10 years ago (before 2009) | 12 | 31
Recruitment Setting^†^
Community health clinic, primary care clinic, school clinic | 12 | 31
STI Clinic | 9 | 23
Women’s health, OBGYN or family planning clinic | 6 | 15
Other specialty health clinic (behavioral health, adolescent health) | 3 | 8
Online, media, advertisements | 9 | 23
Intervention provided by health professional (i.e., nurse, physician, social worker, psychologist, mental health specialist) | 11 | 28
Intervention time^‡^
Low contact (<30 minutes) | 7 | 18
Moderate contact (30-120 minutes) | 11 | 28
High contact (>120 minutes) | 21 | 54
Intervention included group counseling | 17 | 44
Control group
No intervention/usual care/waitlist | 16 | 41
Minimal intervention | 10 | 26
Attention control | 13 | 33
Longest followup time point reported
3-5 months | 7 | 18
6-11 months | 8 | 21
12 months | 18 | 46
>12 months (range 14-24) | 6 | 15

* K additional studies were rated as poor quality and excluded from the review.

† Studies with multiple recruitment settings were categorized according to the most specialized.

‡ Studies with more than one intervention arm were categorized according to the longest contact-time.

Abbreviations: CCT = controlled clinical trial; No. = number; OBGYN = obstetrics and gynecology; RCT = randomized controlled trial; STI = sexually transmitted infection; US = United States.

The most common therapeutic or conceptual approach taken in the included interventions was motivational interviewing,^176,^ ^177^ used in eleven studies (15 intervention arms).^111–113,^ ^116,^ ^135,^ ^149,^ ^160,^ ^163–165^ Another seven studies (9 interventions arms) employed cognitive behavioral therapy approaches.^107,^ ^117,^ ^127,^ ^155,^ ^158,^ ^160,^ ^162,^ ^178^ Social and behavioral theories were the foundation for several of the interventions, sometimes paired with specific therapeutic approaches. The most commonly cited theory was the Information-Motivation-Behavioral Skills (IMB) model,^179,^ ^180^ which guided intervention development in eight studies.^112,^ ^113,^ ^142,^ ^143,^ ^159,^ ^160,^ ^163,^ ^164^ Social cognitive theory^181^ was cited in three studies^119,^ ^128,^ ^129^ and the transtheoretical model^182^ in two.^112,^ ^148^ The Health Belief Model^183^ was cited as a source for one study.^107^ The Theory of Gender and Power^184^ was drawn upon for two of the interventions evaluated^119,^ ^142^ and the AIDS Risk Reduction Model (ARRM)^185^ in one study that focused on adolescent girls^116^ and another with adolescent girls and young adult women.^155^ Several studies described general approaches but did not report designing the intervention according to any specific therapeutic approach or theory.^102,^ ^105,^ ^110,^ ^118,^ ^122,^ ^132,^ ^137,^ ^145,^ ^150,^ ^154,^ ^156^ We did not review the earlier qualitative work and pilot investigations for the included interventions, and it is likely there were theoretical underpinnings considered at early stages of program development.

Fourteen of the intervention arms primarily involved mobile-phone text or computer interventions, and all but two of these involved low or moderate contact times ranging from 5 to 90 minutes.^105,^ ^110,^ ^111,^ ^113,^ ^122,^ ^132,^ ^148,^ ^159,^ ^163–166^ In contrast, one recent study tested a text-based intervention involving 5-10 daily messages for five weeks, amounting to several hours of texting contact with adolescent males identifying as gay, bisexual, or queer.^159^ These interventions using mobile and computer technology all took place in an STI clinic or at participants’ homes via personal devices, and most were self-directed ^113,^ ^159^

The most common intervention component was group counseling (25 intervention arms). Group counseling was frequently paired with other components, such as individual counseling, videos, video games, or phone contact. Interventions with group counseling involved more than 2 hours of contact in all but one study. That study recruited adult men and women at STI clinics for a single, mixed-gender group sessions with moderate contact time (40–60 minutes).^145^ In most studies of group counseling, participants were of the same sex or gender. Clinic settings and involvement of trained health professionals were commonly employed for group counseling interventions.

Twenty-three study arms included individual counseling alone or combined with other components. Eleven study arms involved individual counseling only, delivered by a range health professionals (e.g., physicians, nurses, mental health professionals) or by health educators,^108,^ ^112,^ ^128,^ ^150,^ ^160,^ ^162^ trained research staff, or trained lay peer counselors.^107,^ ^118,^ ^135,^ ^137,^ ^149^ Eight intervention arms involved both group and individual counseling and sometimes also included video or phone components; these tended to involve high contact times (> 2 hours). In three studies, individual counseling was combined with print or phone components.^107,^ ^117,^ ^125^ Only four study arms (from three studies) tested low contact time interventions, ranging from 15 to 20 minutes, with trained health professionals.^112,^ ^128,^ ^150^

Seven intervention arms (six studies) with low contact, ranging from 0 to 29 minutes, were self-directed with computer web-based educational sites^105,^ ^132,^ ^164^ or intervention via emails, texts, printed materials or video. One study of young adult women tested an intervention using print materials only,^154^ and a study of adolescents and adults comprised a low contact time (~23 minutes), self-directed print and video intervention.^156^ Another study of adolescents and young adults sent 8 emails containing links to internet contents.^166^

### Comparators and Outcomes

One third (k=13) of the studies employed attention control conditions involving an equivalent amount of contact time related to healthy lifestyle topics other than STI prevention (Table 4). The remainder used minimal intervention controls (k=10) or no intervention, usual care, or waitlist controls (k=16). The outcomes reported in the trials varied, both in the type of outcome reported and the specific measures used. Five trials reported STI outcomes, but not intermediate behavioral outcomes associated with the interventions. Another 16 trials reported both STI and behavioral outcomes, and 18 reported only behavioral outcomes. The longest followup times reported across the studies ranged from 3 to 24 months, with the majority (61%) reporting outcomes at 12 months or more.

### Quality Assessment

Thirty-six of the included studies were RCTs; two were nonrandomized clinical trials,^145,^ ^156^ including the largest study by Warner et al.,^156^ (n = 40,282) and one was a cluster randomized trial.^153^ Thirteen of the trials were “good quality” and the remaining 26 were “fair quality” based on risk of bias assessments. Thirteen newly identified studies otherwise eligible for inclusion were excluded from this review based on poor quality ratings in risk of bias assessment. The primary threats to internal validity that resulted in exclusion of studies were high loss to followup (>40%), differential attrition between treatment arms, and questionable handling of missing data.

Among the fair-quality studies included in this review, sources of bias most commonly encountered were lack of information reported on key quality domains (e.g., allocation concealment, blinding) and moderate loss to followup reported with no imputation or data substitution.

## Key Question 1 Do Behavioral Counseling Interventions to Decrease Risky Sexual Behaviors, Increase Protective Behaviors, or Both Reduce STIs or Related Morbidity and Mortality?

### Summary of Results

No studies reported intervention effects on STI morbidity or mortality, but 21 included studies reported on the effectiveness of behavioral interventions for preventing STI. Overall, the mostly moderate- and high-contact time interventions included in this body of evidence which focused on individuals at increased STI risk were effective in reducing the incidence of STI in followup, most commonly reported at 6 to 12 months. The overall pooled OR was 0.66 (95% CI 0.54, 0.81; I^2^ 74%, n=52,072). Only four studies reported higher absolute STI rates in the control condition, but the rates were not statistically different from rates in the intervention groups. Based on meta-regression comparisons, larger effect sizes were associated with studies conducted among adolescents (p<0.01), testing high-contact interventions (>120 minutes of contact) (p=0.02), or including group counseling sessions (p=0.02). Intervention effect sizes tended to be smaller in the largest studies and those published more recently, but the larger studies also tended to be among mixed-gender populations with broader age ranges, lower rates of STI, and tested shorter duration interventions. Overall, subgroup comparisons tended to be based on very few studies, however, study population and intervention characteristics tended to be confounded, limiting strong conclusions about the specific factors associated with greater intervention effectiveness.

### Detailed Results

#### Prevention of Morbidity and Mortality From STIs

No studies reporting on the effects of interventions on morbidity or mortality sequelae from STI infection were identified.

#### STI Prevention

Twenty-one trials reported an STI outcome (n = 59,328) (Appendix E, Tables 3 and 4) and 19 reported measures that could be combined for meta-analysis (Table 5 and Figure 3).

Table 5 Meta-Analysis Results for Outcome of Sexually Transmitted Infection

| No. studies (n randomized or allocated) | Pooled Analysis No. studies (n analyzed) | Effect Estimate | Pooled result (95% CI) | I^2^ % | Tau^2^ | Effect Range^*^ | Effect Median (IQR)^*^
All trials reporting STI | 21 (59,328)^†^ | 19 (52,072) | OR | 0.66 (0.54, 0.81) | 74.1 | 0.11 | 0.02 to 3.07; ARD: −18.5 to +9.5 | 0.94 (0.62 to 1.13); ARD: −0.3 (−3.4 to +1.0)
Sensitivity analysis: excluding trial of BV prevention among WSW^135^,^‡^ | -- | 18 (51,985) | OR | 0.65 (0.52, 0.80) | 75.3 | 0.11 | -- | --
Statistically significant subgroup effect comparisons
Trials limited to adolescents | 3 (1,763) | 3 (1,166) | OR | 0.22 (0.02, 2.30)^§^ | 72.7 | 0.46 | 0.02 to 1.72; ARD: −8.4 to +9.1 | 0.76 (0.14 to 1.17); ARD: +0.8 (−5.3 to +2.15)
Trials [underlined: not] limited to adolescents | 18 (57,565)^†^ | 16 (50,906) | OR | 0.78 (0.67, 0.91) | 50.9 | 0.03 | 0.32 to 3.07; ARD: −18.5 to +9.5 | 0.94 (0.66 to 1.12); ARD: −0.4 (−2.5 to +1.0)
High contact time interventions (>120 minutes) | 9 (7,300)^†^ | 8 (3,974) | OR | 0.46 (0.28, 0.75)^§^ | 65.4 | 0.17 | 0.02 to 1.72; ARD: −15.8 to +9.1 | 0.72 (0.47 to 0.99); ARD: −1.9 (−5.3 to +1.0)
Moderate contact time interventions (30-120 minutes) | 9 (11,298)^†^ | 8 (9,072) | OR | 0.90 (0.66, 1.25)^§^ | 58.8 | 0.06 | 0.32 to 3.07; ARD: −18.5 to +7.0 | 1.05 (0.9 to 1.12); ARD: 0 (−1.0 to +1.8)
Low contact time interventions (<30 minutes) | 4 (41,294)^ǁ^ | 4 (39,230)^ǁ^ | OR | 0.66 (0.36, 1.24)^§^ | 43.6 | 0.07 | 0.43 to 1.62; ARD: −13.0 to +9.5 | 0.85 (0.64 to 1.08); ARD: −1.1 (−6.2 to 2.0)
Trials including group counseling | 9 (9,510)^†^ | 8 (6,567) | OR | 0.47 (0.28, 0.78)^§^ | 74.9 | 0.19 | 0.02 to 1.72; ARD: −15.8 to +9.1 | 0.72 (0.47 to 0.99); ARD: −2.2 (−5.3 to +1.0)
Trials [underlined: not] including group counseling | 12 (49,818)^†^ | 11 (45,505) | OR | 0.90 (0.74, 1.08) | 42.7 | 0.03 | 0.32 to 3.07; ARD: −18.5 to +9.5 | 1.01 (0.77 to 1.18); ARD: 0 (−1.4 to +2.0)

* Range of effects for all study arms and timepoints, i.e., not limited to records in the meta-analysis

† Number of trials reporting an STI outcome does not add up to the total number of trials included in the pooled analyses because some trials did not provide sufficient data for inclusion in the meta-analysis

‡ Sensitivity analysis conducted because the STI outcome and population were qualitatively different than the rest of the included evidence.

§ Effect based on restricted maximum likelihood model with the Knapp-Hartung adjustment for small samples. Remaining effects based on DerSimonian and Laird method. Confidence intervals for subgroup estimates shown in the stratified forest plot figures are also based on the DerSimonian and Laird method and are narrower than the confidence limits obtained with statistical adjustments for pooling a small number of studies.

ǁ Number of trials for low contact subgroup includes an additional intervention arm^128^ focusing on the same skills as the high contact time subgroup.

Abbreviations: ARD = absolute risk difference; CI = confidence interval; IQR = interquartile range; k = number of studies; n = number of observations; OR = odds ratio; WSW = women who have sex with women.

Figure 3 Combined Effects of Interventions on Diagnosed Sexually Transmitted Infections, Stratified by Age Groups^*^ * Confidence intervals provided in this plot are estimated with the DerSimonian and Laird method. Table 5 provides conservative confidence intervals for the subgroup pooled effects that are estimated by the Restricted Maximum Likelihood method with Knapp Hartung correction that accounts for greater uncertainty when pooling few studies

† Study participants ranged in age from 12 to 19 years

‡ Study participants ranged in age from 12 to 25 or study included adolescents and adults with population mean age < 25 years

§ Study participants ranged in age from 18 to 25 only or study enrolled adults of all ages with population mean age <25 years

ǁ Study participants ages 18 and older or enrolled broad age range population with mean age ≥25 years

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; mo = month; n = number of observations; NR = not reported; OR = odds ratio.

Figure 3 displays a forest plot of the effect of 19 behavioral intervention trials for STI prevention. The overall pooled odds ratio is 0.66 (95% CI, 0.54 to 0.81) suggesting a statistically significant 34 percent lower odds of STI with intervention compared with a control condition.

The overall pooled effect of behavioral interventions for STI prevention in the included evidence suggested a statically significant 34 percent lower odds of STI with intervention compared with a control condition (pooled OR = 0.66, 95% CI 0.54, 0.81; I^2^ 74%) (Table 5 and Figure 3). Results were predominantly in the direction of an intervention benefit; only four trials reported more STI diagnoses in the intervention group than in the control,^113,^ ^135,^ ^137,^ ^165^ but none were statistically different. STI incidence rates were highly variable across studies; control group rates ranged from 0 to 50 percent, while intervention groups ranged from 0 to 53 percent. The absolute effects across studies ranged from 19 percentage points lower STI incidence in the intervention group to 10 percentage points higher incidence, with a median risk difference (IQR) of −0.3 (−3.4, +1.0). Statistical heterogeneity was substantial, and there was also considerable clinical heterogeneity, particularly in terms of the populations and intervention characteristics. Sensitivity analyses were conducted to examine the pooled effect when excluding studies that were unique in terms of STI outcomes and study population, as for a study conducted with WSW that tested an intervention to prevent the spread of BV, and this did not change the overall result.^135^

Six studies with the largest effect sizes reduced the odds of STI infection by 50 percent or more (50 to 96%), and shared common characteristics.^116,^ ^118,^ ^119,^ ^127,^ ^128,^ ^155^ Most were provided to adolescents or young adults and involved group counseling sessions with high contact times. As well, most interventions were for girls or women, and one was provided to men and another to men and women. The analytic samples ranged from 199 to 490 participants, and all reported statistically significant findings of reduced STI associated with intervention. Two of these six interventions were associated with reduced odds of STI infection of greater than 80 percent; both were conducted with adolescent girls, recruited based on their race/ethnicity and increased or high STI risk.^116,^ ^119^ The first of these two, the Project Image intervention for African American and Mexican American girls with a history of STI or abuse, involved multiple group and individual counseling sessions over the course of 1 year amounting to over 17 hours of contact time.^116^ The second intervention was for HIV prevention, and focused on sexually active adolescent African American girls at increased risk for STI.^119^ This was also a high-contact time intervention involving four 4-hour group counseling sessions over the course of one month. Project Image included motivational interviewing, and the HIV prevention intervention was based in social cognitive theory and theory of gender and power. Another intervention tested by Jemmott and colleagues^127^ that focused on Black and Hispanic adolescent girls was also statistically significant. Consisting of a single group counseling session (250 minutes) that included a video and games, it focused on skills development and was based on CBT therapeutic approaches, and was associated with 56 percent reduced odds of STI.^127^ An adaptation of this intervention was also effective when tested among adult African American women (ages 18–45); it had a similar effect size (52% reduced odds of STI).^128^ Another intervention for Mexican American and African American women that was not limited to adolescents also was associated with reducing the odds of STI by half at followup.^155^ This was also a high contact time intervention taking place over 2 months, and included individual and group counseling amounting to approximately 17 hours. Only one intervention among these studies with larger effect sizes focused on men. The Focus on the Future intervention for young adult African American men recently diagnosed with an STI involved a single individual counseling session and provision of a variety of condoms and lubricants (control condition received 12 free condoms).^118^ The intervention was conducted at an STI clinic and was provided by a trained layperson (peer counselor).

Eight studies with more modest estimates of effects,^105,^ ^107,^ ^122,^ ^129,^ ^145,^ ^156,^ ^158,^ ^164^ ranging from 47 to 15 percent reductions in the odds of STI, included three with statistically significant effects among people making visits to STI clinics.^145,^ ^156,^ ^158^ Two of these were large nonrandomized controlled trials evaluating low or moderate contact interventions for adult populations, mostly over the age of 25^145,^ ^156^ The low contact intervention for adults, Safe in the City, involved an STI clinic video intervention with educational pamphlets and condoms.^156^ The moderate contact time intervention for adults, VOICES/VOCES, was a single 45-minute group counseling session delivered in STI clinics.^145^ The third study with sufficient precision to establish effectiveness was an RCT of an intervention for young adult African American women.^158^ This intervention was two 4-hour group counseling sessions using CBT therapeutic approaches, conducted by health educators in a primary care setting over a 2-week period. The five remaining studies were not statistically significant, but effect sizes were similar. Two high contact time interventions, one for adolescent and young adult pregnant women^129^ and another for adolescent and young adult women seeking contraception,^107^ reported similar effect estimates and confidence intervals. The Centering Pregnancy Plus intervention (OR 0.72, 95% CI 0.38, 1.37) involved 10 group counseling sessions,^129^ and the other intervention for those seeking contraception included an individual counseling session and more than six followup phone calls (OR 0.72, 95% CI 0.35, 1.48).^107^ Two small trials conducted in Great Britain and published in 2016 were also not statistically precise, and evaluated lower contact approaches to STI prevention. One was a text message and email intervention for mixed-gender adolescents and young adult populations at high STI risk that involved 50 to 60 contacts over the course of a year (OR 0.57, 96% CI 0.24, 1.38).^122^ The other, Men’s Safer Sex, focused on men of any age making visits to an STI clinic and involved a single 10-minute visit to a website (OR 0.64, 95% CI 0.23, 1.80).^105^ A similar trial evaluated the electronic kiosk intervention for safer sex (e-KISS) for male and female adolescents and young adults making visits to a public STI clinic.^164^ The intervention offered one 20-minute session with a tailored-interactive computer-based intervention. Fewer cases of diagnosed or self-reported chlamydia cases occurred in the intervention group (12%) compared to the control group (20%) after three months of followup, but the difference was not statistically significant (OR 0.53, 95% CI 0.26, 1.08).^164^

The remaining studies reported similar STI incidence for the intervention and control groups or slightly higher STI incidence for intervention participants, and none approached statistical significance.^112,^ ^113,^ ^135,^ ^137,^ ^148,^ ^165^ The main behavioral study outcomes were also no different between groups for the studies that did not show differences in STI rates (discussed below). A tailored web-based intervention for adolescent and young adult women that involved moderate contact (~90 minutes) with the intervention platform over the course of 2 months was not effective.^148^ A large study (n=4,071) with brief individual counseling and HIV testing for a diverse population of young adult men and women visiting an STI clinic also was not effective,^137^ nor was a very small trial (n=87) of an intervention to prevent BV among WSW.^135^ A large study (n=1,010) of a video and survey intervention for a diverse population of men and women, adolescents, and adults conducted at an STI clinic did not prevent the incidence of STI.^113^ Another intervention study from the same team evaluating a high contact time intervention for adult men and women reported no difference in STI incidence between groups in the publication text, but did not provide details.^112^

The risk of bias rating (good vs. fair quality) was not associated with different intervention effects for STI in meta-regression (p=0.46) (data not shown). More recently published studies tended toward smaller effects than those published earlier, but there was not a statistically significant difference (p = 0.07). The six largest studies (n≥1000) also had smaller effects (p= 0.02) in meta-regression analysis. A statistically significant relationship was not observed, however, when looking at the linear relationship between study size and effect estimates (p=0.42). Statistical tests with Harbord’s modified and Peter’s tests also did not find a pattern of results suggesting the findings were driven by small study effects. However, there was heterogeneity in the populations enrolled where studies enrolling 1,000 or more participants tended to include broader general populations at lower STI risk across a range of ages, including both men and women, and to deliver individual rather than group focused interventions.

## Key Question 2 Do Behavioral Counseling Interventions Decrease Risky Sexual Behaviors or Increase Protective Behaviors That Can Reduce the Risk of STIs?

### Summary of Results

In total, 34 studies contributed evidence on the effectiveness of behavioral counseling interventions in changing a variety of sexual risk and protective behaviors. Eighteen trials reported only behavioral outcomes, and 21 reported STI and behavioral outcomes. Results were generally consistent across STI and behavioral outcomes for studies reporting both outcomes. In pooled analysis, statistically significant effects of interventions for improving condom use (k = 13; pooled OR 1.31, 95% CI 1.10, 1.56, I^2^ 40%) and for reducing unprotected intercourse (k=14; pooled MD −0.94, 95% CI 0-1.40, −0.48, I^2^ 16%) were found across studies with reasonably comparable measures to accommodate pooling. Similar to the studies reporting STI outcomes, nearly all of the included evidence for pooled analysis was from studies of people at increased risk for STI; one study of average-risk adolescents reported no difference in unprotected intercourse. Most interventions involved moderate or high contact times. Followup ranged from 3 to 14 months (mode = 12 months), and for the few studies reporting extended followup beyond a year, effects tended to diminish. Statistical heterogeneity was modest, but clinical heterogeneity was high due to the diverse populations and intervention approaches. Behavioral outcomes were not consistently reported, and measures were variable among those reporting. This limited our ability to combine studies and to explore and identify specific study or intervention characteristics associated with differences in intervention effects. Other behavioral outcomes, such as the number of sexual partners and sexual abstinence, were reported by fewer of the total included studies and tended to be consistent with effects seen for other outcomes.

### Detailed Results

#### Condom Use

Eighteen studies reported a variety of condom use measures (n = 9,205) (Appendix E Tables 5 and 6). The pooled effects in studies reporting dichotomous outcomes (k= 13, n = 5,253) and those reporting comparable continuous outcomes (k=7, n =2,920) were estimated separately (Table 6). One study, by Erhardt and colleagues,^102^ included female condom use, and the remainder reported male condom use only.

Table 6 Meta-Analysis Results for Outcome of Condom Use and Unprotected Intercourse Outcomes

Outcome No. studies (n randomized) | Type of outcome measure | Pooled analysis No. studies (n analyzed) | Effect Estimate | Pooled result (95% CI)^*^ | I^2^ % | Tau^2^ | Effect Range^†^ | Effect Median (IQR)^†^
Condom Use; All trials reporting condom use; 18 (9,205)^§^ | Dichotomous (e.g., consistent, at last sex) | 13 (5,253) | OR | 1.31 (1.10, 1.56) | 39.9 | 0.04 | 0.54 to 5.08 | 1.17 (0.87 to 1.58)
Condom Use; All trials reporting condom use; 18 (9,205)^§^ | Dichotomous (e.g., consistent, at last sex) | 13 (5,253) | ARD | -- | -- | -- | −6.50 to +26.60 | 2.00 (−2.00 to +12.00)
Condom Use; All trials reporting condom use; 18 (9,205)^§^ | Continuous (proportion of sexual intercourse with condom use) | 7 (2,920) | MD | 10.75 (1.01, 20.50) | 79.2 | 79.39 | −8.42 to 27.88 | 5.65 (0.23 to 8.00)
Condom Use; All trials reporting condom use; 18 (9,205)^§^ | Continuous (proportion of sexual intercourse with condom use) | 7 (1,914)^ǁ^ | SMD | 0.34 (0.06, 0.63) | 78.9 | 0.07 | −0.24 to 0.73 | 0.27 (0.05 to 0.37)
Unprotected Intercourse; All studies reporting unprotected intercourse; 21 (13,665)^¶^ | Continuous (e.g., number of unprotected sex acts/episodes/days | 14 (9,183) | SMD | −0.11 (−0.19, −0.03) | 58.8 | 0.01 | −0.71 to +0.25 | −0.05 (−0.20 to +0.04)
Unprotected Intercourse; All studies reporting unprotected intercourse; 21 (13,665)^¶^ | Continuous (e.g., number of unprotected sex acts/episodes/days | 14 (9,183) | MD | −0.94 (−1.40, −0.48) | 16.4 | 0.11 | −11.90 to +4.5 | −0.44 (−1.97 to 0.43)

* For analyses with <10 studies the REML method was used to calculate the CI.

† Range and median of effects for all study arms and timepoints, i.e., not limited to records in the meta-analysis

‡ Measures vary and include proportion condom used for sex acts, sex days, or sexual intercourse episodes across a range of time frames (30 days to 6 months).

§ Number of trials reporting the condom use outcomes does not add up to the total number of trials reporting any outcome because some trials did not provide data to calculate the effect for either dichotomous or continuous score.

ǁ MD and SMD analyses have same number of studies but differed by one study due to available statistical measures. Thus, the total number of participants differed.

¶ Number of trials reporting the unprotected intercourse outcomes does not add up to the total number of trials reporting any outcome because some trials reported only a dichotomous scale score and are not shown in this table

Abbreviations: ARD = absolute risk difference; CI = confidence interval; IQR = interquartile range; MD = mean difference between groups; OR = odds ratio; SMD = standardized mean difference (Hedges’ g).

Thirteen studies reported dichotomous condom-use outcomes. The combined effect across these studies suggested increased odds of condom use associated with intervention (OR 1.31, 95% CI 1.10, 1.56, I^2^ 40%) (Table 6 and Appendix G Figure 1). The percentage reporting any condom use ranged from 4 to 81 percent in the intervention groups, compared with 4 to 77 percent in the control groups, with absolute risk differences ranging from −7 to +27 percent. Seven studies reported a continuous condom-use measure comparing mean differences in the percentage of time condoms were used out of the total sexual acts, encounters, or days of sex. The interventions evaluated in these studies were associated with reports of condom use in just over 10 percent more of total sexual encounters, and statistically heterogeneity was fairly substantial (pooled MD 10.8, 95% CI 1.0, 20.5, I^2^ 79%).

Eight of the studies reporting condom use outcomes also reported STI incidence, and effects were consistent in terms of the statistical significance and effect direction reported in each study. Among the eleven studies that only reported behavioral outcomes, three reported statistically significant benefits of the intervention.^110,^ ^117,^ ^163^ One of these reported a continuous condom use measure defined as the reported number of times condoms were used during the previous 4 sexual acts.^117^ In the intervention group the mean (SD) was 3.4 (2.0) and in the control group it was 2.4 (1.8, p=0.05). The study, conducted in Portugal, evaluated a high-contact time intervention for adolescent and young adult women at high risk for STI that included six 120-minute group counseling and skill building sessions conducted by psychologists using CBT techniques. The Safe Sistah intervention also was associated with statistically significant increases in condom use, which was measured as the proportion of sexual episodes in which condoms were used.^110^ Safe Sistah, which was developed and evaluated in the United States, was an intervention for adult Black women conducted at a community-based health clinic that employed a single computer-based educational session of moderate duration (~88 minutes). The mean percent (SD) condom use percentages measured at 4-month followup were 59.6 (40.4) in the intervention group and 31.6 (34.6) in the control group (p=0.03). A similar intervention, Step by Step, for adolescent females recruited from family planning or community health clinics in the United States administered four computer sessions (~25 minutes each) followed by individual counseling sessions. The study reported a significant increase in consistent condom use for the intervention group (51%) compared with the control group (39%) at 12-month followup (p=0.02).^163^

#### Unprotected Intercourse

Twenty-one studies reported a measure of unprotected intercourse (n = 13,665). Of these, 14 reported the number of times participants engaged in unprotected sexual intercourse or intercourse without a condom over various time frames (e.g., past 30 days, past 3 months), with different degrees of specificity regarding the type of partner or sexual intercourse act. When combined to estimate an overall effect, there was a small but statistically significant difference between groups. Fewer unprotected intercourse occasions were reported among those assigned to the intervention conditions (pooled MD −0.94, 95% CI −1.40, −0.48, I^2^ 16%) (Table 6 and Appendix G Figure 2). Overall, findings for individual studies reporting this outcome were mostly consistent when results were compared for other outcomes, including STI. The exception was the Centering Pregnancy Plus intervention: STI rates were not statistically different, but the intervention was associated with fewer reported acts of unprotected intercourse at 12-month followup (mean [SD] 3.9 [6.5] in the intervention group, 5.3 [7.8] in the control group (p=0.04).^129^ Among studies that did not report STI outcomes, the Safe Sistah intervention, described above with the condom use results, also reported fewer unprotected acts of sexual intercourse at 4 months of followup.^110^

Two recent studies reported statistically significant differences in reported unprotected intercourse. A small study among adult males who mostly identified their sexual orientation as gay or bisexual evaluated reports of unprotected anal intercourse nine months after an intervention involving STI testing and counseling and ten individual therapy sessions. Fewer in the intervention group reported any unprotected anal intercourse (12%) compared to those in the control group (68%) (p<0.001).^162^ Differences in reports of unprotected intercourse were also seen in a trial testing a low-contact computer-based intervention that provided numerous emails with internet links to informational and motivational content. The intervention was tested with sexually active adolescent and young adults of any gender, most of whom identified as Black or Hispanic. At 3 months followup, fewer reported any unprotected intercourse in the intervention group (17%) compared with the control group (48%) (p<0.05).^166^

A trial testing Guy2Guy, a high-contact-time text-message intervention for adolescent cisgender males identifying as gay, bisexual or queer, had null findings for this outcome.^159^ Two newer studies with high-contact time also found no significant results with unprotected intercourse or condomless sex acts. One of these studies^160^ was conducted among adolescents who received ten 60-minute individual sessions and the other study^161^ administered three 2.5-hour group sessions among refugee and immigrant populations of adult Hispanic females.^162,^ ^166^ A trial conducted by Mittal and colleagues (2016)^140,^ ^142^ that evaluated the SUPPORT intervention—which provided three individual counseling sessions (2 to2.5 hours each) and five group counseling sessions (2 to2.5 hours each) to women with a history of intimate partner violence—found no group differences in episodes of unprotected sex, although results suggested a trend toward fewer unprotected episodes with nonsteady partners for intervention participants. An additional study published by Jemmott et al. (2005),^128^ which reported STI-prevention benefits associated with a high contact time group counseling intervention for African American and Latina adolescent girls, also reported on days of sex while high or on drugs and unprotected sex while high or on drugs. At 12 months of followup, there was no difference between groups in the number of days women had sex while high or on drugs (0.4 vs 0.6 days in the intervention and control groups, respectively), but those in the group intervention had lower mean reported days of unprotected sex while high or on drugs (0.1 vs 0.5 in the intervention and control groups, respectively, p=0.02).

#### Other Behavioral Outcomes

Studies reported a wide range of additional behavioral outcomes, detailed results are shown in Appendix E Tables 7 and 8.

##### Number of Sexual Partners

Ten studies compared intervention and control groups on different measures of participants’ reports of the number of sexual partners for recall periods ranging from 1 to 12 months. Dichotomous measures were reports of two or more sexual partners. Continuous measures were reported as the mean number of sexual partners or the absolute number of sexual partners. Four trials with statistically significant intervention benefits for STI, condom use, or unprotected intercourse also found reports of fewer sexual partners among intervention participants.^111,^ ^118,^ ^127,^ ^155,^ ^164^ Four of these trials tested interventions for adolescent and young adult single-gender populations (three for females,^127,^ ^155,^ ^164^ one for males^118^), and one was among mixed-sex/gender adults receiving outpatient psychiatric treatment.^111^ Four trials had null findings for the outcome, consistent with null findings for other reported outcomes.^112,^ ^113,^ ^122,^ ^144^

##### Abstinence

Trials of interventions that focused on younger populations also reported sexual abstinence outcomes and the initiation of new sexual partnerships. The HipTeens intervention evaluated in the study published by Morrison-Beedy and colleagues enrolled sexually active, predominantly African American, low-income adolescent females for a group counseling intervention.^144^ The trial did not report an intervention benefit for STI prevention, condom use, or reductions in unprotected intercourse, nor was there a difference in the number reporting any vaginal sex (protected or unprotected) at 12 months’ followup. An intervention effect on abstinence was observed at 6 months’ followup, where the percent reporting any episodes of vaginal sex was lower in the intervention group.^143^ The study also reported null effects for reports of abstaining from sex or avoiding drinking or drug use before sex as risk-reduction strategies. The Guy2Guy intervention for sexually experienced and unexperienced queer, bisexual, or gay cisgender adolescent males reported abstinence in the previous 90 days as a primary outcome, but did not find overall differences at 3 months of followup.^159^ Post hoc subgroup analyses indicated that participants who were already sexually experienced were less likely to report abstinence after participating in the intervention (aOR 0.48, 95% CI 0.23, 1.00, p<0.05), whereas there was no effect among not-yet sexually experienced individuals (OR 0.98, 95% CI 0.38, 2.53). Sexually experienced participants were, however, more likely than those in the control condition to have been tested for HIV (data not shown).

The HIV prevention intervention for adolescent African American girls at increased STI risk evaluated by DiClemente and colleagues (2004)^119^ found reduced STI infections and increased condom use (see above), and also was associated with a decline in reports of having a new vaginal sex partner in the past 30 days (OR 0.40, 95% CI 0.19, 0.82, p=0.01). A study enrolling mother-child dyads attending pediatric care visits also reported vaginal intercourse as a primary outcome. The intervention evaluated by Guilamo-Ramos and colleagues (2011)^125^ was designed to reduce sexual health risks in a population of African American and Latino adolescent girls and boys ages 11–14. Few of the adolescents in the mother-child dyads had ever had intercourse (6.4% reported vaginal sex). Mothers randomized to the moderate contact time intervention received a 30-minute individual counseling session, a program manual, and two followup phone calls. At followup (9 months) the adolescents with mothers assigned to the intervention were less likely to report having engaged in vaginal sexual intercourse (OR 0.24, 95% CI 0.11, 0.55).

##### Safer Sex Practices

A large cluster-randomized trial conducted in Australia, published by Sanci and colleagues (2015),^153^ randomized general medical practice clinicians and their 14- to 24-year-old patients to an intervention aimed at improving screening and motivational interviewing for adolescent health risk behaviors. A self-reported outcome assessing risk of STI defined as engagement in safe sexual behaviors to prevent STI (response options were never, rarely, sometimes, most of the time, always) was measured 12 months after the clinician intervention; it found no difference between groups (OR 0.79, 95% CI 0.51, 1.24).

Consistently null findings were reported in a trial of an educational materials intervention for mixed-gender populations of young adults in primary care conducted by Proude and colleagues (2004);^150^ null findings for condom use were consistent with null findings for participant reports of new sex partners in the previous 3 months.

Participants’ reports of having any casual sexual partners in the previous month were compared for a trial by Lewis and colleagues (2018)^132^ using low-intensity interventions with computer and text messaging to generate personalized feedback for young adult women and men. They included one intervention with feedback related to alcohol use and sexual risk and another without alcohol use content. Neither intervention was associated with a statistically significant lower relative risk of reporting casual partnerships, although there was a between-group difference suggesting lower odds of reporting any casual partners versus none in the intervention arm that did not incorporate alcohol-related risk-reduction content (OR 0.31, 95% CI 0.12, 0.79).

## Key Questions 1a and 2a Does the Effectiveness of Behavioral Counseling Interventions Differ for Subpopulations (e.g., by Age, STI History, Sexual Orientation, Gender, or Pregnancy Status)?

### Summary of Results

Rigorous tests of intervention effectiveness for different subpopulations within trials were not reported. One trial^156^ reported prespecified several exploratory subgroup comparisons but did not test for interactions or account for multiple comparisons, while other trials presented post hoc exploratory subgroup comparisons^159^ or secondary analyses on a subset of trial participants.^119^ Instead, most of the included evidence focused exclusively on a specific subpopulation defined by gender, age, sexual history, pregnancy status, and racial/ethnic identity. Some subpopulations were not well-represented in the body of evidence; for example, only two included studies recruited participants for interventions occurring during pregnancy. Many of the interventions were effective in the subpopulations for which they were designed and evaluated. For example, interventions designed for African American and Latina adolescents, adult minority women, and mixed-gender populations making visits to STI clinics were effective. Trials among men, adolescent boys, MSM, and average risk populations were not well-represented in the body of evidence, however, and when differences in effects were observed, other factors present could not be ruled out as the source of differential effects. We also explored differences in the pooled effect estimates for sets of studies defined by the study population and other characteristics using stratified meta-analysis and meta-regression. Meta-regression revealed a few subpopulations or study features statistically associated with intervention effectiveness. Isolating specific effects was hindered, however, by the presence of shared features among the most effective trials, such as group counseling interventions often being delivered to racial and ethnic minority women. Too few degrees of freedom and small numbers did not allow for more than one or two variables in meta-regression models, further limiting the disentanglement of subgroup effects.

### Detailed Results

Results from within-study group comparisons were reported by several studies, and while some were planned and sufficiently powered, such as the large study by Warner and colleagues (2008) testing the Safe in the City intervention, the stratified analyses were exploratory in nature, without correction for multiple testing or reporting of interaction effects. The results of within-study subgroup comparisons, meta-analysis and meta-regression exploration of differences in effects, and results for studies conducted among focused subpopulations are discussed below.

#### Age

The Warner study described above suggested reduced intervention effectiveness for participants younger than age 25, relative to those aged 25 and older. Three trials limited to adolescents reported STI outcomes eligible for meta-analysis (n =1,763).^116,^ ^119,^ ^127^ Statistically significant differences were observed in meta-regression (p=0.002) when comparing the studies focused on adolescents with the studies focused on all other age groups. The pooled effect for trials limited to adolescents is statistically significant in Figure 3 using the DL pooling method, but highly imprecise when estimated with the Knapp-Hartung correction, as shown in Table 5. Specifically, the pooled effect for trials limited to adolescents indicated a greater reduction in the odds of infection (OR 0.22, 95% CI 0.02, 2.30; k=3, n = 1,166, REML method with the Knapp-Hartung correction for small number of studies, Table 5) and a smaller and statistically significant effect for trials that were not limited to adolescents (OR 0.79, 95% CI 0.67,0.93; k=14, n=50,627, DL method). This result does not offer conclusive evidence that the difference is due only to the ages of the trial participants, however, since the precision and number of studies for estimating this effect difference for adolescents was low. Moreover, all three of the studies limited to adolescents were conducted among sexually active minority females at increased STI risk and involved high-contact time interventions provided in a group counseling format.^116,^ ^119,^ ^127^ It is not possible to determine the extent to which differences in effect estimates for this age group comparison can be attributed to the age category per se, or to a combination of other factors, but within-study comparisons suggest that some interventions may be more effective for adolescents. The Centering Pregnancy Plus intervention reported statistically significantly reduced odds of STI for adolescent participants (OR 0.37, 95% CI 0.17, 0.77), but not overall (OR 0.72, 95% CI 0.38, 1.36).^129^

#### Sex and Gender

One study fully characterized the gender of study participants, specifying that cisgender men were recruited.^159^ The majority of studies recruited women or females, most recruiting either heterosexual women or women reporting sex with men. Five studies focused only on males or men, whereas 20 focused on adolescent and adult women and 14 included both men and women. Larger effect estimates for STI prevention in trials limited to women suggested a greater intervention benefit, but formal testing with meta-regression did not find a statistically significant difference in intervention effectiveness for studies conducted only among women (k=11) (p=0.17). Larger effect sizes were observed for trials targeted to a single gender (only men or only women) (k=13) compared to those including both men and women (k=6), but the test for intervention effect differences for STI incidence in meta-regression did not meet the threshold for statistical significance (p=0.06). Studies focused on a single gender had many features in common, making it difficult to ascertain whether any one aspect could account for potentially larger effect sizes. Evidence from within study comparisons was mixed. For example, VOICES/VOCES—the single group-counseling session at an STI clinic for adults by Neumann and colleagues (2011)—reported a statistically significant effect of the intervention for STI prevention for women, but not for men. Conversely, the subgroup comparisons provided in the STI clinic Safe in the City intervention trial by Warner and colleagues (2008) showed an intervention effect for men but not for women.^156^ Intervention effects also varied for men and women in the e-KISS trial, and were suggestive of a stronger effect for men than for women on the prevention of incident STI.^164^

#### Sexual Orientation

Only 2 studies focused exclusively on MSM^159^ or WSW^135^ populations, and only a few other studies reported that more than ten percent of study participants were not heterosexual^113,^ ^122,^ ^137,^ ^150,^ ^156,^ ^162,^ ^164,^ ^166^. Most studies enrolled women who either identified as heterosexual or reported having intercourse with men.

The study among MSM was focused on adolescents that identified as gay, bisexual, or queer and did not enroll participants based on whether they had ever had sex (approximately half sexually inexperienced).^159^ The text message-based intervention did not have a statistically significant main effect on the main behavioral outcome, condomless sex, regardless of sexual experience.

One trial of a moderate contact individual counseling and testing intervention conducted with STI clinic attendees by Metsch et al. (2013)^137^ reported null findings overall, and in subgroup comparisons, there was some evidence of a potentially harmful effect for participating MSM; a statistically significant increase in STI was seen for the intervention group (OR 1.62, 95% CI 1.16, 2.26) in this subpopulation and the overall intervention effect was also in the direction of harm, (OR 1.12, 95% CI 0.92, 1.35).

#### History of Abuse

Two studies of interventions for adolescent girls^116,^ ^119^ and one for adult women^142^ considered the effects of abuse history on sexual health risks. A small study (n= 55) by Mittal and colleagues^142^ recruited adult women with a history of intimate partner abuse/violence for an intervention including individual and group counseling sessions (high contact time of 1,080 minutes). The study, which did not report STI or condom use outcomes, found that unprotected intercourse was not statistically different between groups, but means were lower in the intervention group. Improvements in self-esteem and generalized anxiety were associated with the intervention. The study by Champion and colleagues^116^ actively recruited girls with either STIs or abuse history for their Project Image intervention, and a majority of participants reported sexual, physical, and emotional abuse histories. The study reported STIs (chlamydia, gonorrhea) among those reporting a history of sexual abuse and those without. The overall effect of the intervention across all participants was beneficial for STI prevention (OR 0.04, 95% CI 0, 0.53, p=0.02). However, among those reporting a history of sexual abuse (n=241) more STI cases occurred in the intervention group than in the control group (15.4% vs. 9.3%, respectively) and there was not a statistically significant intervention effect (p = 0.16). Among those not reporting a history of sexual abuse, the intervention was associated with fewer STIs, similar to the overall effect (p=0.02). Finally, the study by DiClemente and colleagues^119^ reported a subanalysis of the intervention findings for adolescent African American girls reporting a history of gender-based violence. The intervention was effective overall and in this subpopulation for STI prevention (OR=0.47, 95% CI 0.25, 0.87), and also in increasing condom use.

#### Mental Health

The study by DiClemente and colleagues^119^ evaluating a group counseling intervention for adolescent African American girls reported a secondary subpopulation analysis among participants with depressive symptomatology at baseline. Higher reports of consistent condom use and reported condom use at last sex were associated with the intervention.

Two studies enrolled participants in treatment for mental health conditions. One intervention was tested among men with severe mental illness^108^ and another among men and women with alcohol or drug use in the previous year who were undergoing outpatient psychiatric treatment.^111^ Intervention participants were assigned to attend multiple group-counseling sessions. The intervention for men with severe mental illness found increased condom use (percent sexual acts using condoms) reported by intervention group participants at 14 months of followup, but the mean difference was small (6.4, 95% CI −8.0, 20.8) and not statistically different. The study by Carey and colleagues (2004) for men and women with a history of alcohol or drug use found reduced frequency of unprotected intercourse reported by intervention group participants in adjusted analyses (p=0.004), but a small absolute mean (SD) number with 7.2 (14.5) versus 8.0 (17.9).

#### Level of STI Risk

One of the studies conducted in general average-risk study populations reported in the text that they evaluated incident Chlamydia and found no difference between groups STI outcome.^149^ No other studies among average-risk populations reported STI outcomes. Within the increased risk populations evaluated, there was not a statistically significant difference in effect estimates for studies enrolling individuals at highest risk, having been recruited from an STI clinic or recent history of STI (p=0.18). Stratified within-study comparisons conducted in the nonrandomized Warner trial^156^ discussed above, however, suggested that individuals with an STI at the index visit may have obtained a more pronounced benefit from the brief Safe in the City video intervention.

#### Pregnancy

Only two studies eligible for inclusion in this review were conducted among pregnant individuals.^129,^ ^165^ Both reported STI outcomes, and neither found a preventive benefit. One small trial (n=50) with very low precision for estimated differences in STI outcomes enrolled pregnant women at risk for STI/HIV and alcohol or drug use and provided a moderate contact time computer-based intervention.^165^ A larger trial of the Centering Pregnancy Plus intervention was conducted with pregnant adolescents and young adults.^129^ At 12 months followup, STI incidence was not statistically different between groups, but was in the direction of a preventive benefit (OR 0.72, 95% CI 0.38, 1.36) and there were statistical differences in self-reported behavioral outcomes (condom use, unprotected intercourse). At extended followup, however, these differences were no longer present. The high contact time intervention tested in this trial consisted of an STI prevention component added to each of ten 120-minute group prenatal care sessions.

## Key Questions 1b and 2b Does the Effectiveness of Behavioral Counseling Interventions Differ by Intervention Characteristics (e.g., Intensity or Mode)?

As described above, the interventions tested in the trials varied considerably in their characteristics in terms of total contact time, duration of contact (single vs. multiple contacts over weeks or months), format (e.g., group counseling, individual counseling, in-person, telephone, text messages, computer-based), and behavioral change models and strategies. The heterogeneity of study populations and the interventions tested limited our ability to draw strong inferences about which components were associated with effectiveness. Most studies involved moderate or high contact times, and high contact times were more strongly associated with effectiveness for STI prevention in meta-regression (p=0.02) (Table 5). There was also evidence from meta-regression that interventions involving group counseling may be more effective than those without (p=0.02). There was, however, considerable correlation in the study populations and intervention characteristics, as well as among the different intervention components. For example, group counseling interventions tended to have the highest contact times and were more commonly conducted in interventions for adolescent girls and young adult women. There were also exceptions evident in the body of evidence, including evidence of a modest effect for STI prevention from a brief video intervention for men and women making STI clinic visits.^156^ A single individual counseling intervention with moderate contact time (45 minutes) also was effective for men and women making STI clinic visits.^145^ The most effective interventions were those involving high contact times and group counseling, but it can also be concluded that many types of behavioral counseling interventions can be effective for STI prevention. Exemplars of effective interventions for specific subpopulations are provided in Appendix F Table 1.

## Key Question 3 What Potential Harms Are Associated With Behavioral Counseling Interventions to Reduce STI Infections?

### Summary of Results

Few studies reported potential adverse consequences of the evaluated behavioral interventions to prevent STI, and no evidence of statistically significant intervention harms was identified.

Seven trials (n =3,458) reported potentially adverse consequences that might theoretically arise from the behavioral interventions evaluated (Table 7).^107,^ ^119,^ ^122,^ ^129,^ ^142,^ ^148,^ ^164^ A study conducted among adolescents and young adults (primarily females) that involved a text-messaging intervention reported three driver-caused road traffic accidents related to texting: two in the intervention group and one in the control group. The study was too small to permit estimation of the difference with any precision. No other studies relying on text-messaging interventions reported adverse events related to driving and texting.

Table 7 Results From Studies Reporting Intervention Harms

Author, year | Outcome | Outcome description | Recall period | Int arm | Group | F/U mos | IG n (%) or Mean (SD), n | CG n (%) or Mean (SD), n | Result (95% CI) | P-value
Berenson, 2012^107^ | Pregnancy | Pregnancy | 1 month | IG1 | Overall | 12 | 52/384 (13.5) | 48/388 (12.4) | OR: 1.11 (0.73 to 1.69)^*^ | 0.22
Berenson, 2012^107^ | Pregnancy | Pregnancy | 1 month | IG2 | Overall | 12 | 63/383 (16.4) | 48/388 (12.4) | OR: 1.39 (0.93 to 2.09)^*^ | 0.22
DiClemente, 2004^119^ | Pregnancy | Pregnancy | NR | IG1 | Overall | 6 | 8/226 (3.5) | 17/243 (7.0) | OR: 0.38 (0.15 to 0.36) | 0.04
DiClemente, 2004^119^ | Pregnancy | Pregnancy | NR | IG1 | Overall | 12 | 13/219 (5.9) | 20/241 (8.3) | OR: 0.53 (0.27 to 1.03) | 0.06
Kershaw, 2009^129^ | Pregnancy | Percent repeat pregnancy | 6 months | IG1 | Overall | 6 | 18/318 (5.7) | 51/394 (12.9) | OR: 0.49 (0.27 to 0.91) | 0.02
Kershaw, 2009^129^ | Pregnancy | Percent repeat pregnancy | 6 months | IG1 | Overall | 12 | 73/318 (23.0) | 102/394 (25.9) | OR: 0.95 (0.63 to 1.78) | 0.79
Peipert, 2008^148^ | Pregnancy | Unplanned pregnancy | 2 years | IG1 | Overall | 24 | 60/272 (22.1) | 62/270 (23.0) | OR: 0.95 (0.63 to 1.42)^*^ | NSD
Shafii, 2019^164^ | Pregnancy | Incident pregnancy | NA | IG1 | Overall | 3 | 5/112 (4.5) | 10/130 (7.7) | OR: 0.56 (0.19 to 1.69) | 0.10
Free, 2016^122^ | Intervention harm | Involved in a driver-caused road traffic accident as result of text messaging | 1 year | IG1 | Overall | 12 | 2/77 (2.6) | 1/80 (1.3) | OR: 2.11 (0.19 to 23.72)^*^ | 0.548
Mittal, 2017^142^ | Depression | Frequency of depressive symptoms during the preceding week | 1 week | IG1 | Overall | 3 | 3.6 (2.8), 19 | 2.6 (2.6), 21 | MeanDiff: 0.95 (−0.73 to 2.63)^*^ | NSD
Mittal, 2017^142^ | Generalized anxiety | Bothered by certain problems within the past 2 weeks | 2 weeks | IG1 | Overall | 3 | 7 (6.4), 19 | 10.2 (5), 21 | MeanDiff: −3.04 (−6.65 to 0.57)^*^ | NSD
Mittal, 2017^142^ | PTSD symptoms | Frequency of PTSD symptoms in the past 2 weeks | 1 week | IG1 | Overall | 3 | 21 (14), 19 | 23.4 (13), 21 | MeanDiff: −2.37 (−10.81 to 6.07)^*^ | NSD

* Calculated estimate from reported raw study data. P-values are based on statistical analyses reported in the published study results

Abbreviations: BL = baseline; Calc = calculated; CG = control group; Diff = difference; F/U = followup; IG = intervention group; Int = intervention; Mos = months; n = number of participants; NR = not reported; NSD = no significant difference; OR = odds ratio; SD = standard deviation.

### Detailed Results

Higher rates of unintended pregnancy could occur if female study participants used condoms for STI prevention but did not add a more effective method of birth control. Conversely, interventions could encourage consistent condom use and reduce unintended pregnancy rates for populations not using effective contraceptive methods. One study of young women who did not want to become pregnant in the following year reported higher proportions of pregnancies in the intervention group at 6 and 12 months, but the differences were not statistically significant.^107^ Two other studies reporting pregnancy outcomes found statistically significant lower pregnancy rates in the intervention groups among adolescents^119^ and postpartum women^129^ at 6 months, but the proportion with a pregnancy remained slightly lower and was no longer statistically different at 12 months. Finally, two studies found no differences in unplanned pregnancy at 2-year followup.^148,^ ^164^

Participation in an intervention could potentially impact mental health. Improvements could be seen, or the intervention could be harmful, if individuals had experienced sexual trauma or abuse, or the intervention raised awareness of difficult issues related to sexual health but did not offer adequate resources or support. Only one small pilot trial among women with a history of intimate partner violence reported mental health outcomes by study group. At 3 months of followup, the frequency of depressive symptoms in the prior week was similar between groups, and the frequency of PTSD symptoms was lower in the IG but not statistically different.