# Chapter 2 Methods

## Scope and Purpose

This systematic review will provide updated evidence regarding the effectiveness of behavioral counseling interventions to reduce risky sexual behavior and promote protective sexual behaviors in reducing STI incidence and/or related morbidity and mortality, as well as the potential harms associated with these interventions. The USPSTF will use this review to update its 2014 recommendation for primary care practices.^95^ This review includes all trials from the previous review^96^ that met current inclusion/exclusion criteria as well as newly identified studies.

## Key Questions and Analytic Framework

Using the USPSTF’s methods (detailed in Appendix A), we developed an analytic framework (Figure 1) and three Key Questions (KQs).

Figure 1 Analytic Framework

Abbreviation: STI = sexually transmitted infection.

Figure 1 is the analytic framework that depicts the three Key Questions to be addressed in the systematic review. The figure illustrates how behavioral counseling interventions to decrease risky sexual behaviors or increase protective behaviors, or both, reduce sexually transmitted infections (STI) and/or morbidity and mortality (Key Question 1). Additionally, the figure illustrates how behavioral counseling interventions lead to decreased risky sexual behaviors or increased protective behaviors that can reduce the risk of STI (Key Question 2) and any related harms associated with these interventions (Key Question 3).

The KQs are:

1. Do behavioral counseling interventions that aim to decrease risky sexual behaviors or increase protective behaviors, or both, reduce sexually transmitted infections (STIs) or related morbidity and mortality?
  a. Does the effectiveness of behavioral counseling interventions differ for subpopulations (e.g., defined by age, STI history, sexual orientation, gender, pregnancy status)?
  b. Does the effectiveness of behavioral counseling interventions differ by intervention characteristics (e.g., intensity or mode)?
2. Do behavioral counseling interventions decrease risky sexual behaviors or increase protective behaviors that can reduce the risk of STIs?
  a. Does the effectiveness of behavioral counseling interventions differ for subpopulations (e.g., defined by age, STI history, sexual orientation, gender, pregnancy status)?
  b. Does the effectiveness of behavioral counseling interventions differ by intervention characteristics (e.g., intensity or mode)?
3. What potential harms are associated with behavioral counseling interventions to reduce STI infections?

## Data Sources and Searches

In addition to considering all studies from the previous review for inclusion in the current review, we performed a comprehensive search of MEDLINE, PubMed (publisher-supplied only), PsycInfo, and the Cochrane Collaboration Registry of Controlled Trials for studies published between January 2013 and June 2018. This search was designed to partially overlap with the end search dates of the previous USPSTF commissioned review of this topic, and to identify new studies. Studies included in the previous USPSTF review were evaluated for inclusion against the inclusion and exclusion criteria for the current review. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A).

We also examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials (Appendix G). We imported the literature from these sources directly into EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

Two reviewers independently reviewed the titles and abstracts of all identified articles to determine whether studies met inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A Table 1). Two reviewers then independently evaluated the full-text article(s) of all potentially included studies against the complete inclusion and exclusion criteria. Disagreements regarding the abstract and/or full-text review were resolved by discussion and consultation with a third reviewer if necessary. Excluded studies and reasons for exclusion are listed in Appendix D.

We developed an a priori set of criteria for inclusion and exclusion of studies based on our understanding of the literature (Appendix A Table 1). For all KQs, included studies were required to target sexual behavior change for the prevention of STI. The review included studies conducted among adults and adolescents of any sexual orientation, including pregnant individuals. We included randomized controlled trials (RCTs) and nonrandomized controlled trials reporting STI or behavioral outcomes assessed at 3 months postbaseline or longer. Comparative effectiveness trials were excluded; included studies compared the intervention to attention control, minimal intervention, usual care, or no treatment (e.g., waitlist) conditions. Included interventions involved behavioral counseling, including but not limited to the provision of education, skills training, or guidance on how to change sexual behaviors to prevent STI. Studies aimed solely at targeting behavior change to prevent unintended pregnancy or change behaviors associated with risky sexual behavior (e.g., substance use disorder, interpersonal violence) were not included, nor were those assessing the impact of circumcision to prevent HIV/STI, involving HIV/STI testing only, or testing biomedical prevention interventions. Included studies were conducted in or recruited from primary care settings, which included family planning clinics, STI clinics, and behavioral/mental health clinics. Studies recruited from the community involving individual media-based interventions (computer, email, text messages) were considered for inclusion if all other inclusion criteria were met, and a comparable population, recruitment approach, and intervention would be feasible in a primary care setting. Studies involving recruitment through or conducted within pre-existing social networks (e.g., worksites, school, classrooms, social clubs, churches) were not included. Studies enrolling individuals living with HIV were included, unless the study was entirely limited to this population since interventions designed solely for HIV positive populations predominantly focus on preventing STI transmission and increasing HIV treatment adherence and tend to include provision of specialized clinical care. We also did not include studies limited to populations requiring complex, specialized interventions outside the scope of primary care to address their specific STI risk (e.g., HIV serodiscordant couples, commercial sex workers). The review was limited to studies conducted in countries categorized as “very high” on the Human Development Index (2016) published by the United Nations Development Programme.^97^

We limited our included studies to those published in English and deemed good- or fair-quality based on USPSTF quality rating standards.^98^ There were two minor but notable changes to the scope of this review relative to the previous 2014 review. The current review excluded studies providing only self-reported STI outcomes since laboratory-confirmed diagnosis of STI generally possible and commonly reported in studies evaluating behavioral interventions and is the key health outcome for determining effectiveness. In addition, in considering the medical and social context of STI risk and prevention, it was determined that studies conducted over 20 years ago may not be applicable to present-day United States population risks and prevention. Changes occurring in the past two decades include the development of effective prophylactic and treatment interventions for HIV, the resurgence and emergence of pathogens (e.g., syphilis, antibiotic-resistant gonorrhea), new contraceptive options (i.e., levenogestrel intrauterine contraception, implant, injectibles), and shifts in the social and sexual environment, including widespread use of social media and applications. Therefore, studies from the 2014 review that were published in 1999 or prior were excluded from the current review. The outcomes that were included in the review are fully listed in Appendix A Table 1.

## Quality Assessment and Data Abstraction

Two reviewers applied USPSTF design-specific criteria to assess the methodological quality of all eligible studies (Appendix A Table 2). We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were resolved by discussion or by a third reviewer and adjudicated as needed. Studies rated as poor quality were excluded from the review.

Good-quality RCTs were those that met all or nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study, followup was 90 percent or higher, assessment procedures were described and blinded if they involved direct interview, randomization methods were described, allocation was concealed). Fair-quality studies did not meet all criteria but did not have serious threats to their internal validity related to design, execution, or reporting. Intervention studies rated as poor quality generally had several important limitations, including at least one of the following risks of bias: very high attrition (generally > 40%); differential attrition between intervention arms (generally > 20%); lack of baseline comparability between groups without adjustment; or problematic issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting; inappropriate exclusion of participants from analyses; questionable validity of allocation or assessment procedures).

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), analytic methods, and results.

For KQ1, we abstracted reported data of STI incidence based on testing or biologic confirmation and related morbidity and mortality outcomes (e.g., STI-related cancers, reproductive complications, perinatal and infant morbidity), as well as mental health and quality of life outcomes. For KQ2, which examined the behavioral outcomes of sexual risk and protective behaviors, we abstracted changes in STI risk behaviors, such as the current number of sexual partners; instances of unprotected vaginal or anal intercourse or other sexual contact; sex with partners with high STI risk; sex while intoxicated with alcohol or other substances; and sex in exchange for money or drugs. Additionally, we abstracted data indicating changes in protective factors, including sexual abstinence; delayed initiation of intercourse or age of sexual debut; use of condoms or other barrier methods; or other changes in sexual behavior. For harms of these behavioral counseling interventions we abstracted data indicating possible paradoxical effects; health care avoidance; psychological harms such as anxiety, shame, guilt, or stigma; and unintended or unwanted pregnancy.

## Data Synthesis and Analysis

We synthesized data separately for each KQ and provided tables describing the study results for all included outcomes, with stratification by intervention and study population characteristics. Narrative summary and summary tables were used to describe important features of the included evidence, including study design and setting, interval validity, and important characteristics about patients and interventions. Based on a priori plans to evaluate differences in intervention effects by age, we present data tables for studies focused on adolescent and young adult populations separately from those focused primarily on adult populations. The included studies varied in the inclusion criteria used and the ages of participants recruited. The age categories used in this review were defined to represent the ages of the included populations as accurately as possible, but there is some overlap in the age ranges and included in each of the review age categories. The adolescent age category includes studies limited to participants ages 12 to 19 years. The combined adolescent and young adult age category applied to studies enrolling adolescents and adults that reported a mean age of the included population of <25 years. The young adult category includes studies with eligibility criteria limited to young adults (e.g., 18–25 years) reporting a study population mean age <25 years. The adult age category includes a mix of studies including those limited to adults ages 18 years and older, as well as studies with participants of any age, including adolescents, having a study population mean age ≥25 years. We abstracted within study age-specific subgroup analyses when available, regardless of the subgroup comparison methods (e.g., a priori hypotheses, statistical power).

Studies reporting diagnosed STIs were included for KQ1. The outcomes were based on laboratory-confirmed clinical tests that were conducted in the trial, recorded in the medical records of study participants, found in public health surveillance registries, or drawn from all of these sources. A few studies reported incidence of a specific STI (e.g., BV, chlamydia, hrHPV), while others considered intervention effects on the diagnosis of any STI or a specific subset (e.g., chlamydia and gonorrhea). For meta-analysis, we combined these outcomes, considering the effects of the interventions on the acquisition of any STI in the followup period. The followup periods ranged from 3 to 24 months, and we selected the longest time point or that closest to 12 months when several time points were reported.

We computed random-effects models using the DerSimonian and Laird (DL) method. For analyses with fewer than 10 trials and with substantial statistical heterogeneity (I^2^=50% and higher), we ran restricted maximum likelihood (REML) models with the Knapp-Hartung correction for small samples. The DL method tends to underestimate the width of the 95% CI interval when the number of studies is small or statistical heterogeneity is high (and I^2^ were typically near or above 50% in this review).^99^ Our meta-analysis summary tables reflect the results of the REML correction method. Finally, for outcomes with 10 or more trials in the meta-analysis, we generated funnel plots and ran regression tests (e.g., Egger, Peters, or Harbord’s modified test) to explore small-study effects and potential publication bias.^100,^ ^101^

We conducted meta-analyses of STI incidence, condom use, and unprotected intercourse outcomes. Diagnosis of STI was the primary outcome for this review. For studies that reported STI outcomes, findings for behavioral outcomes were examined to assess whether they contradicted or agreed with STI results within the study. A pooled odds ratio (OR) was used to analyze the average effect of the interventions on STI incidence. We included adjusted study-reported ORs in meta-analysis if they were reported, and calculated ORs based on the reported proportion of participants with an STI in each group if adjusted differences were not reported or results were presented in a format that could not be combined with the outcomes available in the included studies (e.g., hazard ratios).^100,^ ^101^ Additionally, we conducted meta-regression and stratified analyses to explore intervention, population, and study characteristics that might explain heterogeneity in the effects observed in the included evidence.^99^ For these comparisons, we examined the following as potential effect modifiers: study quality (good vs. fair), publication year, country (United States vs. other), recruitment approach (primary care-based, broad media-based recruitment, or other), whether the intervention was conducted in an STI clinic, whether the study targeted a highest STI risk group defined by history or STI or recruitment at an STI clinic, whether the study was limited to a single sex or gender, study age populations (adolescent only vs. others, and the 4-level age group categorization of adolescent only, combined adolescents and young adults, young adults, adults), estimated minutes of contact with the intervention (as a continuous variable and also grouped into low contact (<30 minutes), moderate contact (30–120 minutes), and high contact (>120 minutes), group vs. individual counseling sessions, mode of intervention (e.g., technology-based only vs. others), number of intervention components (single vs. multiple), whether the intervention was delivered by a health care professional (i.e., nurse, physician, social worker, psychologist, mental health specialist), and type of control group (attention control, minimal intervention, or usual care/none/waitlist).

Condom use and unprotected outcomes were reported using a variety of measures. We conducted one pooled odds ratio (for binary data) for condom use measures, selecting any of the following available measures in order of preference: consistent condom use (variably defined, e.g., “percent consistent condom use,” “percent consistent condom use for every vaginal sex act in past 30 days”), condom use at last intercourse, any condom use, and condom used at first intercourse with new partners. Female condom use was included for this outcome and was reported in one trial.^102^ For continuous outcomes, we analyzed the effect sizes two ways: 1) weighted mean difference (MD) of percentage or proportion of sex acts using a condom or of unprotected sex acts between intervention and control, and 2) standardized mean difference (Hedges’ g) of sex acts using a condom or of unprotected sex acts, based on the differences in change between groups from baseline to followup.

After synthesizing the evidence, we created an implementation table according to Agency for Healthcare Research and Quality (AHRQ) specifications that provides examples and features of selected effective interventions identified in this review.

We used Stata version 15.1 (StataCorp LP, College Station, TX) for all analyses. All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less. The data on study numbers reported throughout this report are n randomized in the case of randomized controlled trials and the n allocated to the study conditions unless otherwise indicated.

## Grading the Strength of the Body of Evidence

The strength of the overall body of evidence for each KQ was graded using an adaptation of the Evidence-based Practice Center approach,^103^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^104^ This adaptation explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations, risk of bias). We do not evaluate the fifth domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

The overall strength of evidence was graded as “high,” “moderate,” “low,” or “insufficient.” “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft Research Plan for this review was posted for public comment on the USPSTF Website from April 19, 2018, to May 15, 2018. In response to comments, the USPSTF revised the scope of the review to exclude studies solely enrolling HIV positive participants (studies including a mix of participants whose HIV infection status was negative, positive or unknown were included in the review). In addition, the USPSTF expanded the list of STIs to include the hepatitis C virus and Zika virus. The USPSTF made other minor changes to clarify the scope and intention of the review. Some commenters requested changes outside of the scope of the USPSTF, such as political and social policy approaches to STI prevention, including community-level interventions; the USPSTF made no changes in response to these comments. A final research plan was posted on the USPSTF’s Web site on August 23, 2018.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate. Additionally, a draft of this report was posted for public comment on the USPSTF Web site from December 17, 2019 through January 21, 2020. Few comments were received during this public comment period; minor clarifications and editorial changes were made to the report based on these comments, but no changes were made to the included evidence or to our conclusions.

## USPSTF Involvement

We worked with four USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and Key Questions. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.