# Appendix H Ongoing Studies

Trial identifier | Study name | Location | Participants n | Intervention | Relevant outcome measures | Status 2019
NCT03826342 | Technology-Based Intervention for Reducing Sexually Transmitted Infections and Substance Use During Pregnancy | U.S. | NA | Health Check-up for Expectant Moms (HCEM), a computer-delivered screening and brief intervention (SBI) | Number of unprotected sexual occasions | Not yet recruiting
NCT03736876 | About Us: A Healthy Relationships Program for Vulnerable Youth | U.S. | NA | 10 lessons (2 that are between 30-45 minutes long 8 that are 50 minutes long) that blend group-based activities with online activities implemented in a small group format | Rates of vaginal or anal sex without condoms | Recruiting
NCT02965014 | Young Women-Focused HIV Prevention: Seek & Test in North Carolina (NC) Clinics | U.S. | 700 | HIV counseling, testing, a two-session face-to-face intervention. The face-to-face sessions include information addressing the intersection of substance use, sexual risk, and violence through skill building, role-play, and rehearsal. | Condomless sex, number of sex partners, frequency of substance use | Recruiting
NCT03408743 | Engineering an Online STI Prevention Program: CSE2 | U.S. | 22337 | Online intervention | Unprotected sex behavior at most recent sex | Active, not recruiting
NCT03666247 | Mobile Messaging Intervention to Present New HIV Prevention Options for MSM | U.S. | 1,206 | Personalized mobile messaging platform; free condoms, lube, and HIV/STI testing kits | Change in condom use compliance, change in condom use, change in STI testing | Recruiting
NCT03167606 (https://clinicaltrials.gov/show/NCT03167606) | A Pragmatic Clinical Trial of MyPEEPS Mobile to Improve HIV Prevention Behaviors in Diverse Adolescent MSM | U.S. | 700 | Mobile technology to deliver HIV prevention information specifically developed for at-risk YMSM | Change in male-male sexual risk (total number of sex partners and condomless anal sex partners, frequencies of condomless sex acts (anal or oral), sex (anal or oral) with or without condoms under the influence of drugs/alcohol, unprotected anal intercourse under the influence of alcohol/drugs) | Recruiting
NCT02993185 (https://clinicaltrials.gov/show/NCT02993185) | An Integrated Group-Individual Curriculum to Prevent Teen Pregnancy | U.S. | 2,100 | Your Move (YM), an interactive sex education intervention. Seven 75-minute sessions, and each session contains 60 minutes of facilitator-led discussion, video clips, activities, and games as well as 15 minutes of “personal reflection” time during which girls practice the decision-making skills they have learned. | Number of sexual partners for vaginal, oral, or anal sex intercourse; Number of incidents of unprotected vaginal, oral, or anal sex; Condom errors or failure | Recruiting
NCT03284541 | A New Approach to Integrating Primary and Secondary HIV Prevention in Young Male Couples | U.S. | 400 | 2GETHER is an HIV prevention and relationship education program designed for young male couples. 2GETHER consists of 4 sessions (2 group sessions, 2 individualized couple session) administered over the course of 1 month (1 session per week). Group sessions focus on developing skills related to sexual health and relationship functioning, including HIV prevention in couples, communication skills, coping skills, problem-solving and acceptance. Individualized couple sessions focus on implementation of skills specific to the needs of each couple. | Condomless anal sex, occurrence of STIs | Active, not yet recruiting
NCT03765255 (https://clinicaltrials.gov/show/NCT03765255) | Personal Responsibility Education Program Innovative Strategies: Digital Initiative for Youth | U.S. | 1360 | 6 hours of in-person sexual health and adolescent development education with an app that includes a resource locator, text message reminders (for one month), goal setting, and other resources. | Condom/contraceptive use or no sex in the last 3 months; number of sexual partners in the past 3 months | Recruiting
NCT03465852 (https://clinicaltrials.gov/show/NCT03465852) | HIV Prevention Among Latina Transgender Women Who Have Sex with Men: Evaluation of a Locally Developed Intervention | U.S. | 140 | Two 4-hour group sessions over a period of two weeks to groups of about 10 participants | Consistent condom use | Active, not yet recruiting
NCT02513225 (https://clinicaltrials.gov/show/NCT02513225) | Randomized Controlled Trial of an Adapted STD Screening and Risk Reduction Intervention | U.S. | 350 | Project EMPWR; comprised of 2 sessions delivered approximately 7-10 days apart by a trained Apache paraprofessional interventionist. Curriculum will include information regarding personal risk factors for STDs and developing an achievable personalized risk-reduction plan that emphasizes individual and community-based strengths and resources. STD testing will be offered. | Condom use | Recruiting
HYPERLINK “https://clinicaltrials.gov/show/NCT03009539” \o “Current version of study NCT03009539 on ClinicalTrials.gov” NCT03009539 | Evaluating the Effectiveness of an eHealth EBI for Latino Youth in Primary Care | U.S. | 456 | eHealth Familias Unidas (an adaptation of the face-to-face version); aims to prevent drug use, sexual risk behaviors, and STIs by improving family functioning; a multi-level intervention that targets risk and protective factors at the multiple systems affecting the youth and youths’ family. Consists of 12 sessions: eight (12 - 15 minute) “mock” parent sessions in Spanish and four (30 - 45 minute) online family sessions delivered in either Spanish and/or English. | Unprotected sexual behavior; STI incidence | Recruiting