# Appendix G Figures

Appendix G Figure 1 Condom Use: Pooled Results

Confidence intervals for the pooled estimates in this forest plot were calculated with the Dersimonian and Laird method, thus subgroup effects based on few studies may overestimate precision

* Study participants ranged in age from 12 to 19 years

† Study participants ranged in age from 12 to 25 or study included adolescents and adults with population mean age < 25 years

‡ Study participants ranged in age from 18 to 25 only or study enrolled adults of all ages with population mean age <25 years

§ Only trial reported female condom use; trial reported “borderline statistical significance (all women: p=0.06; at-risk women: p=0.10)

ǁ Study participants ages 18 and older or enrolled broad age range population with mean age ≥25 years

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; Mo = month; n = number of observations; NR = not reported; OR = odds ratio.

Appendix G Figure 1 displays a forest plot of the effect of 13 behavioral intervention trials for condom use. The overall pooled effect suggested increased odds of condom use associated with intervention (OR 1.31, 95% CI, 1.10 to 1.56) compared with the control group.

Appendix G Figure 2 Unprotected Intercourse: Pooled Results

Confidence intervals for the pooled estimates in this forest plot were calculated with the Dersimonian and Laird method, thus subgroup effects based on few studies may overestimate precision

* Adolescents: Study participants ranged in age from 12 to 19 years

† Adolescents/Young adults: Study participants ranged in age from 12 to 25 or study included adolescents and adults with population mean age < 25 years

‡ Young adults: Study participants ranged in age from 18 to 25 only or study enrolled adults of all ages with population mean age <25 years

§ Adults: Study participants ages 18 and older or enrolled broad age range population with mean age ≥25 years

ǁ Trial reported GEE with group x time interaction for non-normal outcome, p=0.004; effect size from mean differences are plotted

¶ Trial reported a trend of unprotected intercourse decreasing, p=0.098; forest plot with mean difference is presented as significant

Abbreviations: CG = control group; CI = confidence interval; Diff. = difference; IG = intervention group; Mo = month; n = number of observations; NR = not reported; OR = odds ratio; SD = standard deviation; UAI = unprotected anal intercourse UI = unprotected intercourse; UVI = unprotected vaginal intercourse.

Appendix G Figure 2 displays a forest plot of the effect of 14 behavioral intervention trials for unprotected intercourse. The pooled mean difference in number of times of unprotected intercourse was -0.94 (95% CI, -1.40 to -0.48) fewer occasions in the intervention group vs. control group.