# Appendix F Implementation Table

Appendix F Table 1 Behavioral Intervention Implementation Table: Summary and Examples of Included Interventions

Primary Population | Individuals at increased risk for STI based on infection history, sexual risk behaviors, or high STI prevalence subpopulation
Primary Outcomes | STI infection, condom use, unprotected intercourse, number of sexual partners
Study Findings | Behavioral counseling interventions were generally consistent in reducing incident STI across a range of study populations, most at increased risk due to their STI history or attendance at STI clinics, sexual behaviors, or having sociodemographic characteristics associated with higher STI prevalence (E.g., adolescents, young adults, racial and ethnic minorities in low-resource communities). Increased condom use and reduced unprotected sex were also associated with behavioral interventions to prevent STI.
Behavior change goals and techniques | A variety of therapeutic approaches (I.e., Cognitive Behavioral Therapy, Motivational Interviewing, family therapy) and theoretical models of behavior change (e.g., Social Cognitive Theory, AIDS Risk Reduction Model, Information-Behavior-Motivation Model, Theory of Gender and Power) were used in the included interventions. Interventions often provided information, addressed condom use and negotiation skills, evaluated and aimed to change risk perceptions, stage of change, and motivations, including some that were tailored to the individual.
Interventions contact time and duration | The most effective interventions required over 2 hours of participant time. A few studies involving low (<30 minutes) or moderate (30-120 minutes) contact times reported benefits, but evidence was more limited. Interventions commonly involved multiple contacts (over a few weeks or an entire year), and a few involving a single encounter of low, moderate or high contact time were also effective.
Settings of Studies | Many studies took place in primary care settings, including women’s health and family planning clinics. Several were conducted in STI clinics.
To Whom is Intervention Targeted? | Most of the effective interventions were targeted to populations at increased STI risk, including some at especially high risk based on recent STI or STI clinic visits. Much of the available evidence is for interventions to prevent STI among adolescent girls and women. Fewer of the effectiveness studies from the past 20 years that were included in this review focused just on men or on mixed gender populations, and evidence of a benefit among those was less commonly found.
| Intervention Mode^*^
INTERVENTION PARTICIPANTS AT RISK FOR STI | Group counseling (group only or group + individual) | Individual counseling | Media-based (e.g., computer, video, text message)
Mode and intensity of delivery | Group counseling interventions were conducted in-person with trained facilitators. Additional individual counseling sessions were also sometimes included.; Most interventions with group counseling involved total contact times of more than 120 minutes and multiple sessions over 1-12 months.; Group counseling interventions often focused on specific demographic groups defined by age range and/or race/ethnicity. | In person, individual counseling sessions were with a mental health professional, counselor, or trained layperson.; Most involved > 30 minutes of total contact time and were often provided in a single session. | Media-based interventions did not include in-person counseling. Several involved one or more interactive computer sessions; others involved viewing a video or receiving emails or mobile phone text messages.; Approximately half of media-only interventions involved total contact times of 30-90 minutes; others involved < 30 minutes. Interventions involving video or computer interaction entailed fewer sessions than those involving repeated text or emails over many months.
Interventions included in meta-analysis of STI prevention efficacy | Champion^†^, DiClemente^†^, Jemmott 2005^†^, Jemmott 2007^†,ǂ^, Kershaw, Wingood^†^, Shain^†^, Neumann^†^ | Berenson, Marazzo, Crosby^†^, Metsch, Jemmott 2007^†,ǂ^ | Free, Peipert, Carey 2015, Bailey, Warner^†^‖, Shafii, Tzilos Wernette
Examples intervention materials ^§^ | https://effectiveinterventions.cdc.gov/home/interventions-previously-supported-by-cdc/sista; https://www.etr.org/ebi/programs/be-proud-be-responsible/; https://www.cdc.gov/hiv/pdf/research/interventionresearch/compendium/rr/cdc-hiv-horizons-best-rr.pdf; https://www.cdc.gov/hiv/pdf/research/interventionresearch/compendium/cdc-hiv-VOICES_VOCES_BEST_RR.pdf | https://www.cdc.gov/hiv/pdf/research/interventionresearch/compendium/rr/cdc-hiv-focus_on_the_future_best_rr.pdf; https://www.cdc.gov/hiv/pdf/research/interventionresearch/compendium/rr/cdc-hiv-Sister_to_Sister_BEST_RR.pdf | https://www.cdc.gov/std/safe-in-the-city/default.htm
Evidence of effect modification | There is evidence that interventions with group counseling and with higher contact times had larger preventive effects for STI outcomes, but these intervention features were correlated and unclear what accounts for the effect.
Comparison group | Attention control and minimal intervention (to address other health risk behaviors such as nutrition) most common. Usual care, waitlist, and no intervention also used.
Interventionist and Training Required | Trained clinical health professionals such as nurses, physicians, or psychologists conducted nearly one-third of the interventions evaluated, the remainder were with research staff, peer educators, or health educators, often matched to race/ethnicity, age and other characteristics of target population.
Reported Intervention Adherence | Relatively high adherence with most studies reporting more than three-quarters of the intervention participants completing the full intervention. Participation rates tended to be slightly lower for less intensive interventions.

* Most intensive intervention component if multiple modes used (e.g., group counseling + video).

† Intervention tested in the study was associated with a statistically significant reduction in STI incidence.

ǂ Two different intervention modalities were associated with reduced STI incidence in this study.

§ Materials for practice were identified by examining published studies and public resources (e.g., Centers for Disease Control and Prevention. An extensive catalogue of behavioral interventions for different at-risk populations are available online at https://www.cdc.gov/hiv/research/interventionresearch/compendium/rr/characteristics.html