# Appendix E Evidence Tables

Appendix E Table 1 Intervention Characteristics: Adolescent and Young Adults

Appendix E Table 2 Intervention Characteristics: Adults*

Appendix E Table 3 STI Infection Results: Adolescents and Young Adults

Appendix E Table 4 STI Infection Results: Adults*

Appendix E Table 5 Condom Use and Unprotected Sexual Activity: Adolescents and Young Adults

Appendix E Table 6 Condom Use and Unprotected Sexual Activity: Adults*

Appendix E Table 7 Other Sexual Behaviors: Adolescents and Young Adults

Appendix E Table 8 Other Sexual Behaviors: Adults*

Appendix E Table 9 Detailed Intervention Descriptions

Appendix E Table 10 Overview of Intervention Components