# Appendix D Excluded Studies

Reason for Exclusion^*^
E1. Relevance: Not applicable/relevant to key question
E2. Design (e.g., observational studies, comparative effectiveness trials without control group); E2a. Not primary data (e.g., editorials, narrative reviews)
E3. Setting: Otherwise outside of scope (e.g., emergency departments, research laboratories, school classrooms, worksites, inpatient/residential departments); E3a. Interventions not linked to healthcare excluded at full text (except online only)
E4. Population: Otherwise outside of scope (e.g., serodiscordant couples, commercial sex workers)
E5. Intervention (e.g., STI testing only, sexual abuse prevention, cash and reward-based incentives, PrEP or vaccine only)
E6. Comparator (e.g., comparative effectiveness)
E7. Outcomes: No relevant outcomes (e.g., knowledge of HIV/STI risk, knowledge of protective behaviors, risk perception); E7a. Self-reported STI outcomes (KQ1)
E8. Study Quality: Poor
E9. Publication type: Abstract-only, Non-English publication
E10. Country: Countries with an HDI other than “Very High”
E11. Publication Date: Published before 2000
E12. Abstract only

* Assigned at full-text phase

Code | Reference
E7 | Albarracin, D, Wilson, K, . A meta-intervention to increase completion of an HIV-prevention intervention: Results from a randomized controlled trial in the state of Florida. J Consult Clin Psychol. 84(12): 1052–1065. 2016.27786499 27786499
E3a | Amirkhanian, YA, Kelly, JA, . Effects of a social network HIV/STD prevention intervention for MSM in Russia and Hungary: a randomized controlled trial. AIDS. 29(5): 583–93. 2015. 10.1097/QAD.0000000000000558 25565495
E6 | Anderson, Mollie Blair. The Condom Carnival: Assessment of a novel group intervention aimed to decrease sexual risk and increase condom use among college students. Dissertation Abstracts International: Section B: The Sciences and Engineering. 78(8-B(E)): No Pagination Specified. 2018.
E7 | Archibald, CM, Newman, D. Pilot Testing HIV Prevention in an Afro Caribbean Faith-Based Community. ABNF Journal. 26(2): 43–9. 2015. PMID:26197635
E6 | Arnold, EA, Kegeles, SM, . A Randomized Controlled Trial to Reduce HIV-Related Risk in African American Men Who Have Sex with Men and Women: the Bruthas Project. Prevention Science. 20(1): 115–125. 2019. 10.1007/s11121-018-0965-7 30478804
E2a | Arnold, EA, Operario, D, . The Development of a Counseling-Based HIV Prevention Intervention for African American Men Who Have Sex With Men and Women: The Bruthas Project. AIDS Educ Prev. 27(6): 505–21. 2015. 10.1521/aeap.2015.27.6.505 26595264
E3 | Bannink, R, Broeren, S, . Effectiveness of a Web-based tailored intervention (E-health4Uth) and consultation to promote adolescents’ health: randomized controlled trial. J Med Internet Res. 16(5): e143. 2014. 10.2196/jmir.3163 24878521
E3a | Barbee, AP, Cunningham, MR, . Impact of Two Adolescent Pregnancy Prevention Interventions on Risky Sexual Behavior: A Three-Arm Cluster Randomized Control Trial. Am J Public Health. 106(S1): S85–s90. 2016. 10.2105/ajph.2016.303429 27689500
E3 | Barker, DH, Hadley, W, . Evaluating the Role of Family Context Within a Randomized Adolescent HIV-Risk Prevention Trial. AIDS Behav. 23(5): 1195–1209. 2019. 10.1007/s10461-019-02400-3 30701390
E2a | Bauermeister, J, Sullivan, PS, . Reducing HIV Vulnerability Through a Multilevel Life Skills Intervention for Adolescent Men (The iREACH Project): Protocol for a Randomized Controlled Trial. JMIR Res Protoc. 7(7): e10174. 2018. 10.2196/10174 29991470
E7 | Bodin, M, Tyden, T, . Can Reproductive Life Plan-based counselling increase men’s fertility awareness?. Ups J Med Sci. 123(4): 255–263. 2018. 10.1080/03009734.2018.1541948 30541376
E3a | Boekeloo, B, Geiger, T, . Evaluation of a socio-cultural intervention to reduce unprotected sex for HIV among African American/Black women. AIDS Behav. 19(10): 1752–62. 2015. 10.1007/s10461-015-1004-3 25645327
E7 | Booth, BM, Wright, PB, . Trajectory of substance use after an HIV risk reduction intervention. Am J Drug Alcohol Abuse. 41(4): 345–52. 2015. 10.3109/00952990.2015.1043437 26035094
E8 | Boman, J, Lindqvist, H, . Brief manual-based single-session Motivational Interviewing for reducing high-risk sexual behaviour in women - an evaluation. Int J STD AIDS. 29(4): 396–403. 2018. 10.1177/0956462417729308 28920542
E7 | Brawner, BM, Jemmott, LS, . Project GOLD: A pilot randomized controlled trial of a novel psychoeducational HIV/STI prevention intervention for heterosexually-active black youth. Res Nurs Health. 42(1): 8–28. 2019. 10.1002/nur.21930 30730043
E6 | Brown, JL, Sales, JM, . Added benefits: reduced depressive symptom levels among African-American female adolescents participating in an HIV prevention intervention. J Behav Med. 37(5): 912–20. 2014. 10.1007/s10865-013-9551-4 24366521
E3 | Brown, LK, Hadley, W, . Project STYLE: a multisite RCT for HIV prevention among youths in mental health treatment. Psychiatr Serv. 65(3): 338–44. 2014. 10.1176/appi.ps.201300095 24382603
E2a | Browne, FA, Wechsberg, WM, . mHealth versus face-to-face: study protocol for a randomized trial to test a gender-focused intervention for young African American women at risk for HIV in North Carolina. BMC Public Health. 18(1): 982. 2018. 10.1186/s12889-018-5796-8 30081868
E6 | Bryan, Ad, Magnan, Re, . Moderation of alcohol-related sexual risk reduction intervention with adolescents: the role of neurocognitive and genetic factors. Alcohol Alcohol. 50: i37. 2015. 10.1093/alcalc/agv079.07
E3 | Bull, S, Devine, S, . Text Messaging, Teen Outreach Program, and Sexual Health Behavior: A Cluster Randomized Trial.[Erratum appears in Am J Public Health. 2016 Dec;106(12):e14; PMID: 27831783]. Am J Public Health. 106(S1): S117–S124. 2016.27689478
E10 | Castillo-Arcos Ldel, C, Benavides-Torres, RA, . The effect of an Internet-based intervention designed to reduce HIV/AIDS sexual risk among Mexican adolescents. AIDS Care. 28(2): 191–6. 2016. 10.1080/09540121.2015.1073663 26301864
E2 | Champion, JD, Young, C, . Substantiating the need for primary care-based sexual health promotion interventions for ethnic minority adolescent women experiencing health disparities. J Am Assoc Nurse Pract. 28(9): 487–92. 2016. 10.1002/2327-6924.12346 26887630
E7 | Chandler, R, Ross, H, . The HIP LADIES: A Pilot Health Improvement Project for HIV Prevention in Black College Women. J Assoc Nurses AIDS Care. 30(4): 474–487. 2019. 10.1097/jnc.0000000000000058 31241511
E1 | Charron-Prochownik, D, Sereika, SM, . Long-term effects of the booster-enhanced READY-Girls preconception counseling program on intentions and behaviors for family planning in teens with diabetes. Diabetes Care. 36(12): 3870–4. 2013. 10.2337/dc13-0355 24130343
E12 | Cherian, Av, Lasopa, So, . Reductions in high risk sexual behavior among depressed and non-depressed women in the community participating peer delivered randomized controlled field trial. Comprehensive psychiatry. 54(8): e18. 2013. 10.1016/j.comppsych.2013.07.011
E7 | Choi, SK, LeGrand, S, . Condom use intentions mediate the relationships between psychosocial constructs and HIV sexual risk behavior in young Black men who have sex with men. AIDS Care. 31(1): 53–60. 2019. 10.1080/09540121.2018.1492695 29950106
E8 | Christensen, JL, Miller, LC, . Reducing shame in a game that predicts HIV risk reduction for young adult MSM: a randomized trial delivered nationally over the Web. J Int AIDS Soc. 16(3 Suppl 2): 18716. 2013. 10.7448/IAS.16.3.18716 24242264
E8 | Cianelli, R, Ferrer, L, . Mano a Mano-Mujer: an effective HIV prevention intervention for Chilean women. Health Care Women Int. 33(4): 321–341. 2012. PMID: 22420675.22420675
E2 | Cianelli, R, Villegas, N, . Self-efficacy for HIV Prevention Among Refugee Hispanic Women in South Florida. Journal of Immigrant & Minority Health. 19(4): 905–912. 2017. 10.1007/s10903-016-0462-7 27470226
E3a | Coffin, Phillip O, Santos, Glenn-Milo, . Adapted personalized cognitive counseling for episodic substance-using men who have sex with men: a randomized controlled trial. AIDS Behav. 18(7): 1390–1400. 2014.24510401
E7 | Cordova, D. The preliminary efficacy of a HIV preventive intervention app in an urban youth-centered community health clinic. Journal of adolescent health. Conference: society for adolescent health and medicine annual meeting 2018. United states. 62(2 Supplement 1): S10–s11. 2018.
E8 | Cortes-Bordoy, J, Vidart, JA, . Usefulness of an educational leaflet to modify sexual risk behaviour in women with external genital warts. Eur J Dermatol. 20(3): 339–344. 2010. PMID: 20146965.20146965
E5 | Crawford, MJ, Sanatinia, R, . The clinical and cost-effectiveness of brief advice for excessive alcohol consumption among people attending sexual health clinics: a randomised controlled trial. Sex Transm Infect. 91(1): 37–43. 2015. 10.1136/sextrans-2014-051561 24936090
E6 | Crosby, RA, Charnigo, RJ, . Enhancing condom use among Black male youths: a randomized controlled trial. Am J Public Health. 104(11): 2219–25. 2014. 10.2105/AJPH.2014.302131 25211749
E8 | Crosby, RA, Mena, L, . Efficacy of a Clinic-Based Safer Sex Program for Human Immunodeficiency Virus-Uninfected and Human Immunodeficiency Virus-Infected Young Black Men Who Have Sex With Men: A Randomized Controlled Trial. Sex Transm Dis. 45(3): 169–176. 2018. 10.1097/OLQ.0000000000000721 29419709
E12 | Crosby, RA, Mena, L, . Promoting positive condom use experiences among young black MSM: a randomized controlled trial of a brief, clinic-based intervention. Health Educ Res. 33(3): 197–204. 2018. 10.1093/her/cyy010 29534210
E6 | Crosby, RA, Mena, L, . Randomised controlled trial of a brief, clinic-based intervention to promote safer sex among young Black men who have sex with men: implications for pre-exposure prophylaxis-related counselling. Sex Health. 16(2): 187–191. 2019. 10.1071/SH18156 30721647
E12 | Crosby, R, Salazar, LF. Reduction of condom use errors from a brief, clinic-based intervention: a secondary analysis of data from a randomised, controlled trial of young black males. Sex Transm Infect. 91(2): 111–5. 2015. 10.1136/sextrans-2013-051492 24898858
E3a | D’Amico, EJ, Houck, JM, . Group motivational interviewing for homeless young adults: Associations of change talk with substance use and sexual risk behavior. Psychology of Addictive Behaviors. 31(6): 688–698. 2017. 10.1037/adb0000288 28627914
E6 | DiClemente, RJ, Brown, JL, . Rate of decay in proportion of condom-protected sex acts among adolescents after participation in an HIV risk-reduction intervention. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 63 (Suppl 1): S85–9. 2013. 10.1097/QAI.0b013e3182920173 23673893
E6 | DiClemente, RJ, Wingood, GM, . Efficacy of a telephone-delivered sexually transmitted infection/human immunodeficiency virus prevention maintenance intervention for adolescents: a randomized clinical trial. JAMA Pediatr. 168(10): 938–46. 2014. 10.1001/jamapediatrics.2014.1436 25155070
E3 | Dinaj-Koci, V, Lunn, S, . Adolescent age at time of receipt of one or more sexual risk reduction interventions. J Adolesc Health. 55(2): 228–34. 2014. 10.1016/j.jadohealth.2014.01.016 24656447
E7 | Downs, JS, Ashcraft, AM, . Video Intervention to Increase Perceived Self-Efficacy for Condom Use in a Randomized Controlled Trial of Female Adolescents. J Pediatr Adolesc Gynecol. 31(3): 291–298.e2. 2018. 10.1016/j.jpag.2017.10.008 29126824
E2a | Downs, JS, Bruine de Bruin, W, . Behavioral Decision Research Intervention Reduces Risky Sexual Behavior. Curr HIV Res. 13(5): 439–46. 2015.26149165
E12 | Downs, Js, Ashcraft, Am, . Can you get an STI from a virgin? The answer might surprise you intervention improves knowledge about sexual risk perceptions. Journal of adolescent health. 56(2 suppl. 1): S76–s77. 2015. 10.1016/j.jadohealth.2014.10.311
E6 | Eaton, LA, Kalichman, SC, . A reanalysis of a behavioral intervention to prevent incident HIV infections: including indirect effects in modeling outcomes of Project EXPLORE. AIDS Care. 25(7): 805–11. 2013. 10.1080/09540121.2012.748870 23245226
E6 | Eaton, Lisa A, Kalichman, Seth C, . Randomised controlled trial of a sexual risk reduction intervention for STI prevention among men who have sex with men in the USA. Sex Transm Infect. 94(1): 40–45. 2018.28404766
E3 | Espada, JP, Morales, A, . Short-term evaluation of a skill-development sexual education program for Spanish adolescents compared with a well-established program. J Adolesc Health. 56(1): 30–7. 2015. 10.1016/j.jadohealth.2014.08.018 25438966
E7 | Esposito-Smythers, C, Hadley, W, . Randomized pilot trial of a cognitive-behavioral alcohol, self-harm, and HIV prevention program for teens in mental health treatment. Behav Res Ther. 89: 49–56. 2017. 10.1016/j.brat.2016.11.005 27883927
E3 | Estrada, Y, Rosen, A, . Efficacy of a Brief Intervention to Reduce Substance Use and Human Immunodeficiency Virus Infection Risk Among Latino Youth. J Adolesc Health. Sep 19:S1054-139X(15)00285-2. 2015. 10.1016/j.jadohealth.2015.07.006
E2a | Ewing, AC, Kottke, MJ, . 2GETHER - The Dual Protection Project: Design and rationale of a randomized controlled trial to increase dual protection strategy selection and adherence among African American adolescent females. Contemp Clin Trials. 54: 1–7. 2017. 10.1016/j.cct.2016.12.014 28007634
E7 | Feinstein, BA, Bettin, E, . The Influence of Internalized Stigma on the Efficacy of an HIV Prevention and Relationship Education Program for Young Male Couples. AIDS Behav. 22(12):3847–3858. 2018. 10.1007/s10461-018-2093-6 29569000
E6 | Fernandez, M, Hosek, SybilG, . A randomized controlled trial of POWER: An Internet-based HIV prevention intervention for Black bisexual men. AIDS Behav. 20(9): 1951–1960. 2016. 10.1007/s10461-016-1403-0 27085548
E3 | Fernandez-Santos, DM, Miranda-Diaz, C, . Impact of ASUMA Intervention on HIV Risk Behaviors among Puerto Rican Adolescents. International Journal of Environmental Research & Public Health [Electronic Resource]. 13(1): ijerph13010060. 2015. 10.3390/ijerph13010060
E3a | Fiellin, LE, Hieftje, KD, . Video Game Intervention for Sexual Risk Reduction in Minority Adolescents: Randomized Controlled Trial. J Med Internet Res. 19(9): e314. 2017. 10.2196/jmir.8148 28923788
E2a | Gamarel, KE, Darbes, LA, . The Development and Testing of a Relationship Skills Intervention to Improve HIV Prevention Uptake Among Young Gay, Bisexual, and Other Men Who Have Sex With Men and Their Primary Partners (We Prevent): Protocol for a Randomized Controlled Trial. JMIR Res Protoc. 8(1): e10370. 2019. 10.2196/10370 30602433
E3 | Garofalo, R, Kuhns, LM, . Efficacy of an Empowerment-Based, Group-Delivered HIV Prevention Intervention for Young Transgender Women: The Project LifeSkills Randomized Clinical Trial. JAMA Pediatr. 172(10): 916–923. 2018. 10.1001/jamapediatrics.2018.1799 30105381
E3a | Gil-Llario, MD, Ballester-Arnal, R, . Effectiveness of HIV prevention for women: what is working?. AIDS Behav. 18(10): 1924–33. 2014. 10.1007/s10461-014-0703-5 24452498
E6 | Gimenez-Garcia, C, Ballester-Arnal, R, . Peer-Led or Expert-Led Intervention in HIV Prevention Efficacy? A Randomized Control Trial Among Spanish Young People to Evaluate Their Role. Health Promot Pract. 19(2): 277–286. 2018. 10.1177/1524839917733966 28954546
E6 | Gold, MA, Tzilos, GK, . A Randomized Controlled Trial to Compare Computer-assisted Motivational Intervention with Didactic Educational Counseling to Reduce Unprotected Sex in Female Adolescents. J Pediatr Adolesc Gynecol. 29(1): 26–32. 2016. 10.1016/j.jpag.2015.06.001 26514957
E7 | Gollub, EL, Cyrus-Cameron, E, . Basic body knowledge in street-recruited, active drug-using women enrolled in a “body empowerment” intervention trial. AIDS Care. 25(6): 732–7. 2013. 10.1080/09540121.2012.748167 23216297
E3a | Gollub, E, Cyrus-Cameron, E, . Active Drug-Using Women Use Female-Initiated Barrier Methods to Reduce HIV/STI Risk: Results from a Randomized Trial. ISRN Addiction. 2013: 768258. 2013. 10.1155/2013/768258 25938118
E3 | Gooden, Lauren, Metsch, LisaR, . Examining the efficacy of HIV risk-reduction counseling on the sexual risk behaviors of a national sample of drug abuse treatment clients: Analysis of subgroups. AIDS Behav. 20(9): 1893–1906. 2016. 10.1007/s10461-016-1300-6 26837631
E2a | Gousse, Y, McFarlane, D, . Lessons Learned from the Implementation of a Shared Community-Academic HIV Prevention Intervention. Progress in Community Health Partnerships. 12(4): 451–461. 2018. 10.1353/cpr.2018.0070 30739899
E3 | Green, J, Oman, RF, . Long-Term Improvements in Knowledge and Psychosocial Factors of a Teen Pregnancy Prevention Intervention Implemented in Group Homes. J Adolesc Health. 60(6): 698–705. 2017. 10.1016/j.jadohealth.2017.01.004 28259621
E7 | Grossman, SL, Campagna, B, . Improving body image and sexual health behaviors among college women. J Am Coll Health. 66(8): 826–830. 2018. 10.1080/07448481.2018.1454927 29565752
E3 | Hadley, W, Barker, D, . Relationship Between Unsupervised Time and Participation in an Emotion Regulation Intervention and Risk Outcomes. J Dev Behav Pediatr. 38(9): 714–722. 2017. 10.1097/DBP.0000000000000498 28902065
E6 | Hadley, W, Brown, LK, . Work It Out Together: Preliminary Efficacy of a Parent and Adolescent DVD and Workbook Intervention on Adolescent Sexual and Substance Use Attitudes and Parenting Behaviors. AIDS Behav. 20(9): 1961–72. 2016. 10.1007/s10461-016-1418-6 27155880
E3 | Harawa, NT, Guentzel-Frank, H, . Efficacy of a Small-Group Intervention for Post-Incarcerated Black Men Who Have Sex with Men and Women (MSMW). J Urban Health. 95(2): 159–170. 2018. 10.1007/s11524-018-0227-9 29541962
E6 | Harawa, NT, Williams, JK, . Efficacy of a culturally congruent HIV risk-reduction intervention for behaviorally bisexual black men: results of a randomized trial. AIDS. 27(12): 1979–88. 2013.24180003
E2 | Hart, TA, Stratton, N, . A Pilot Trial of a Sexual Health Counseling Intervention for HIV-Positive Gay and Bisexual Men Who Report Anal Sex without Condoms. PLoS ONE [Electronic Resource]. 11(4): e0152762. 2016. 10.1371/journal.pone.0152762
E6 | Hatch-Maillette, MaryA, Beadnell, Blair, . Heterosexual anal sex among men and women in substance abuse treatment: Secondary analysis of two gender-specific HIV-prevention trials. J Sex Res. 54(1): 33–41. 2017. 10.1080/00224499.2015.1118426 26820608
E5 | Hawk, M. The Girlfriends Project: Results of a pilot study assessing feasibility of an HIV testing and risk reduction intervention developed, implemented, and evaluated in community settings. AIDS Educ Prev. 25(6): 519–34. 2013. 10.1521/aeap.2013.25.6.519 24245598
E2a | Herbst, JH, Raiford, JL, . Adaptation and National Dissemination of a Brief, Evidence-Based, HIV Prevention Intervention for High-Risk Men Who Have Sex with Men. MMWR: Morbidity & Mortality Weekly Report - Supplement. 65(1): 42–50. 2016. 10.15585/mmwr.su6501a7 26916033
E6 | Hidalgo, MA, Kuhns, LM, . The MyPEEPS randomized controlled trial: a pilot of preliminary efficacy, feasibility, and acceptability of a group-level, HIV risk reduction intervention for young men who have sex with men. Arch Sex Behav. 44(2): 475–85. 2015. 10.1007/s10508-014-0347-6 25135064
E6 | Hightow-Weidman, LB, LeGrand, S, . A Randomized Trial of an Online Risk Reduction Intervention for Young Black MSM. AIDS Behav. 23(5): 1166–1177. 2019. 10.1007/s10461-018-2289-9 30269231
E3a | Houck, CD, Barker, DH, . Sexual Risk Outcomes of an Emotion Regulation Intervention for At-Risk Early Adolescents. Pediatrics. 141(6): 06. 2018. 10.1542/peds.2017-2525
E3a | Jemmott, JB, 3rd, Jemmott, . On the Efficacy and Mediation of a One-on-One HIV Risk-Reduction Intervention for African American Men Who Have Sex with Men: A Randomized Controlled Trial. AIDS Behav. 19(7): 1247–62. 2015. 10.1007/s10461-014-0961-2 25449552
E3 | Jenner, E, Jenner, LW, . Impact of an Intervention Designed to Reduce Sexual Health Risk Behaviors of African American Adolescents: Results of a Randomized Controlled Trial. Am J Public Health. 106(S1): S78–s84. 2016. 10.2105/ajph.2016.303291 27689499
E6 | Jones, DL, Kashy, D, . The impact of substance use, sexual trauma, and intimate partner violence on sexual risk intervention outcomes in couples: a randomized trial. Ann Behav Med. 45(3): 318–28. 2013. 10.1007/s12160-012-9455-5 23208648
E10 | Jones, HE, Kirtadze, I, . Feasibility and initial efficacy of a culturally sensitive women-centered substance use intervention in Georgia: Sex risk outcomes. Subst Abuse Treat Prev Policy. 10: 47. 2015. 10.1186/s13011-015-0043-0 26644132
E6 | Jones, R, Hoover, DR, . A randomized controlled trial of soap opera videos streamed to smartphones to reduce risk of sexually transmitted human immunodeficiency virus (HIV) in young urban African American women.[Erratum appears in Nurs Outlook. 2013 Nov-Dec;61(6):383]. Nurs Outlook. 61(4): 205–215.e3. 2013. 10.1016/j.outlook.2013.03.006 23743482
E2 | Kanamori, M, De La Rosa, M, . A Brief Report: Lessons Learned and Preliminary Findings of Progreso en Salud, an HIV Risk Reduction Intervention for Latina Seasonal Farmworkers. Int J Environ Res Public Health. 14(1): 30. 2016. 10.3390/ijerph14010032
E3 | Kaufman, CE, Whitesell, NR, . Effectiveness of Circle of Life, an HIV-preventive intervention for American Indian middle school youths: a group randomized trial in a Northern Plains tribe. Am J Public Health. 104(6): e106–12. 2014. 10.2105/AJPH.2013.301822
E3 | Kelsey, Meredith, Layzer, Carolyn, . Replicating Cuidate!: 6-month impact findings of a randomized controlled trial. Am J Public Health. 106(Suppl 1): S70–S77. 2016. 10.2105/AJPH.2016.303371 27689498
E6 | Kennedy, SB, Nolen, S, . Effectiveness of a brief condom promotion program in reducing risky sexual behaviours among African American men. J Eval Clin Pract. 19(2): 408–13. 2013. 10.1111/j.1365-2753.2012.01841.x 22435646
E8 | Klein, CH, Kuhn, T, . C-SAFE: A Computer-Delivered Sexual Health Promotion Program for Latinas. Health Promot Pract. 18(4): 516–525. 2017. 10.1177/1524839917707791 28490203
E6 | Koblin, BA, Bonner, S, . A randomized trial of a behavioral intervention for black MSM: the DiSH study. AIDS. 26(4): 483–488. 2012. PMID: 22156967.22156967
E6 | Kurth, AE, Chhun, N, . Linguistic and Cultural Adaptation of a Computer-Based Counseling Program (CARE+ Spanish) to Support HIV Treatment Adherence and Risk Reduction for People Living With HIV/AIDS: A Randomized Controlled Trial. J Med Internet Res. 18(7): e195. 2016. 10.2196/jmir.5830 27417531
E6 | Kurtz, SP, Stall, RD, . A randomized trial of a behavioral intervention for high risk substance-using MSM. AIDS Behav. 17(9): 2914–26. 2013. 10.1007/s10461-013-0531-z 23732957
E3 | Kurtz, Sp, Buttram, Me, . A randomized trial of brief assessment interventions for young adults who use drugs in the club scene. J Subst Abuse Treat. 78: 64–73. 2017. 10.1016/j.jsat.2017.05.008 28554606
E12 | Lau, JT, Lee, AL, . A Randomized Control Trial for Evaluating Efficacies of Two Online Cognitive Interventions With and Without Fear-Appeal Imagery Approaches in Preventing Unprotected Anal Sex Among Chinese Men Who Have Sex with Men. AIDS Behav. 20(9): 1851–62. 2016. 10.1007/s10461-015-1263-z 26802004
E6 | Lauby, J, Milnamow, M, . Evaluation of Project RISE, an HIV Prevention Intervention for Black Bisexual Men Using an Ecosystems Approach. AIDS Behav. 22(1): 164–177. 2018. 10.1007/s10461-017-1892-5 28871506
E7 | Lewis, MA, Patrick, ME, . Randomized controlled trial of a web-delivered personalized normative feedback intervention to reduce alcohol-related risky sexual behavior among college students. J Consult Clin Psychol. 82(3): 429–40. 2014. 10.1037/a0035550 24491076
E8 | Llewellyn, CD, Abraham, C, . A randomised controlled trial of a telephone administered brief HIV risk reduction intervention amongst men who have sex with men prescribed post-exposure prophylaxis for HIV after sexual exposure in the UK: Project PEPSE. PLoS ONE [Electronic Resource]. 14(5): e0216855. 2019. 10.1371/journal.pone.0216855
E2 | Logie, CarmenH, Lacombe-Duncan, Ashley, . A pilot study of a group-based HIV and STI prevention intervention for lesbian, bisexual, queer, and other women who have sex with women in Canada. AIDS Patient Care STDS. 29(6): 321–328. 2015. 10.1089/apc.2014.0355 25867642
E5 | Lyson, HC, Le, GM, . Social Media as a Tool to Promote Health Awareness: Results from an Online Cervical Cancer Prevention Study. J Cancer Educ. 34(4):819–822. 2018. 10.1007/s13187-018-1379-8
E3 | Mallory, C, Hesson-McInnis, M. Pilot test results of an HIV prevention intervention for high-risk women. West J Nurs Res. 35(3): 313–29. 2013. 10.1177/0193945911416134 21821725
E2 | Marcell, AV, Allan, E, . Effectiveness of a brief curriculum to promote condom and health care use among out-of-school young adult males. Perspect Sex Reprod Health. 45(1): 33–40. 2013. 10.1363/4503313 23489856
E8 | Marion, LN, Finnegan, L, . The Well Woman Program: a community-based randomized trial to prevent sexually transmitted infections in low-income African American women. Res Nurs Health. 32(3): 274–285. 2009. PMID: 19373824.19373824
E2a | McCabe, BE, Gonzalez-Guarda, RM, . Mechanisms of Partner Violence Reduction in a Group HIV-Risk Intervention for Hispanic Women. J Interpers Violence. 31(13): 2316–37. 2016. 10.1177/0886260515575608 25805845
E2 | McCabe, BE, Schaefer Solle, N, . Alcohol misuse, depressive symptoms, and HIV/STI risks of US Hispanic women. Ethn Health. 22(5): 528–540. 2017. 10.1080/13557858.2016.1244738 27744723
E7 | McMahon, JM, Chimenti, R, . Risk of Intimate Partner Violence and Relationship Conflict Following Couple-Based HIV Prevention Counseling: Results From the Harlem River Couples Project. J Interpers Violence. 32(24):3709–3734. 2015. 10.1177/0886260515600878 26319710
E3a | McMahon, JM, Pouget, ER, . Couple-based HIV counseling and testing: a risk reduction intervention for US drug-involved women and their primary male partners. Prevention Science. 16(2): 341–51. 2015. 10.1007/s11121-014-0540-9 25512179
E3a | McMahon, JM, Tortu, S, . Effectiveness of Couple-Based HIV Counseling and Testing for Women Substance Users and Their Primary Male Partners: A Randomized Trial. Adv Prev Med. 2013: 286207. 2013. 10.1155/2013/286207 23555059
E3a | McMahon, James M, Tortu, Stephanie, . Recruitment of heterosexual couples in public health research: a study protocol. BMC Med Res Methodol. 3(1): 24. 2003.14594457
E3 | Mimiaga, MJ, Hughto, JMW, . A Randomized Pilot Study of a Group-Delivered HIV Risk Reduction Intervention for At-Risk Urban Men Who Have Sex with Men Who Regularly Attend Private Sex Events. Arch Sex Behav. 48(4): 1059–1071. 2019. 10.1007/s10508-018-1326-0 30805830
E2a | Mimiaga, MJ, Pantalone, DW, . A randomized controlled efficacy trial of behavioral activation for concurrent stimulant use and sexual risk for HIV acquisition among MSM: project IMPACT study protocol. BMC Public Health. 18(1): 914. 2018. 10.1186/s12889-018-5856-0 30045702
E2 | Moniz, MH, Meyn, LA, . Text Messaging to Improve Preventive Health Attitudes and Behaviors During Pregnancy: A Prospective Cohort Analysis. J Reprod Med. 60(9–10): 378–82. 2015.26592061
E12 | Montanaro, ErikaA. What are the ‘active ingredients’ of change in the theory of planned behavior? evaluating the relative effectiveness of attitudes, norms, and perceived behavioral control/self-efficacy. Dissertation Abstracts International: Section B: The Sciences and Engineering. 76(1-B(E)): No Pagination Specified. 2015.
E7 | Montgomery, TM, Mays, VM, . Acceptability and Feasibility of a Sexual Health Intervention for Young Adult Black Women. J Obstet Gynecol Neonatal Nurs. 47(6):862–873. 2018. 10.1016/j.jogn.2018.04.136
E3 | Morales, A, Espada, JP, . Mediation of an efficacious HIV risk reduction intervention for adolescents: A cluster-randomised controlled trial. J Health Psychol. 24(13):1884–1896. 2017. 10.1177/1359105317707256 28810466
E3 | Morales, A, Espada, JP, . The short-term impact of peers as co-facilitators of an HIV prevention programme for adolescents: a cluster randomised controlled trial. European Journal of Contraception & Reproductive Health Care. 19(5): 379–91. 2014. 10.3109/13625187.2014.919445 24902040
E3a | Morgenstern, J, Bux, DA, . Randomized trial to reduce club drug use and HIV risk behaviors among men who have sex with men. J Consult Clin Psychol. 77(4): 645–656. 2009. PMID: 19634958.19634958
E7 | Morrison-Beedy, D, Grove, L. Adolescent Girls’ Experiences With Sexual Pressure, Coercion, and Victimization: #MeToo. Worldviews on Evidence-Based Nursing. 15(3): 225–229. 2018. 10.1111/wvn.12293 29729655
E6 | Motley, DN, Hammond, S, . Strategies Chosen by YMSM During Goal Setting to Reduce Risk for HIV and Other Sexually Transmitted Infections: Results From the Keep It Up! 2.0 Prevention Trial. AIDS Educ Prev. 29(1): 1–13. 2017. 10.1521/aeap.2017.29.1.1 28195780
E2a | Munro-Kramer, ML, Fava, NM, . What are we missing? Risk behaviors among Arab-American adolescents and emerging adults. J Am Assoc Nurse Pract. 28(9): 493–502. 2016. 10.1002/2327-6924.12352 26990394
E12 | Murray, P, Ashcraft, A, . Evaluation of video intervention on sex-related psychosocial and behavioral outcomes in a randomized controlled trial of female adolescents. Sexually transmitted diseases. Conference: 2016 sexually transmitted diseases prevention conference. United states. 43(10 Supplement 2): S205–s206. 2016. 10.1097/01.olq.0000503358.65329.6f
E6 | Mustanski, B, Garofalo, R, . Feasibility, acceptability, and preliminary efficacy of an online HIV prevention program for diverse young men who have sex with men: the keep it up! intervention. AIDS Behav. 17(9): 2999–3012. 2013. 10.1007/s10461-013-0507-z 23673793
E6 | Mustanski, B, Parsons, JT, . Biomedical and Behavioral Outcomes of Keep It Up!: An eHealth HIV Prevention Program RCT. Am J Prev Med. 55(2): 151–158. 2018. 10.1016/j.amepre.2018.04.026 29937115
E12 | Negash, Sesen. Sexual health education in college: The impact of sexual negotiation training on sexual risk reduction. Dissertation Abstracts International Section A: Humanities and Social Sciences. 74(2-A(E)): No Pagination Specified. 2013.
E2a | Newby, KV, French, DP, . Increasing young adults’ condom use intentions and behaviour through changing chlamydia risk and coping appraisals: study protocol for a cluster randomised controlled trial of efficacy. BMC Public Health. 13: 528. 2013. 10.1186/1471-2458-13-528 23721352
E8 | Ng, JYS, Chan, RKW, . An Abstinence and Safer Sex Intervention for Adolescents Attending the Public Sexually Transmitted Infection Clinic in Singapore. J Adolesc Health. 62(6): 737–746. 2018. 10.1016/j.jadohealth.2017.12.014 29661642
E7 | Nostlinger, C, Borms, R, . Development of a theory-guided pan-European computer-assisted safer sex intervention. Health Promot Int. 31(4): 782–792. 2016.26092853
E5 | Nyamathi, A, Reback, CJ, . Impact of Tailored Interventions to Reduce Drug Use and Sexual Risk Behaviors Among Homeless Gay and Bisexual Men. Am J Mens Health. 11(2): 208–220. 2017. 10.1177/1557988315590837 26130725
E3a | O’Donnell, L, Stueve, A, . Adapting the VOICES HIV behavioral intervention for Latino men who have sex with men. AIDS Behav. 18(4): 767–75. 2014. 10.1007/s10461-013-0653-3 24419993
E12 | Operario, D, Arnold, E, . A forgotten drug in the hiv epidemic: alcohol use and unprotected sexual behavior in high-risk african american men. Alcoholism: clinical and experimental research.. 37: 295a. 2013. 10.1111/acer.12163
E6 | Operario, D, Gamarel, KE, . Couples-Focused Prevention Program to Reduce HIV Risk Among Transgender Women and Their Primary Male Partners: Feasibility and Promise of the Couples HIV Intervention Program. AIDS Behav. 21(8): 2452–2463. 2017. 10.1007/s10461-016-1462-2 27334464
E2 | Owczarzak, J, Broaddus, M, . Effectiveness of an evidence-based HIV prevention intervention when implemented by frontline providers. Transl Behav Med. 21; 8(6):917–926. 2018.29385559
E6 | Parsons, JT, Lelutiu-Weinberger, C, . A randomized controlled trial utilizing motivational interviewing to reduce HIV risk and drug use in young gay and bisexual men. J Consult Clin Psychol. 82(1): 9–18. 2014. 10.1037/a0035311 24364800
E8 | Pearson, CR, Kaysen, D, . Randomized Control Trial of Culturally Adapted Cognitive Processing Therapy for PTSD Substance Misuse and HIV Sexual Risk Behavior for Native American Women. AIDS Behav. 23(3): 695–706. 2019. 10.1007/s10461-018-02382-8 30607757
E7 | Pellowski, JA, Kalichman, SC. Mixing it Up: Integrating Men and Women Living with HIV/AIDS in Prevention Groups. J HIV AIDS Soc Serv. 12(2): 190–204. 2013. 10.1080/15381501.2013.790751 25525414
E3a | Perez-Jimenez, D, Seal, DW, . A Pilot Intervention to Promote Safer Sex in Heterosexual Puerto Rican Couples. Couple Family Psychol. 3(3): 193–206. 2014. 10.1037/cfp0000022 25512880
E3 | Peskin, MF, Shegog, R, . Efficacy of It’s Your Game-Tech: A Computer-Based Sexual Health Education Program for Middle School Youth. J Adolesc Health. 56(5): 515–21. 2015. 10.1016/j.jadohealth.2015.01.001 25739520
E2a | Prado, G, Estrada, Y, . Rationale and design for eHealth Familias Unidas Primary Care: A drug use, sexual risk behavior, and STI preventive intervention for hispanic youth in pediatric primary care clinics. Contemp Clin Trials. 76: 64–71. 2019. 10.1016/j.cct.2018.11.005 30453076
E3 | Prado, G, Huang, S, . Ecodevelopmental and intrapersonal moderators of a family based preventive intervention for Hispanic youth: a latent profile analysis. Prevention Science. 14(3): 290–9. 2013. 10.1007/s11121-012-0326-x 23408280
E6 | Raghupathy, S, Klein, C, . Online Activities for Enhancing Sex Education Curricula: Preliminary Evidence on the Effectiveness of the Abstinence and Contraception Education Storehouse. J HIV AIDS Soc Serv. 12(2): 160–171. 2013. 10.1080/15381501.2013.790749 24078799
E5 | Reback, CJ, Peck, JA, . Contingency management among homeless, out-of-treatment men who have sex with men. J Subst Abuse Treat. 39(3): 255–263. 2010. PMID: 20667681.20667681
E6 | Reback, CathyJ, Veniegas, Rosemary, . Getting off: Development of a model program for gay and Bisexual Male Methamphetamine Users. J Homosex. 61(4): 540–553. 2014. 10.1080/00918369.2014.865459 24245506
E3a | Rhodes, SD, Alonzo, J, . Small-Group Randomized Controlled Trial to Increase Condom Use and HIV Testing Among Hispanic/Latino Gay, Bisexual, and Other Men Who Have Sex With Men. Am J Public Health. 107(6): 969–976. 2017. 10.2105/AJPH.2017.303814 28426301
E3 | Rizzo, CJ, Joppa, M, . Project Date SMART: a Dating Violence (DV) and Sexual Risk Prevention Program for Adolescent Girls with Prior DV Exposure. Prevention Science. 19(4): 416–426. 2018. 10.1007/s11121-018-0871-z 29352400
E7 | Roux, P, Le Gall, JM, . Innovative community-based educational face-to-face intervention to reduce HIV, hepatitis C virus and other blood-borne infectious risks in difficult-to-reach people who inject drugs: results from the ANRS-AERLI intervention study. Addiction. 111(1): 94–106. 2016. 10.1111/add.13089 26234629
E6 | Safren, SA, O’Cleirigh, CM, . Project enhance: a randomized controlled trial of an individualized HIV prevention intervention for HIV-infected men who have sex with men conducted in a primary care setting. Health Psychol. 32(2): 171–9. 2013. 10.1037/a0028581 22746262
E7 | Sales, Jm, Brown, Jl, . A pilot study of a combination STD prevention intervention for african-american mothers and their adolescent daughters. Sexually transmitted diseases.. 41: S9. 2014.
E3a | Sanchez, J, De La Rosa, M, . Project Salud: Efficacy of a community-based HIV prevention intervention for Hispanic migrant workers in south Florida. AIDS Educ Prev. 25(5): 363–75. 2013. 10.1521/aeap.2013.25.5.363 24059875
E8 | Sanderson, M, Khabele, D, . Results of a Health Education Message Intervention on HPV Knowledge and Receipt of Follow-up Care among Latinas Infected with High-risk Human Papillomavirus. J Health Care Poor Underserved. 26(4): 1440–55. 2015. 10.1353/hpu.2015.0131 26548691
E7 | Schonnesson, LN, Bowen, AM, . Project SMART: Preliminary Results From a Test of the Efficacy of a Swedish Internet-Based HIV Risk-Reduction Intervention for Men Who Have Sex With Men. Arch Sex Behav. 45(6): 1501–11. 2016. 10.1007/s10508-015-0608-z 26545912
E6 | Schwarcz, SK, Chen, YH, . A randomized control trial of personalized cognitive counseling to reduce sexual risk among HIV-infected men who have sex with men. AIDS Care. 25(1): 1–10. 2013. 10.1080/09540121.2012.674095 22568569
E2 | Scott-Sheldon, La, Senn, Te, . Quantity, not frequency, of alcohol use moderates the association between multiple sexual partners and Trichomonas vaginalis among women attending an urban STD clinic. Sex Transm Infect. 89(6): 498–503. 2013. 10.1136/sextrans-2012-050983 23580608
E7 | Scull, TM, Kupersmidt, JB, . Examining the efficacy of an mHealth media literacy education program for sexual health promotion in older adolescents attending community college. Journal of American College Health. 66(3): 165–177. 2018. 10.1080/07448481.2017.1393822 29068772
E8 | Seth, P, Wingood, GM, . Abuse Impedes Prevention: The Intersection of Intimate Partner Violence and HIV/STI Risk Among Young African American Women. AIDS Behav. 19(8): 1438–45. 2015. 10.1007/s10461-014-0940-7 25399033
E2a | Shrestha, R, Krishnan, A, . A non-inferiority trial of an evidence-based secondary HIV prevention behavioral intervention compared to an adapted, abbreviated version: Rationale and intervention description. Contemp Clin Trials. 44: 95–102. 2015. 10.1016/j.cct.2015.08.002 26253181
E7 | Sieving, RE, Allen, ML, . Encuentro: Feasibility, Acceptability, and Outcomes of a Culturally Tailored Teen-Parent Health Promotion Program. Health Promot Pract. 18(5): 751–762. 2017. 10.1177/1524839916654462 27288691
E5 | Sieving, RE, McMorris, BJ, . Prime Time: 12-month sexual health outcomes of a clinic-based intervention to prevent pregnancy risk behaviors. J Adolesc Health. 49(2): 172–9. 2011. 10.1016/j.jadohealth.2010.12.002 21783050
E5 | Sieving, RE, McRee, AL, . Prime time: sexual health outcomes at 24 months for a clinic-linked intervention to prevent pregnancy risk behaviors. JAMA Pediatr. 167(4): 333–40. 2013. 10.1001/jamapediatrics.2013.1089 23440337
E5 | Sieving, RE, McRee, AL, . Prime Time: long-term sexual health outcomes of a clinic-linked intervention. Perspect Sex Reprod Health. 46(2): 91–100. 2014. 10.1363/46e0914 24650164
E6 | Sikkema, KJ, Abler, L, . Positive choices: outcomes of a brief risk reduction intervention for newly HIV-diagnosed men who have sex with men. AIDS Behav. 18(9): 1808–19. 2014. 10.1007/s10461-014-0782-3 24771017
E6 | Snead, MC, O’Leary, AM, . Relationship between social cognitive theory constructs and self-reported condom use: assessment of behaviour in a subgroup of the Safe in the City trial.[Erratum appears in BMJ Open. 2016 Jun 22;6(6):e006093corr1; PMID: 27334880]. BMJ Open. 4(12): e006093. 2014. 10.1136/bmjopen-2014-006093
E3 | Spoth, R, Clair, S, . Universal family-focused intervention with young adolescents: effects on health-risking sexual behaviors and STDs among young adults. Prevention Science. 15(Suppl 1): S47–58. 2014. 10.1007/s11121-012-0321-2 23408278
E3 | Stanton, B, Dinaj-Koci, V, . Adolescent HIV Risk Reduction in the Bahamas: Results from Two Randomized Controlled Intervention Trials Spanning Elementary School Through High School. AIDS Behav. 20(6): 1182–96. 2016. 10.1007/s10461-015-1225-5 26499123
E6 | Starks, TJ, Parsons, JT. Drug Use and HIV Prevention With Young Gay and Bisexual Men: Partnered Status Predicts Intervention Response. AIDS Behav. 22(9):2788–2796. 2018. 10.1007/s10461-018-2091-8 29556833
E8 | Starosta, AJ, Cranston, E, . Safer sex in a digital world: A Web-based motivational enhancement intervention to increase condom use among college women. Journal of American College Health. 64(3): 184–93. 2016. 10.1080/07448481.2015.1107835 26700487
E7 | Stern, J, Larsson, M, . Introducing the Reproductive Life Plan in midwifery counselling-a randomised controlled trial. European journal of contraception and reproductive health care.. 18: S195. 2013. 10.3109/13625187.2013.793038
E3a | Stewart, KE, Wright, PB, . Reducing Risky Sex among Rural African American Cocaine Users: A Controlled Trial. J Health Care Poor Underserved. 28(1): 528–547. 2017. 10.1353/hpu.2017.0038 28239017
E6 | Sun, WH, Wong, CKH, . A Peer-Led, Social Media-Delivered, Safer Sex Intervention for Chinese College Students: Randomized Controlled Trial. J Med Internet Res. 19(8): e284. 2017. 10.2196/jmir.7403 28793980
E4 | Takahashi, LM, Tobin, KE, . Chieh Mei Ching Yi: A randomized controlled trial of a culturally tailored HIV prevention intervention for Chinese massage parlor women in Los Angeles. AIDS Educ Prev. 25(6): 508–18. 2013. 10.1521/aeap.2013.25.6.508 24245597
E7 | Thomas, KA, Sorenson, SB, . “Consent is Good, Joyous, Sexy”: A banner campaign to market consent to college students. Journal of American College Health. 64(8): 639–650. 2016.27471816
E6 | Thompson, RG, Jr, Elliott, . Short-term effects of a brief intervention to reduce alcohol use and sexual risk among homeless young adults: Results from a randomized controlled trial. Addict Res Theory. 25(1): 24–31. 2017. 10.1080/16066359.2016.1193165 28620272
E1 | Thurheimer, J, Sereika, SM, . Efficacy of the READY-Girls Program on General Risk-Taking Behaviors, Condom Use, and Sexually Transmitted Infections Among Young Adolescent Females With Type 1 Diabetes. Diabetes Educator. 42(6): 712–720. 2016.27630009
E1 | Thurheimer, JenniferL. Examining short- and long-term effects of preconception counseling delivered during adolescence on risk-taking behaviors, condom use, and sexually transmitted infections among females with type 1 diabetes. Dissertation Abstracts International: Section B: The Sciences and Engineering. 77(1-B(E)): No Pagination Specified. 2016.
E3 | Tingey, L, Mullany, B, . The Respecting the Circle of Life trial for American Indian adolescents: rationale, design, methods, and baseline characteristics. AIDS Care. 27(7): 885–91. 2015. 10.1080/09540121.2015.1015481 25714127
E3a | Tobin, K, Davey-Rothwell, MA, . RCT of an integrated CBT-HIV intervention on depressive symptoms and HIV risk. PLoS ONE [Electronic Resource]. 12(12): e0187180. 2017. 10.1371/journal.pone.0187180
E3a | Tobin, K, Kuramoto, SJ, . Unity in diversity: results of a randomized clinical culturally tailored pilot HIV prevention intervention trial in Baltimore, Maryland, for African American men who have sex with men. Health Education & Behavior. 40(3): 286–95. 2013. 10.1177/1090198112452125 22984216
E2 | Toland, Rebecca. Reduction of risky sexual behavior through behavioral modification based curriculum. Dissertation Abstracts International Section A: Humanities and Social Sciences. 74(12-A(E)): No Pagination Specified. 2014.
E3a | Tucker, JS, D’Amico, EJ, . A group-based motivational interviewing brief intervention to reduce substance use and sexual risk behavior among homeless young adults. J Subst Abuse Treat. 76: 20–27. 2017. 10.1016/j.jsat.2017.02.008 28340904
E12 | Van Orden, Onna Rose. The influence of event-level factors and processes of change on safe sex and alcohol use among HIV+ men who have sex with men. Dissertation Abstracts International: Section B: The Sciences and Engineering. 75(1-B(E)): No Pagination Specified. 2014.
E3a | Wechsberg, Wendee M, Browne, Felicia A, . Efficacy of the Young Women’s CoOp: An HIV Risk-Reduction Intervention for Substance-Using African-American Female Adolescents in the South. J Child Adolesc Subst Abuse. 26(3): 205–218. 2017.28845096
E7 | Wenzel, SL, Cederbaum, JA, . Pilot Test of an Adapted, Evidence-Based HIV Sexual Risk Reduction Intervention for Homeless Women. Prevention Science. 17(1): 112–21. 2016. 10.1007/s11121-015-0575-6 26103921
E7 | Widman, L, Golin, CE, . Sexual Assertiveness Skills and Sexual Decision-Making in Adolescent Girls: Randomized Controlled Trial of an Online Program. Am J Public Health. 108(1): 96–102. 2018. 10.2105/AJPH.2017.304106 29161072
E7 | Widman, L, Golin, CE, . Feasibility and acceptability of a web-based HIV/STD prevention program for adolescent girls targeting sexual communication skills. Health Educ Res. 32(4): 343–352. 2017. 10.1093/her/cyx048 28854574
E3 | Williams, SP, Myles, RL, . An Intervention for Reducing the Sexual Risk of Men Released From Jails. Journal of Correctional Health Care. 24(1): 71–83. 2018. 10.1177/1078345817745537 29303039
E6 | Witte, SS, Wu, E, . Implementation of a couple-based HIV prevention program: a cluster randomized trial comparing manual versus Web-based approaches. Implementation Science. 9: 116. 2014. 10.1186/s13012-014-0116-x 25208569
E8 | Wong, ML, Ng J YS, Chan R KW, . Randomized controlled trial of abstinence and safer sex intervention for adolescents in Singapore: 6-month follow-up. Health Educ Res. 32(3): 233–243. 2017. 10.1093/her/cyx040 28472284
E5 | Wray, TB, Chan, PA, . A Pilot, Randomized Controlled Trial of HIV Self-Testing and Real-Time Post-Test Counseling/Referral on Screening and Preventative Care Among Men Who Have Sex with Men. AIDS Patient Care STDS. 32(9): 360–367. 2018. 10.1089/apc.2018.0049 30179528
E3 | Wray, TB, Kahler, CW, . A Preliminary Randomized Controlled Trial of Game Plan, A Web Application to Help Men Who Have Sex with Men Reduce Their HIV Risk and Alcohol Use. AIDS Behav. 23(6): 1668–1679. 2019. 10.1007/s10461-019-02396-w 30671682
E7 | Ybarra, ML, Liu, W, . The Effect of a Text Messaging Based HIV Prevention Program on Sexual Minority Male Youths: A National Evaluation of Information, Motivation and Behavioral Skills in a Randomized Controlled Trial of Guy2Guy. AIDS Behav. 22(10):3335–3344. 2018. 10.1007/s10461-018-2118-1 29696403
E8 | Young, SD, Cumberland, WG, . Social networking technologies as an emerging tool for HIV prevention: a cluster randomized trial. Ann Intern Med. 159(5): 318–24. 2013. 10.7326/0003-4819-159-5-201309030-00005 24026317
E7 | Young, SD, Holloway, I, . Project HOPE: online social network changes in an HIV prevention randomized controlled trial for African American and Latino men who have sex with men. Am J Public Health. 104(9): 1707–12. 2014. 10.2105/AJPH.2014.301992 25033137
E3a | Zellner, T, Trotter, J, . Color It Real: A Program to Increase Condom Use and Reduce Substance Abuse and Perceived Stress. International Journal of Environmental Research & Public Health [Electronic Resource]. 13(1): ijerph13010051. 2015. 10.3390/ijerph13010051
E3 | Zhang, J, Cederbaum, JA, . Theory-Based Behavioral Intervention Increases Mother-Son Communication About Sexual Risk Reduction Among Inner-City African-Americans. J Adolesc Health. 63(4): 497–502. 2018. 10.1016/j.jadohealth.2018.04.017 30146434
E3 | Zhang, J, Jemmott, JB, . Mediation and moderation of an efficacious theory-based abstinence-only intervention for African American adolescents. Health Psychol. 34(12): 1175–84. 2015. 10.1037/hea0000244 26214076
E7 | Zhang, J, Jemmott, JB, . Efficacy and Mediation of a Theory-Based Physical Activity Intervention for African American Men Who Have Sex with Men: A Randomized Controlled Trial. Annals of Behavioral Medicine. 51(1): 106–116. 2017. 10.1007/s12160-016-9832-6 27658914
E8 | Zule, WA, Bobashev, GV, . Results of a pilot test of a brief computer-assisted tailored HIV prevention intervention for use with a range of demographic and risk groups. AIDS Behav. 17(9): 3045–58. 2013. 10.1007/s10461-013-0557-2 23872994