# Appendix C Included Studies

## Below is a list of included studies and their ancillary publications (indented below main results publication)

Bai, S., . (2018). “Reducing health risk behaviors and improving depression in adolescents: A randomized controlled trial in primary care clinics.” [underlined: Journal of Pediatric Psychology] 43(9): 1004–1016. PMID: 30016473 10.1093/jpepsy/jsy048 30016473
Bailey JV, Webster R, Hunter R, . The Men’s Safer Sex project: intervention development and feasibility randomised controlled trial of an interactive digital intervention to increase condom use in men. Health Technology Assessment (Winchester, England). 2016;20(91):1–124. PMID: 27966409. 10.3310/hta20910 27966409
Berenson AB, Rahman M. A randomized controlled study of two educational interventions on adherence with oral contraceptives and condoms. Contraception. 2012;86(6):716–24. PMID: 22840278. 10.1016/j.contraception.2012.06.007 22840278
Berkman A, Pilowsky DJ, Zybert PA, . HIV prevention with severely mentally ill men: a randomised controlled trial. AIDS Care. 2007;19(5):579–88. PMID: 17505917. 10.1080/09540120701213989 17505917
Billings DW, Leaf SL, Spencer J, . A Randomized Trial to Evaluate the Efficacy of a Web-Based HIV Behavioral Intervention for High-Risk African American Women. AIDS Behav. 2015;19(7):1263–74. PMID: 25616838. 10.1007/s10461-015-0999-9 25616838
Carey MP, Carey KB, Maisto SA, . Reducing HIV-risk behavior among adults receiving outpatient psychiatric treatment: results from a randomized controlled trial. J Consult Clin Psychol. 2004;72(2):252–68. PMID: 15065959. 10.1037/0022-006X.72.2.252 15065959
Carey MP, Senn TE, Vanable PA, . Brief and intensive behavioral interventions to promote sexual risk reduction among STD clinic patients: results from a randomized controlled trial. AIDS & Behav. 2010;14(3):504–17. PMID: 19590947. 10.1007/s10461-009-9587-1 19590947
Carey MP, Vanable PA, Senn TE, . Evaluating a two-step approach to sexual risk reduction in a publicly-funded STI clinic: rationale, design, and baseline data from the Health Improvement Project-Rochester (HIP-R). Contemp Clin Trials. 2008;29(4):569–86. PMID: 18325853. 10.1016/j.cct.2008.02.001 18325853
Mittal M, Senn TE, Carey MP. Mediators of the relation between partner violence and sexual risk behavior among women attending a sexually transmitted disease clinic. Sex Transm Dis. 2011;38(6):510–5. PMID: 21258269. 10.1097/OLQ.0b013e318207f59b 21258269
Mittal M, Senn TE, Carey MP. Fear of violent consequences and condom use among women attending an STD clinic. Women & Health. 2013;53(8):795–807. PMID: 24215273. 10.1080/03630242.2013.847890 24215273
Carey MP, Senn TE, Walsh JL, . Evaluating a Brief, Video-Based Sexual Risk Reduction Intervention and Assessment Reactivity with STI Clinic Patients: Results from a Randomized Controlled Trial. AIDS Behav. 2015;19(7):1228–46. PMID: 25433653. 10.1007/s10461-014-0960-3 25433653
Champion JD. Behavioural interventions and abuse: secondary analysis of reinfection in minority women. Int J STD AIDS. 2007;18(11):748–53. PMID: 18005508. 10.1258/095646207782212180 18005508
Recto P, Champion JD. Psychological Distress and Associated Factors Among Mexican American Adolescent Females. Hisp Health Care Int. 2016;14(4):170–6. PMID: 27852947. 10.1177/1540415316676224 27852947
Costa EC, McIntyre T, Trovisqueira A, . Comparison of two psycho-educational interventions aimed at preventing HIV and promoting sexual health among Portuguese women. International Journal of Sexual Health. 2017;29(3):258–72. PMID: 2017-42146-006. 10.1080/19317611.2017.1307300
Crosby R, DiClemente RJ, Charnigo R, . A brief, clinic-based, safer sex intervention for heterosexual African American men newly diagnosed with an STD: a randomized controlled trial. Am J Public Health. 2009;99:(Suppl 1):S96–S103. PMID: 19218185. 10.2105/AJPH.2007.123893 19218185
DiClemente RJ, Wingood GM, Harrington KF, . Efficacy of an HIV prevention intervention for African American adolescent girls: a randomized controlled trial. JAMA. 2004;292(2):171–9. PMID: 15249566. 10.1001/jama.292.2.171 15249566
Benner TA. SiHLE: Health workshops for young black women. Model Programs for Adolescent Sexual Health: Evidence-based HIV, STI and Pregnancy Prevention Interventions. 2008:253–60. PMID: None.
Kirby D. An HIV-prevention intervention for African American adolescent girls significantly increased condom use. Evidence-based Obstetrics Gynecology. 2005. PMID: None.
Lang DL, DiClemente RJ, Hardin JW, . Threats of cross-contamination on effects of a sexual risk reduction intervention: fact or fiction. Prev Sci. 2009;10(3):270–5. PMID: 19241171. 10.1007/s11121-009-0127-z 19241171
Milhausen RR, DiClemente RJ, Lang DL, . Frequency of sex after an intervention to decrease sexual risk-taking among African-American adolescent girls: Results of a randomized, controlled clinical trial. Sex Education. 2008;8:47–57. PMID: None.
Sales JM, Lang DL, Hardin JW, . Efficacy of an HIV prevention program among African American female adolescents reporting high depressive symptomatology. J Womens Health (Larchmt). 2010;19(2):219–27. PMID: 20109119. 10.1089/jwh.2008.1326 20109119
Wingood GM, DiClemente RJ, Harrington KF, . Efficacy of an HIV prevention program among female adolescents experiencing gender-based violence. Am J Public Health. 2006;96(6):1085–90. PMID: 16670238. 10.2105/AJPH.2004.053595 16670238
Ehrhardt AA, Exner TM, Hoffman S, . A gender-specific HIV/STD risk reduction intervention for women in a health care setting: short- and long-term results of a randomized clinical trial. AIDS Care. 2002;14(2):147–61. PMID: 11940275. 10.1080/09540120220104677 11940275
Dworkin SL, Beckford ST, Ehrhardt AA. Sexual scripts of women: a longitudinal analysis of participants in a gender-specific HIV/STD prevention intervention. Arch Sex Behav. 2007;36(2):269–79. PMID: 17186128. 10.1007/s10508-006-9092-9 17186128
Enrhardt AA, Exner TM, Hoffman S, . HIV/STD risk and sexual strategies among women family planning clients in New York: Project FIO. AIDS Behav. 2002;6(1):1–13. PMID: None.
Hoffman S, Exner TM, Leu CS, . Female-condom use in a gender-specific family planning clinic trial. Am J Public Health. 2003;93(11):1897–903. PMID: 14600063.14600063
Melendez RM, Hoffman S, Exner T, . Intimate partner violence and safer sex negotiation: effects of a gender-specific intervention. Arch Sex Behav. 2003;32(6):499–511. PMID: 14574094.14574094
Miller S, Exner TM, Williams SP, . A gender-specific intervention for at-risk women in the USA. AIDS Care. 2000;12(5):603–12. PMID: 11218546. 10.1080/095401200750003789 11218546
Free C, McCarthy O, French RS, . Can text messages increase safer sex behaviours in young people? Intervention development and pilot randomised controlled trial. Health Technology Assessment (Winchester, England). 2016;20(57):1–82. PMID: 27483185. 10.3310/hta20570 27483185
Guilamo-Ramos V, Bouris A, Jaccard J, . A parent-based intervention to reduce sexual risk behavior in early adolescence: building alliances between physicians, social workers, and parents. J Adolesc Health. 2011;48(2):159–63. PMID: 21257114. 10.1016/j.jadohealth.2010.06.007 21257114
Jemmott JB, III, Jemmott LS, Braverman PK, . HIV/STD risk reduction interventions for African American and Latino adolescent girls at an adolescent medicine clinic: a randomized controlled trial. Arch Pediatr Adolesc Med. 2005;159(5):440–9. PMID: 15867118. 10.1001/archpedi.159.5.440 15867118
Jemmott LS, Jemmott JB, III, O’Leary A. Effects on sexual risk behavior and STD rate of brief HIV/STD prevention interventions for African American women in primary care settings. Am J Public Health. 2007;97(6):1034–40. PMID: 17463391. 10.2105/AJPH.2003.020271 17463391
O’Leary A, Jemmott LS, Jemmott JB. Mediation analysis of an effective sexual risk-reduction intervention for women: the importance of self-efficacy. Health Psychol. 2008;27:(2 Suppl):S180–S4. PMID: 18377160. 10.1037/0278-6133.27.2(Suppl.).S180 18377160
Kershaw TS, Magriples U, Westdahl C, . Pregnancy as a window of opportunity for HIV prevention: effects of an HIV intervention delivered within prenatal care. Am J Public Health. 2009;99(11):2079–86. PMID: 19762662. 10.2105/AJPH.2008.154476 19762662
Lewis MA, Rhew IC, Fairlie AM, . Evaluating Personalized Feedback Intervention Framing with a Randomized Controlled Trial to Reduce Young Adult Alcohol-Related Sexual Risk Taking. Prev Sci. 2018. PMID: 29511966. 10.1007/s11121-018-0879-4 29511966
Marrazzo JM, Thomas KK, Ringwood K. A behavioural intervention to reduce persistence of bacterial vaginosis among women who report sex with women: results of a randomised trial. Sex Transm Infect. 2011;87(5):399–405. PMID: 21653935. 10.1136/sti.2011.049213 21653935
Marrazzo JM, Thomas KK, Agnew K, . Prevalence and risks for bacterial vaginosis in women who have sex with women. Sex Transm Dis. 2010;37(5):335–9. PMID: 20429087.20429087
Marrazzo JM, Thomas KK, Fiedler TL, . Relationship of specific vaginal bacteria and bacterial vaginosis treatment failure in women who have sex with women. Ann Intern Med. 2008;149(1):20–8. PMID: 18591634.18591634
Metsch LR, Feaster DJ, Gooden L, . Effect of risk-reduction counseling with rapid HIV testing on risk of acquiring sexually transmitted infections: the AWARE randomized controlled trial. JAMA. 2013;310(16):1701–10. PMID: 24150466. 10.1001/jama.2013.280034 24150466
Mittal M, Thevenet-Morrison K, Landau J, . An Integrated HIV Risk Reduction Intervention for Women with a History of Intimate Partner Violence: Pilot Test Results. AIDS & Behavior. 2017;21(8):2219–32. PMID: 27172976. 10.1007/s10461-016-1427-5 27172976
Morrison-Beedy D, Jones SH, Xia Y, . Reducing sexual risk behavior in adolescent girls: results from a randomized controlled trial. Journal of Adolescent Health. 2013;52(3):314–21. PMID: 23299011. 10.1016/j.jadohealth.2012.07.005 23299011
Morrison-Beedy D, Crean HF, Passmore D, . Risk reduction strategies used by urban adolescent girls in an HIV prevention trial. Current HIV Research. 2013;11(7):559–69. PMID: 24476350.24476350
Neumann MS, O’Donnell L, Doval AS, . Effectiveness of the VOICES/VOCES sexually transmitted disease/human immunodeficiency virus prevention intervention when administered by health department staff: does it work in the “real world”? Sex Transm Dis. 2011;38(2):133–9. PMID: 20729794. 10.1097/OLQ.0b013e3181f0c051 20729794
O’Cleirigh C, Safren SA, Taylor SW, . Cognitive Behavioral Therapy for Trauma and Self-Care (CBT-TSC) in Men Who have Sex with Men with a History of Childhood Sexual Abuse: A Randomized Controlled Trial. AIDS Behav. 2019. PMID: 30993478. 10.1007/s10461-019-02482-z 30993478
Peipert JF, Redding CA, Blume JD, . Tailored intervention to increase dual-contraceptive method use: a randomized trial to reduce unintended pregnancies and sexually transmitted infections. Am J Obstet Gynecol. 2008;198(6):630–8. PMID: 18395692. 10.1016/j.ajog.2008.01.038 18395692
Peipert J, Redding CA, Blume J, . Design of a stage-matched intervention trial to increase dual method contraceptive use (Project PROTECT). Contemp Clin Trials. 2007;28(5):626–37. PMID: 17374567.17374567
Peragallo Montano N, Cianelli R, Villegas N, . Evaluating a Culturally Tailored HIV Risk Reduction Intervention Among Hispanic Women Delivered in a Real-World Setting by Community Agency Personnel. Am J Health Promot. 2019;33(4):566–575. PMID: 30354190 10.1177/0890117118807716 30354190
Petersen R, Albright J, Garrett JM, . Pregnancy and STD prevention counseling using an adaptation of motivational interviewing: a randomized controlled trial. Perspect Sex Reprod Health. 2007;39(1):21–8. PMID: 17335378. 10.1363/3902107 17355378
Proude EM, D’Este C, Ward JE. Randomized trial in family practice of a brief intervention to reduce STI risk in young adults. Fam Pract. 2004;21(5):537–44. PMID: 15367476.15367476
Redding C, Prochaska J, Armstrong K, . Randomized trial outcomes of a TTM-tailored condom use and smoking intervention in urban adolescent females. Health Educ Res. 2015;30(1):162–78. PMID: 24794584 10.1093/her/cyu015 24794584
Sanci L, Chondros P, Sawyer S, . Responding to Young People’s Health Risks in Primary Care: A Cluster Randomised Trial of Training Clinicians in Screening and Motivational Interviewing. PLoS ONE. 2015;10(9):e0137581. PMID: 26422235. 10.1371/journal.pone.0137581 26422235
Scholes D, McBride CM, Grothaus L, . A tailored minimal self-help intervention to promote condom use in young women: results from a randomized trial. AIDS. 2003;17(10):1547–56. PMID: 12824793.12824793
Shafii T, Benson S, Morrison D, . Results from e-KiSs: electronic-KIOSK Intervention for Safer Sex: a pilot randomized controlled trial of an interactive computer-based intervention for sexual health in adolescents and young adults. PLoS ONE. 2019;14(1). PMID: 30673710. 10.1371/journal.pone.0209064 30673710
Shain RN, Piper JM, Holden AE, . Prevention of gonorrhea and Chlamydia through behavioral intervention: results of a two-year controlled randomized trial in minority women. Sex Transm Dis. 2004;31(7):401–8. PMID: 15215694.15215694
Champion JD, Collins JL. Comparison of a theory-based (AIDS Risk Reduction Model) cognitive behavioral intervention versus enhanced counseling for abused ethnic minority adolescent women on infection with sexually transmitted infection: results of a randomized controlled trial. Int J Nurs Stud. 2012;49(2):138–50. PMID: 21937041. 10.1016/j.ijnurstu.2011.08.010 21937041
Tzilos Wernette G, Plegue M, Kahler CW, . A Pilot Randomized Controlled Trial of a Computer-Delivered Brief Intervention for Substance Use and Risky Sex During Pregnancy. Journal of Women’s Health. 2018;27(1):83–92. PMID: 28981379. 10.1089/jwh.2017.6408 28981379
Warner L, Klausner JD, Rietmeijer CA, . Effect of a brief video intervention on incident infection among patients attending sexually transmitted disease clinics. PLoS Med. 2008;5(6):e135. PMID: 18578564. 10.1371/journal.pmed.0050135 18578564
Besera GT, Cox S, Malotte CK, . Assessing Patient Exposure to a Video-Based Intervention in STD Clinic Waiting Rooms: Findings From the Safe in the City Trial. Health promotion practice. 2016;17(5):731–8. PMID: 27091608. 10.1177/1524839916631537 27091608
Gallo MF, Margolis AD, Malotte CK, . Sexual abstinence and other behaviours immediately following a new STI diagnosis among STI clinic patients: Findings from the Safe in the City trial. Sexually Transmitted Infections. 2016;92(3):206–10. PMID: 26670913. 10.1136/sextrans-2014-051982 26670913
Gift TL, O’Donnell LN, Rietmeijer CA, . The Program Cost of a Brief Video Intervention Shown in Sexually Transmitted Disease Clinic Waiting Rooms. Sexually Transmitted Diseases. 2016;43(1):61–4. PMID: 26650999. 10.1097/OLQ.0000000000000388 26650999
Whiteley LB, Brown LK, Curtis V, . Publicly Available Internet Content as a HIV/STI Prevention Intervention for Urban Youth. Journal of Primary Prevention. 2018;39(4):361–70. PMID: 30003459. 10.1007/s10935-018-0514-y 30003459
Wingood GM, DiClemente RJ, Robinson-Simpson L, . Efficacy of an HIV intervention in reducing high-risk human papillomavirus, nonviral sexually transmitted infections, and concurrency among African American women: a randomized-controlled trial. JAIDS. 2013;63:(Suppl 1):S36–S43. PMID: 23673884. 10.1097/QAI.0b013e3182920031 23673884
Ybarra ML, Prescott TL, Phillips GL, 2nd, . Pilot RCT Results of an mHealth HIV Prevention Program for Sexual Minority Male Adolescents. Pediatrics. 2017;140(1). PMID: 28659456. 10.1542/peds.2016-2999 28659456