# Appendix B Recommendations of Others

Appendix B Table 1 Recommendations of Other Organizations for Sexual Risk Reduction Counseling to Prevent Sexually Transmitted Infections

Organization, Year | Recommendation
American Academy of Family Physicians, 2014^73^ | The AAFP recommends high-intensity behavioral counseling to prevent STIs in all sexually active adolescents and high-risk adults. The AAFP concludes the current evidence is insufficient to assess the benefits and harms of behavioral counseling to prevent STIs in pre-sexually active adolescents and in adults not at increased risk for STIs. These recommendations were based on the USPSTF 2014 Recommendation Statement.
American Academy of Pediatrics, 2014^72^ | The AAP targets several recommendations to pediatricians and other clinicians, including (1) clinicians should actively support and encourage the consistent and correct use of condoms as part of anticipatory guidance in adolescents; (2) Clinicians should promote communication between parents and adolescents about healthy sexual development and effective use of condoms; (3) Clinicians should raise awareness that making condoms available does not increase the onset or frequency of adolescent sexual activity; (4) Clinicians should provide and support parental education programs to help parents develop communication skills with their adolescent children around preventions of STIs and proper use of condoms.
American College of Obstetricians and Gynecologists, 2009-2014 | The ACOG recommends discussing contraception and STIs during an adolescent’s initial reproductive health visits and provides time-based coding recommendations for individual counseling in preventive medicine or risk factor reduction or both in individuals without a specific illness to promote health and prevention illness or injury or both.^74^ The ACOG recognizes that an annual well-women visit provides an excellent opportunity to counsel patients about maintaining a healthy lifestyle and minimizing health risks and it should include screening, evaluation and counseling and immunizations based on the patients age and risk factors.^75^ Applying principles of motivational interviewing (e.g., prompting patients to use safe sex practices and to use contraception more consistently) to daily patient practices has been proved effective in eliciting behavior change that contributes to positive health outcomes and improved patient-physician communication.^217^ Among lesbian and bisexual patients, comprehensive care including prevention of STIs is recommended.^79^ Education about the risks of STIs and dispelling the perception that transmission STIs between women is negligible will help patients make informed decisions. All patients should be encouraged to use safe sex practices to reduce the risk of transmitting or acquiring STIs and HIV such as using condoms on sex toys, gloves and dental dams as well as avoidance of sharing other sex paraphernalia. Among women of color, several approaches (e.g., gender-tailored and culturally appropriate interventions to reduce risk-taking behavior) can reduce the rate of HIV infection and optimize health.^218^ For women participating in non-coital activities, clinicians should assess patient STI risk and provide risk reduction counseling.^219^ When engaging in oral and anal sex, most individuals, including adolescents, are unlikely to use barrier protection for a variety of reasons, including a greater perceived safety of noncoital sexual activity compared with vaginal sex. Clinicians should encourage and counsel patients in the correct and consistent use of condoms, barrier protection during oral sex, and cleaning of sex toys.
Centers for Disease Control and Prevention, 2015^1^ | The CDC recommends that all providers should routinely obtain a sexual history from their patients and encourage risk-reduction using various strategies (e.g., prevention counseling). The CDC also recommends that HIV prevention counseling should be offered and encouraged in all health care facilities that serve patients at high risk (e.g., STI clinics).
National Health Care for the Homeless Council, 2010^220^ | The National Health Care for the Homeless Council recommends to counsel at-risk clients to adopt safer sexual behavior to prevent STIs (e.g., use of interactive counseling that focuses on preventing unwanted pregnancy and transmission of disease).
National Institute for Health and Clinical Excellence, 2007^80^ | After identifying individuals at high risk for STIs, NICE recommends having one-to-one structured discussions with these individuals (if the health professional is trained in sexual health) or arrange for these discussions to take place with a trained practitioner. Among vulnerable young people aged under 18 years including pregnant women and mothers, when appropriate, practitioners should provide one-to-one sexual advice on how to prevent and/or get tested for STIs.
The Society for Adolescent Health and Medicine^221^ | SAHM recommends that health care providers provide STI and HIV education, counseling, and services to all adolescents, and that these services are incorporated into well-adolescent and contraception visits.

Abbreviations: AAFP = American Academy of Family Physicians; ACOG = American College of Obstetricians and Gynecologists; HIV = human immunodeficiency virus; NICE = National Institute for Health and Clinical Excellence; SAHM = Society for Adolescent Health and Medicine; STI = sexually transmitted infection; USPSTF = U.S. Preventive Services Task Force.