# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Databases searched:

- Cochrane Central Register of Controlled Trials (CENTRAL)
- MEDLINE
- PsycInfo
- PubMed, publisher-supplied records

Key:

- / = MeSH subject heading
- $ = truncation
- * = truncation
- ab = word in abstract
- adj# = adjacent within x number of words
- hw = subject heading word
- id = key phrase identifier
- kf= keyword heading [word not phrase indexed]
- kw = keyword
- md = methodology
- pt = publication type
- ti = word in title

## CENTRAL Issue 5 of 12, May 2018

#1 (hiv or “human immune deficiency” or “human immunodeficiency” or “acquired immune deficiency” or “acquired immunodeficiency” or hepatitis or herpes* or hpv or papilloma* or warts or condyloma* or trichomonas or trichomoniasis or chlamydia* or gonorrh* or syphil*):ti,ab,kw 45685
#2 (std or stds or sti or stis):ti,ab,kw 1861
#3 sexual*:ti,ab,kw next transmi*:ti,ab,kw 2143
#4 (“safe sex” or “unsafe sex” or “risky sex” or “risky sexual”):ti,ab,kw 924
#5 #1 or #2 or #3 or #4 47000
#6 (“health promotion” or “health education” or “patient education”):ti,ab,kw 24715
#7 (counsel* or advise or advice):ti,ab,kw 20469
#8 (motivational next interview*):ti,ab,kw 2460
#9 (prevent* next intervention*):ti,ab,kw 2648
#10 (“cognitive therapy” or CBT):ti,ab,kw 12452
#11 (physician* near/2 role):ti,ab,kw 278
#12 “preventive health services”:ti,ab,kw 655
#13 “student health services”:ti,ab,kw 65
#14 “teaching materials”:ti,ab,kw 461
#15 “client education”:ti,ab,kw 8
#16 (behavio* next intervention*):ti,ab,kw 4046
#17 (behavio* next therapy):ti,ab,kw 14148
#18 (behavio* next change*):ti,ab,kw 5217
#19 (behavio* next modification*):ti,ab,kw 1023
#20 “preventive medicine”:ti,ab,kw 594
#21 (health next behavio*):ti,ab,kw 6300
#22 intervention*:ti,ab,kw 186690
#23 #21 and #22 4586
#24 (lifestyle next change*):ti,ab,kw 1275
#25 #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #23 or #24 69192
#26 #5 and #25 Publication Year from 2013 to 2018 1702

## MEDLINE (via Ovid)

Database: Ovid MEDLINE(R) <1946 to June Week 3 2018>, Ovid MEDLINE(R) Epub Ahead of Print <June 20, 2018>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <June 20, 2018>, Ovid MEDLINE(R) Daily Update <June 20, 2018>

------------------------------------------------------------

1. HIV Infections/ (174246)
2. Acquired Immunodeficiency Syndrome/ (75170)
3. Hepatitis B/ (40887)
4. Hepatitis B, Chronic/ (13618)
5. Hepatitis C/ (37300)
6. Hepatitis C, Chronic/ (21801)
7. Herpes Simplex/ (13711)
8. Herpes Genitalis/ (4482)
9. Herpes Labialis/ (1149)
10. Condylomata Acuminata/ (5012)
11. Warts/ (4363)
12. Chlamydia Infections/ (14641)
13. Gonorrhea/ (13176)
14. Syphilis/ (20855)
15. Papillomavirus Infections/ (21862)
16. Human papillomavirus 6/ (387)
17. Human papillomavirus 11/ (346)
18. Human papillomavirus 16/ (4034)
19. Human papillomavirus 18/ (1600)
20. Trichomonas Infections/ (3134)
21. Trichomonas Vaginitis/ (3412)
22. Sexually Transmitted Diseases/ (23085)
23. Sexually Transmitted Diseases, Bacterial/ (973)
24. Sexually Transmitted Diseases, Viral/ (1397)
25. (hiv or human immune deficiency or human immunodeficiency or acquired immune deficiency or acquired immunodeficiency).ti,ab,kf. (313255)
26. (hepatitis or herpes or warts or chlamydia or gonorrh$ or syphilis).ti,ab,kf. (323151)
27. (sexually transmitted or std or stds or sti or stis).ti,ab,kf. (39014)
28. (papilloma$ or hpv or trichomonas or trichomoniasis).ti,ab,kf. (68847)
29. condyloma$.ti,ab,kf. (4209)
30. or/1-29 (764140)
31. health promotion/ (66451)
32. Health Education/ (57715)
33. patient education/ (79706)
34. counseling/ (33085)
35. directive counseling/ (2103)
36. “Acceptance and Commitment Therapy”/ (234)
37. Mindfulness/ (1844)
38. Cognitive Remediation/ (128)
39. cognitive therapy/ (21903)
40. behavior therapy/ (26196)
41. physician’s role/ (28594)
42. preventive health services/ (12452)
43. student health services/ (3035)
44. teaching materials/ (6261)
45. counsel$.ti,ab,kf. (94968)
46. advice.ti,ab,kf. (42272)
47. advise.ti,ab,kf. (8327)
48. motivational interview$.ti,ab,kf. (3422)
49. prevent$ intervention$.ti,ab,kf. (11766)
50. (physician$ adj2 role).ti,ab,kf. (2555)
51. preventive health services.ti,ab,kf. (667)
52. student health services.ti,ab,kf. (246)
53. teaching materials.ti,ab,kf. (690)
54. client education.ti,ab,kf. (205)
55. health promotion.ti,ab,kf. (28016)
56. health education.ti,ab,kf. (30382)
57. patient education.ti,ab,kf. (16217)
58. cognitive therapy.ti,ab,kf. (2742)
59. behavio$ therapy.ti,ab,kf. (18209)
60. behavio$ intervention$.ti,ab,kf. (8774)
61. behavio$ change$.ti,ab,kf. (29944)
62. behavio$ modification$.ti,ab,kf. (4296)
63. preventive medicine.ti,ab,kf. (7684)
64. (health behavio$ and intervention$).ti,ab,kf. (6406)
65. lifestyle change$.ti,ab,kf. (6713)
66. or/31-65 (511424)
67. 30 and 66 (35207)
68. Safe Sex/ (2779)
69. Unsafe Sex/ (4226)
70. Sexual Behavior/ (50951)
71. safe sex.ti,ab,kf. (1268)
72. unsafe sex.ti,ab,kf. (689)
73. risky sex$.ti,ab,kf. (2912)
74. 68 or 69 or 70 or 71 or 72 or 73 (57281)
75. 66 and 74 (10251)
76. HIV Infections/pc (33258)
77. Acquired Immunodeficiency Syndrome/pc (13392)
78. Hepatitis B/pc (10080)
79. Hepatitis B, Chronic/pc (619)
80. Hepatitis C/pc (3150)
81. Hepatitis C, Chronic/pc (335)
82. Herpes Simplex/pc (963)
83. Herpes Genitalis/pc (786)
84. Herpes Labialis/pc (106)
85. Condylomata Acuminata/pc (424)
86. Warts/pc (37)
87. Chlamydia Infections/pc (1572)
88. Gonorrhea/pc (1114)
89. Syphilis/pc (1249)
90. Papillomavirus Infections/pc (5034)
91. Trichomonas Infections/pc (78)
92. Trichomonas Vaginitis/pc (109)
93. Sexually Transmitted Diseases/pc (8704)
94. Sexually Transmitted Diseases, Bacterial/pc (180)
95. Sexually Transmitted Diseases, Viral/pc (458)
96. 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 (71292)
97. intervention$.ti,ab,kf,hw. (857306)
98. 96 and 97 (10230)
99. 67 or 75 or 98 (42929)
100. (clinical trial or controlled clinical trial or randomized controlled trial or adaptive clinical trial or equivalence clinical trial or pragmatic clinical trial or meta analysis).pt. (868580)
101. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or adaptive clinical trials as topic/ or equivalence clinical trials as topic/ or pragmatic clinical trials as topic/ (301422)
102. Meta-Analysis as Topic/ (16255)
103. Random allocation/ (94679)
104. clinical trial$.ti,ab,kf. (314050)
105. (control$ adj3 (study or studies or trial$)).ti,ab,kf. (450888)
106. random$.ti,ab,kf. (982943)
107. trial.ti. (183333)
108. 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 (1963179)
109. 99 and 108 (6612)
110. limit 109 to (english language and yr="2013 -Current") (2412)
111. remove duplicates from 110 (2407)

## PsycINFO (via Ovid)

Database: PsycINFO <1806 to June Week 3 2018>

------------------------------------------------------------

1. sexually transmitted diseases/ (4203)
2. Acquired Immune Deficiency Syndrome/ (15045)
3. Human Immunodeficiency Virus/ (32806)
4. GONORRHEA/ (155)
5. HERPES GENITALIS/ (155)
6. HERPES SIMPLEX/ (962)
7. AIDS Prevention/ (8200)
8. SYPHILIS/ (404)
9. HEPATITIS/ (2499)
10. Human Papillomavirus/ (1162)
11. Sexual Risk Taking/ (7752)
12. safe sex/ (1405)
13. Psychosexual Behavior/ (24060)
14. sexually transmitted.ti,ab,id. (7451)
15. (hiv or human immune deficiency or human immunodeficiency or acquired immune deficiency or acquired immunodeficiency).ti,ab,id. (50028)
16. hepatitis b.ti,ab,id. (1106)
17. hepatitis c.ti,ab,id. (2556)
18. herpes.ti,ab,id. (2009)
19. condyloma$.ti,ab,id. (28)
20. warts.ti,ab,id. (336)
21. chlamydia.ti,ab,id. (844)
22. gonorrh$.ti,ab,id. (730)
23. papillomavirus.ti,ab,id. (1303)
24. hpv.ti,ab,id. (1452)
25. (trichomonas or trichomoniasis).ti,ab,id. (171)
26. syphilis.ti,ab,id. (1604)
27. (safe sex or unsafe sex or risky sex or risky sexual).ti,ab,id. (4433)
28. or/1-27 (82914)
29. Health Education/ (12222)
30. Health Promotion/ (22491)
31. Cognitive behavior therapy/ (17112)
32. Behavior Therapy/ (13373)
33. Behavior Change/ (11343)
34. Behavior Modification/ (10248)
35. Client Education/ (3672)
36. Counseling/ (22129)
37. Preventive Medicine/ (2023)
38. Motivational interviewing/ (2157)
39. student personnel services/ (2223)
40. Lifestyle Changes/ (1176)
41. advice.ti,ab,id. (18998)
42. advise.ti,ab,id. (2042)
43. counsel$.ti,ab,id,hw. (117277)
44. motivational interview$.ti,ab,id. (3318)
45. prevention intervention$.ti,ab,id. (4524)
46. preventive health services.ti,ab,id. (185)
47. (physician$ adj2 role).ti,ab,id. (805)
48. student health services.ti,ab,id. (61)
49. teaching materials.ti,ab,id. (642)
50. client education.ti,ab,id. (205)
51. health promotion.ti,ab,id. (17905)
52. health education.ti,ab,id. (9566)
53. patient education.ti,ab,id. (3219)
54. cognitive therapy.ti,ab,id. (6340)
55. behavio$ therapy.ti,ab,id. (30155)
56. behavio$ intervention$.ti,ab,id. (10809)
57. behavio$ change$.ti,ab,id. (24459)
58. behavio$ modification$.ti,ab,id. (5943)
59. preventive medicine.ti,ab,id. (827)
60. Health Behavior/ and intervention$.ti,ab,id,hw. (6589)
61. lifestyle change$.ti,ab,id. (2075)
62. or/29-61 (276332)
63. 28 and 62 (14307)
64. random$.ti,ab,id,hw. (179259)
65. (control$ adj3 (study or studies or trial$)).ti,ab,id,hw. (73591)
66. clinical trial$.ti,ab,id,hw. (34378)
67. trial.ti. (26134)
68. (treatment outcome or clinical trial).md. (39450)
69. 64 or 65 or 66 or 67 or 68 (244261)
70. 63 and 69 (1941)
71. limit 70 to english language (1908)
72. limit 71 to yr="2013 -Current" (728)

## Pubmed, publisher-supplied

#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #14 AND English[Language] AND (“2013/01/01”[Date - Publication] : “3000”[Date - Publication])
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #13 AND publisher[sb]
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #12 AND (trial[tiab] OR trials[tiab] OR random*[tiab] OR metaanaly*[tiab] OR “meta analysis”[tiab] OR “meta analyses”[tiab] OR “meta analytic”[tiab] OR systematic[tiab])
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND #11
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search motivational[tiab] AND interview*[tiab]
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (prevention[tiab] OR preventive[tiab]) AND intervention*[tiab]
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search advice[tiab] or advise[tiab]
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “preventive health services”[tiab] OR “student health services”[tiab]
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “behavior change”[tiab] OR “behavioral change”[tiab] OR “behaviour change”[tiab] OR “behavioural change”[tiab] OR “behavior modification”[tiab] OR “behavioral modification”[tiab] OR “behaviour modification”[tiab] OR “behavioural modification”[tiab] OR lifestyle change*[tiab]
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search behavio*[tiab] AND (therapy[tiab] OR intervention*[tiab])
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “cognitive therapy”[tiab] OR cbt[tiab]
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search counsel*[tiab]
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health promotion”[tiab] OR “Health Education”[tiab] OR “patient education”[tiab] OR “client education”[tiab] OR “teaching materials”[tiab] OR “physician role”[tiab] OR “physician’s role”[tiab] OR “physicians’ role”[tiab]
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search hiv[tiab] OR “human immunodeficiency”[tiab] OR “human immune deficiency”[tiab] OR “acquired immunodeficiency”[tiab] OR “acquired immune deficiency”[tiab] OR “Hepatitis B”[tiab] OR “Hepatitis C”[tiab] OR Herpes[tiab] OR warts[tiab] OR condyloma*[tiab] OR Papilloma*[tiab] OR hpv[tiab] OR Chlamydia[tiab] OR Gonorrhea[tiab] OR Gonorrhoea[tiab] OR Syphilis[tiab] OR Trichomonas[tiab] OR trichomoniasis[tiab] OR “safe sex”[tiab] OR “unsafe sex”[tiab] OR “risky sex”[tiab] OR “risky sexual”[tiab] OR “Sexually Transmitted”[tiab] OR std[tiab] OR stds[tiab] OR sti[tiab] OR stis[tiab]

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | Studies targeting sexual behavior change to prevent STIs | Studies aimed solely at targeting behavior change to prevent unintended pregnancy or solely to change behaviors associated with risky sexual behavior (e.g., substance use disorders, interpersonal violence)
Condition | Any infection that is transmitted through sexual contact (i.e., oral, vaginal, or anal), including, but not limited to: HIV, human papillomavirus (HPV), herpes simplex virus (HSV) type 1 and 2, hepatitis b and c viruses, Zika virus, chlamydia, gonorrhea, syphilis, and trichomoniasis. | Infections acquired through non-sexual transmission routes (e.g., maternal-fetal transmission, blood transfusions, inadvertent needle sticks, sharing needles or injection equipment with an infected person)
Population | Adolescents and adults of any sexual orientation; People who are sexually active; Pregnant women; People who are not sexually active (e.g., adolescents before sexual debut) | Studies limited to populations requiring specialized health care or interventions to address STI health risks (e.g., HIV sero-discordant couples, commercial sex workers)
Interventions | Interventions involving behavioral counseling to prevent or reduce STIs (i.e., some provision of education, skills training, or guidance on how to change sexual behaviors) delivered alone or in combination with other interventions intended to promote sexual risk reduction or risk avoidance, which can feasibly be implemented in or referred from primary care. Interventions may include, but are not limited to:; Individual-, family-, couple-, or group-based counseling (e.g., motivational interviewing, cognitive behavioral therapy); Waiting room, multimedia, or other health system-based behavior change interventions; Telemedicine or technology-based behavior change interventions (e.g., text messages, Internet-based) | Trials within closed pre-existing social networks (e.g., worksite or church programs); Social marketing (e.g., media campaigns); Policy (e.g., State or local public or health policy; health care delivery); Circumcision to prevent HIV/STI; circumcision counseling; Solely focused on biomedical prevention interventions (e.g., HPV vaccination, Pre-exposure Prophylaxis for HIV); STI testing only; Sexual abuse prevention; Cash and voucher reward-based incentives for behavior change (e.g., condom use); Counseling to increase partner referral/notification only; Promoting non-condom contraceptive use only
Comparators | No intervention (e.g., waitlist); Usual care; Minimal intervention (e.g., usual care limited to ≤15 minutes of information); Attention control (e.g., similar in format and intensity but intervention is on a different content area, such as general sex education, wellness promotion, or nutrition education) | Active intervention (i.e., comparative effectiveness)
Outcomes | KQ 1 (Health outcomes):; STI incidence (based on testing/biologic confirmation); Morbidity and mortality, including:; STI related cancers (e.g., liver, oral, cervical, vulvar, vaginal, anal, penile); Oral and genital lesions; Pelvic and genitourinary pain; Chronic conditions (e.g., AIDS, neurosyphilis, chronic liver disease); Reproductive complications (e.g., pelvic inflammatory disease, ectopic pregnancy, spontaneous abortion, infertility); Perinatal and infant morbidity/mortality (e.g., neonatal infection, stillbirth, low birth weight, ophthalmia neonatorum, neurologic damage, congenital abnormalities); Mental health; Quality of life; KQ 2 (Behavioral outcomes):; Changes in STI risk behaviors (e.g., multiple sexual partners, concurrent sexual partners, sexual partners with high STI risk, unprotected sexual intercourse or contact, sex while intoxicated with alcohol or other substances, sex in exchange for money or drugs); Changes in protective behaviors (e.g., sexual abstinence, mutual monogamy, delayed initiation of intercourse or age of sexual debut, use of condoms, other barrier methods, chemical barriers, or other changes in sexual behavior); KQ 3 (Harms):; Increase in STI incidence or risky sexual behaviors or decrease in protective behaviors; Health care avoidance; Psychological harms (e.g., anxiety, shame, guilt, feelings of stigma); Unintended pregnancy | Self-reported measures of infection, attitude, knowledge, ability, or self-efficacy, including:; Knowledge of risks and protective behaviors; Perception of STI risk in self or partners; Perceived relationship power; Sexual negotiation skills; Scheduling a health care appointment; Intention to use protective barriers; Carrying barrier protection
Setting | Conducted in or recruited from primary care settings, including:; Health care systems; STI clinics; Family planning clinics; School-based health clinics; Prenatal care clinics; Military health clinics; Obstetrics-gynecology clinics; Behavioral/mental health clinics. | Research laboratories; Correctional facilities; School classrooms; Worksites; Substance abuse treatment facilities or methadone maintenance clinics; Inpatient/residential facilities; Emergency departments
Study design | Randomized, controlled trials and nonrandomized, controlled trials (controlled clinical trials) | Observational studies; comparative effectiveness trials without a control group
Timing of outcome assessment | ≥ 3 months postbaseline | < 3 months postbaseline
Publication date | Published after 1999 (2000 to present) | Published in or before 1999
Country | Studies conducted in countries categorized as “Very High” on the 2016 Human Development Index (as defined by the United Nations Development Programme) | Countries with a Human Development Index other than “Very High”
Language | English only | Non-English publications
Study quality | Fair- or good-quality studies | Poor-quality studies (according to design-specific USPSTF criteria)

Abbreviations: AIDS = acquired immunodeficiency syndrome; HIV = human immunodeficiency virus; HSV = herpes simplex virus; KQ = key question; STI = sexually transmitted infections; USPSTF = U.S. Preventive Services Task Force.

Appendix A Table 2 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods | Bias arising in the randomization process or due to confounding; Valid random assignment/random sequence generation method used; Allocation concealed; Balance in baseline characteristics; Bias in selecting participants into the study; CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; Fidelity to the intervention protocol; Low risk of contamination between groups; Participants were analyzed as originally allocated; Bias from missing data; No, or minimal, post-randomization exclusions; Outcome data are reasonably complete and comparable between groups; Reasons for missing data are similar across groups; Missing data are unlikely to bias results; Bias in measurement of outcomes; Blinding of outcome assessors; Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; No evidence of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Appendix A Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 4,583 citations identified through literature databases. An additional 4 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, and 62 citations were from the 2014 USPSTF Behavioral Counseling to Prevent Sexually Transmitted Infections review. After duplicates were removed, 4,649 unique citations were screened at the title/abstract stage. The full text of 273 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=21), Key Question 2 (k=34), Key Question 3 (k=7). Reasons for excluding the other articles are available in Appendix D.