# References

1 Calonge N, Petitti DB, DeWitt TG, . Screening for bacterial vaginosis in pregnancy to prevent preterm delivery: US Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;148(3):214–9.18252683
2 Nygren P, Fu R, Freeman M, . Screening and treatment for bacterial vaginosis in pregnancy: systematic review to update the 2001 US Preventive Services Task Force recommendation. Ann Intern Med. 2008 January;148(3):214–9. PMID: 18252683.18252683
3 Nygren P, Fu R, Freeman M, . Evidence on the benefits and harms of screening and treating pregnant women who are asymptomatic for bacterial vaginosis: an update review for the U.S. Preventive Services Task Force. Ann Intern Med. 2008 Feb 5;148(3):220–33. doi: 10.7326/0003-4819-148-3-200802050-00008. PMID: 18758800.18252684
4 Srinivasan S, Fredricks DN. The human vaginal bacterial biota and bacterial vaginosis. Interdiscip Perspect Infect Dis. 2008;2008: 750479.19282975
5 Livengood CH. Bacterial vaginosis: an overview for 2009. Rev Obstet Gynecol. 2009 Winter;2(1):28–37. PMID: 19399292.19399292
6 Martin DH. The microbiota of the vagina and its influence on women’s health and disease. Am J Med Sci. 2012 Jan;343(1):2–9. doi: 10.1097/MAJ.0b013e31823ea228. PMID: 22143133.22143133
7 Lamont RF, Sobel JD, Akins RA, . The vaginal microbiome: new information about genital tract flora using molecular based techniques. BJOG. 2011 Apr;118(5):533–49. doi: 10.1111/j.1471-0528.2010.02840.x. PMID: 21251190.21251190
8 Quinn J-A, Munoz FM, Gonik B, . Preterm birth: case definition and guidelines for data collection, analysis, and presentation of immunisation safety data. Vaccine. 2016;34(49):6047–56. doi: 10.1016/j.vaccine.2016.03.045. PMID: PMC5139808.27743648
9 Marlow N. Full term; an artificial concept. Arch Dis Child Fetal Neonatal Ed. 2012 May;97(3):F158–9. doi: 10.1136/fetalneonatal-2011-301507. PMID: 22262663.22262663
10 Bradshaw CS, Sobel JD. Current treatment of bacterial vaginosis-limitations and need for innovation. J Infect Dis. 2016 Aug 15;214 Suppl 1:S14–20. doi: 10.1093/infdis/jiw159. PMID: 27449869.27449869
11 Allsworth JE, Peipert JF. Prevalence of bacterial vaginosis: 2001-2004 National Health and Nutrition Examination Survey data. Obstet Gynecol. 2007 Jan;109(1):114–20. doi: 10.1097/01.AOG.0000247627.84791.91. PMID: 17197596.17197596
12 Vodstrcil LA, Walker SM, Hocking JS, . Incident bacterial vaginosis (BV) in women who have sex with women is associated with behaviors that suggest sexual transmission of BV. Clin Infect Dis. 2015 Apr 01;60(7):1042–53. doi: 10.1093/cid/ciu1130. PMID: 25516188.25516188
13 Kenyon C, Colebunders R, Crucitti T. The global epidemiology of bacterial vaginosis: a systematic review. Am J Obstet Gynecol. 2013 Dec;209(6):505–23. doi: 10.1016/j.ajog.2013.05.006. PMID: 23659989.23659989
14 Amsel R, Totten PA, Spiegel CA, . Nonspecific vaginitis: diagnostic criteria and microbial and epidemiologic associations. Am J Med. 1983;74(1):14–22.6600371
15 American Congress of Obstetricans and Gynecologists. ACOG Practice Bulletin. Clinical management guidelines for obstetrician-gynecologists, Number 72, May 2006: vaginitis (Reaffirmed 2017). Obstet Gynecol. 2006 May;107(5):1195–206. PMID: 16648432.16648432
16 Klebanoff MA, Schwebke JR, Zhang J, . Vulvovaginal symptoms in women with bacterial vaginosis. Obstet Gynecol. 2004 Aug;104(2):267–72. doi: 10.1097/01.AOG.0000134783.98382.b0. PMID: 15291998.15291998
17 Bradshaw CS, Morton AN, Hocking J, . High recurrence rates of bacterial vaginosis over the course of 12 months after oral metronidazole therapy and factors associated with recurrence. J Infect Dis. 2006 Jun 01;193(11):1478–86. doi: 10.1086/503780. PMID: 16652274.16652274
18 Bilardi JE, Walker S, Temple-Smith M, . The burden of bacterial vaginosis: women’s experience of the physical, emotional, sexual and social impact of living with recurrent bacterial vaginosis. PLoS One. 2013;8(9):e74378. doi: 10.1371/journal.pone.0074378. PMID: 24040236.24040236
19 Verstraelen H, Verhelst R, Vaneechoutte M, . The epidemiology of bacterial vaginosis in relation to sexual behaviour. BMC Infect Dis. 2010 Mar 30;10:81. doi: 10.1186/1471-2334-10-81. PMID: 20353563.20353563
20 Ralph SG, Rutherford AJ, Wilson JD. Influence of bacterial vaginosis on conception and miscarriage in the first trimester: cohort study. BMJ. 1999 Jul 24;319(7204):220–3. PMID: 10417083.10417083
21 McGregor JA, French JI, Parker R, . Prevention of premature birth by screening and treatment for common genital tract infections: results of a prospective controlled evaluation. Am J Obstet Gynecol. 1995 Jul;173(1):157–67. PMID: 7631673.7631673
22 Taylor BD, Darville T, Haggerty CL. Does bacterial vaginosis cause pelvic inflammatory disease? Sex Transm Dis. 2013 Feb;40(2):117–22. doi: 10.1097/OLQ.0b013e31827c5a5b. PMID: 23324974.23324974
23 Achilles SL, Reeves MF. Prevention of infection after induced abortion: release date October 2010: SFP guideline 20102. Contraception. 2011 Apr;83(4):295–309. doi: 10.1016/j.contraception.2010.11.006. PMID: 21397086.21397086
24 Watts DH, Krohn MA, Hillier SL, . Bacterial vaginosis as a risk factor for post-cesarean endometritis. Obstet Gynecol. 1990 Jan;75(1):52–8. PMID: 2296423.2296423
25 Hillier SL, Nugent RP, Eschenbach DA, . Association between bacterial vaginosis and preterm delivery of a low-birth-weight infant. N Engl J Med. 1995;333(26):1737–42.7491137
26 Blencowe H, Cousens S, Oestergaard MZ, . National, regional, and worldwide estimates of preterm birth rates in the year 2010 with time trends since 1990 for selected countries: a systematic analysis and implications. Lancet. 2012 2012/06/09/;379(9832):2162–72. doi: 10.1016/S0140-6736(12)60820-4.22682464
27 Mathews T, MacDorman MF, Thoma ME. Infant mortality statistics from the 2013 period linked birth/infant death data set. 2015.
28 Schindler T, Koller-Smith L, Lui K, . Causes of death in very preterm infants cared for in neonatal intensive care units: a population-based retrospective cohort study. BMC Pediatr. 2017;17(1):59.28222717
29 Hamilton BE, Martin JA, Osterman MJK, . Births: provisional data for 2018. Vital Statistics Rapid Release; no 7. Hyattsville, MD: National Center for Health Statistics; 2019. https://www.cdc.gov/nchs/data/vsrr/vsrr-007-508.pdf.
30 McIntire DD, Leveno KJ. Neonatal mortality and morbidity rates in late preterm births compared with births at term. Obstet Gynecol. 2008;111(1):35–41.18165390
31 Savitz DA, Blackmore CA, Thorp JM. Epidemiologic characteristics of preterm delivery: etiologic heterogeneity. Am J Obstet Gynecol. 1991 Feb;164(2):467–71. PMID: 1992685.1992685
32 Allen MC. Neurodevelopmental outcomes of preterm infants. Curr Opin Neurol. 2008 Apr;21(2):123–8. doi: 10.1097/WCO.0b013e3282f88bb4. PMID: 18317268.18317268
33 Blencowe H, Cousens S, Chou D, . Born too soon: the global epidemiology of 15 million preterm births. Reprod Health. 2013;10:(Suppl 1):S2. doi: 10.1186/1742-4755-10-s1-s2. PMID: 24625129.24625129
34 Behrman R, Butler A. Preterm birth: causes consequences and prevention. Committee on Understanding Premature Birth and Assuring Health Outcomes, Institute of Medicine of the National Academies. Washington DC: National Academies Press; 2006.
35 Martin DH, Marrazzo JM. The vaginal microbiome: current understanding and future directions. J Infect Dis. 2016 Aug 15;214 Suppl 1:S36–41. doi: 10.1093/infdis/jiw184. PMID: 27449871.27449871
36 Lewis FM, Bernstein KT, Aral SO. Vaginal microbiome and its relationship to behavior, sexual health, and sexually transmitted diseases. Obstet Gynecol. 2017 Apr;129(4):643–54. doi: 10.1097/aog.0000000000001932. PMID: 28277350.28277350
37 Turovskiy Y, Sutyak Noll K, Chikindas ML. The aetiology of bacterial vaginosis. J Appl Microbiol. 2011 May;110(5):1105–28. doi: 10.1111/j.1365-2672.2011.04977.x. PMID: 21332897.21332897
38 Coleman JS, Gaydos CA. Molecular diagnosis of bacterial vaginosis: an update. J Clin Microbiol. 2018 Sep;56(9) doi: 10.1128/jcm.00342-18. PMID: 29769280.29769280
39 Machado A, Cerca N. Influence of biofilm formation by gardnerella vaginalis and other anaerobes on bacterial vaginosis. J Infect Dis. 2015 Dec 15;212(12):1856–61. doi: 10.1093/infdis/jiv338. PMID: 26080369.26080369
40 Swidsinski A, Mendling W, Loening-Baucke V, . Adherent biofilms in bacterial vaginosis. Obstet Gynecol. 2005 Nov;106(5 Pt 1):1013–23. doi: 10.1097/01.AOG.0000183594.45524.d2. PMID: 16260520.16260520
41 Muzny CA, Schwebke JR. Pathogenesis of bacterial vaginosis: discussion of current hypotheses. J Infect Dis. 2016 Aug 15;214 Suppl 1:S1–5. doi: 10.1093/infdis/jiw121. PMID: 27449868.27449868
42 Unemo M, Bradshaw CS, Hocking JS, . Sexually transmitted infections: challenges ahead. Lancet Infect Dis. 2017 Aug;17(8):e235–e79. doi: 10.1016/s1473-3099(17)30310-9. PMID: 28701272.28701272
43 Tabrizi SN, Fairley CK, Bradshaw CS, . Prevalence of Gardnerella vaginalis and Atopobium vaginae in virginal women. Sex Transm Dis. 2006 Nov;33(11):663–5. doi: 10.1097/01.olq.0000216161.42272.be. PMID: 17374511.16601662
44 Fethers KA, Fairley CK, Morton A, . Early sexual experiences and risk factors for bacterial vaginosis. J Infect Dis. 2009 Dec 1;200(11):1662–70. doi: 10.1086/648092. PMID: 19863439.19863439
45 Schwebke JR, Desmond R. Risk factors for bacterial vaginosis in women at high risk for sexually transmitted diseases. Sex Transm Dis. 2005;32(11):654–8.16254538
46 Murphy K, Mitchell CM. The interplay of host immunity, environment and the risk of bacterial vaginosis and associated reproductive health outcomes. J Infect Dis. 2016 Aug 15;214 Suppl 1:S29–35. doi: 10.1093/infdis/jiw140. PMID: 27056955.27056955
47 Kenyon CR, Delva W, Brotman RM. Differential sexual network connectivity offers a parsimonious explanation for population-level variations in the prevalence of bacterial vaginosis: a data-driven, model-supported hypothesis. BMC Womens Health. 2019 Jan 10;19(1):8. doi: 10.1186/s12905-018-0703-0. PMID: 30630481.30630481
48 Godha K, Tucker KM, Biehl C, . Human vaginal pH and microbiota: an update. Gynecol Endocrinol. 2017 Dec 22:1–5. doi: 10.1080/09513590.2017.1407753. PMID: 29271266.29271266
49 Neggers YH, Nansel TR, Andrews WW, . Dietary intake of selected nutrients affects bacterial vaginosis in women. J Nutr. 2007 Sep;137(9):2128–33. PMID: 17709453.17709453
50 Leitich H, Kiss H. Asymptomatic bacterial vaginosis and intermediate flora as risk factors for adverse pregnancy outcome. Best Pract Res Clin Obstet Gynaecol. 2007 Jun;21(3):375–90. doi: 10.1016/j.bpobgyn.2006.12.005. PMID: WOS:000247462000004.17241817
51 Goldenberg RL, Culhane JF, Iams JD, . Epidemiology and causes of preterm birth. Lancet. 2008 2008/01/05/;371(9606):75–84. doi: 10.1016/S0140-6736(08)60074-4.18177778
52 Muglia LJ, Katz M. The enigma of spontaneous preterm birth. N Engl J Med. 2010 Feb 11;362(6):529–35. doi: 10.1056/NEJMra0904308. PMID: 20147718.20147718
53 Mercer BM, Goldenberg RL, Moawad AH, . The preterm prediction study: effect of gestational age and cause of preterm birth on subsequent obstetric outcome. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. 1999 Nov;181(5 Pt 1):1216–21. PMID: 10561648.10561648
54 To MS, Skentou CA, Royston P, . Prediction of patient-specific risk of early preterm delivery using maternal history and sonographic measurement of cervical length: a population-based prospective study. Ultrasound Obstet Gynecol. 2006 Apr;27(4):362–7. doi: 10.1002/uog.2773. PMID: 16565989.16565989
55 Berghella V, Roman A, Daskalakis C, . Gestational age at cervical length measurement and incidence of preterm birth. Obstet Gynecol. 2007;110(2, Part 1):311–7.17666605
56 Romero R, Conde-Agudelo A, Da Fonseca E, . Vaginal progesterone for preventing preterm birth and adverse perinatal outcomes in singleton gestations with a short cervix: a meta-analysis of individual patient data. Am J Obstet Gynecol. doi: 10.1016/j.ajog.2017.11.576.
57 Slyker JA, Patterson J, Ambler G, . Correlates and outcomes of preterm birth, low birth weight, and small for gestational age in HIV-exposed uninfected infants. BMC Pregnancy Childbirth. 2014 Jan 8;14:7. doi: 10.1186/1471-2393-14-7. PMID: 24397463.24397463
58 Shapiro GD, Fraser WD, Frasch MG, . Psychosocial stress in pregnancy and preterm birth: associations and mechanisms. J Perinat Med. 2013 Nov;41(6):631–45. doi: 10.1515/jpm-2012-0295. PMID: 24216160.24216160
59 Kajeepeta S, Sanchez SE, Gelaye B, . Sleep duration, vital exhaustion, and odds of spontaneous preterm birth: a case-control study. BMC Pregnancy Childbirth. 2014 Sep 27;14:337. doi: 10.1186/1471-2393-14-337. PMID: 25261975.25261975
60 Shah NR, Bracken MB. A systematic review and meta-analysis of prospective studies on the association between maternal cigarette smoking and preterm delivery. Am J Obstet Gynecol. 2000 Feb;182(2):465–72. PMID: 10694353.10694353
61 Ide M, Papapanou PN. Epidemiology of association between maternal periodontal disease and adverse pregnancy outcomes-systematic review. J Periodontol. 2013 Apr;84:(4 Suppl):S181–94. doi: 10.1902/jop.2013.134009. PMID: 23631578.23631578
62 Fiscella K. Racial disparities in preterm births. The role of urogenital infections. Public Health Rep. 1996 Mar-Apr;111(2):104–13. PMID: 8606905.8606905
63 Nugent RP, Krohn MA, Hillier SL. Reliability of diagnosing bacterial vaginosis is improved by a standardized method of gram stain interpretation. J Clin Microbiol. 1991;29(2):297–301.1706728
64 Ison CA, Hay PE. Validation of a simplified grading of Gram stained vaginal smears for use in genitourinary medicine clinics. Sex Transm Infect. 2002;78(6):413–5. doi: 10.1136/sti.78.6.413.12473800
65 Gaydos CA, Beqaj S, Schwebke JR, . Clinical validation of a test for the diagnosis of vaginitis. Obstet Gynecol. 2017 Jul;130(1):181–9. doi: 10.1097/aog.0000000000002090. PMID: 28594779.28594779
66 Plummer EL, Garland SM, Bradshaw CS, . Molecular diagnosis of bacterial vaginosis: does adjustment for total bacterial load or human cellular content improve diagnostic performance? J Microbiol Methods. 2017 Feb;133:66–8. doi: 10.1016/j.mimet.2016.12.024. PMID: 28042056.28042056
67 Rumyantseva T, Shipitsyna E, Guschin A, . Evaluation and subsequent optimizations of the quantitative AmpliSens Florocenosis/Bacterial vaginosis-FRT multiplex real-time PCR assay for diagnosis of bacterial vaginosis. APMIS. 2016 Dec;124(12):1099–108. doi: 10.1111/apm.12608. PMID: 27714844.27714844
68 Hoffman MK, Bellad MB, Charantimath US, . A comparison of colorimetric assessment of vaginal pH with Nugent score for the detection of bacterial vaginosis. Infect Dis Obstet Gynecol. 2017;2017:1040984. doi: 10.1155/2017/1040984. PMID: 28293099.28293099
69 Hay P, Tummon A, Ogunfile M, . Evaluation of a novel diagnostic test for bacterial vaginosis: ‘the electronic nose’. Int J STD AIDS. 2003 Feb;14(2):114–8. doi: 10.1258/095646203321156881. PMID: 12662390.12662390
70 Scherf U. Letter to Dr. Patricia Dionne, GeneOhm Sciences Canada, Inc. (BD Diagnostics). Silver Spring, MD: Department of Health & Human Services, Food and Drug Administration; 2016. https://www.accessdata.fda.gov/cdrh_docs/pdf16/den160001.pdf. Accessed November 20, 2017.
71 Harper CC. Letter to Natasha Leskovsek, Common Sense Ltd. Silver Spring, MD: Department of Health and Human Services, Food and Drug Administration; 2009. Accessed November 20, 2017.
72 Cooper JM. Letter to Mr. Thomas M. Tsakeris, Gryphus Diagnostids, LLC. Rockville, MD: Department of Health and Human Services, Food and Drug Administration; 2005. https://www.accessdata.fda.gov/cdrh_docs/pdf5/k050755.pdf. Accessed November 20, 2017.
73 Klebanoff MA, Hauth JC, MacPherson CA, . Time course of the regression of asymptomatic bacterial vaginosis in pregnancy with and without treatment. Am J Obstet Gynecol. 2004;190(2):363–70.14981375
74 Swidsinski A, Mendling W, Loening-Baucke V, . An adherent Gardnerella vaginalis biofilm persists on the vaginal epithelium after standard therapy with oral metronidazole. Am J Obstet Gynecol. 2008 Jan;198(1):97.e1–6. doi: 10.1016/j.ajog.2007.06.039. PMID: 18005928.18005928
75 United Nations Development Programme. Human Development Index. Website. New York City, NY: United Nations Development Programme; 2016. http://hdr.undp.org/en/composite/HDI. Accessed October 15,, 2017.
76 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions. The Cochrane Collaboration; 2011. www.handbook.cochrane.org. Accessed Aug 24, 2016.
77 Sterne JA, Hernan MA, Reeves BC, . ROBINS-I: A tool for assessing risk of bias in non-randomised studies of interventions. BMJ. 2016 Oct 12;355:i4919. doi: 10.1136/bmj.i4919. PMID: 27733354.27733354
78 Sleith C. Methodology checklist 4: case control studies. Edinburgh (UK): Scottish Intercollegiate Guidelines Network. 2012.
79 Whiting P, Savović J, Higgins JP, . ROBIS: a new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2016;69:225–34.26092286
80 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
81 Reitsma JB, Glas AS, Rutjes AW, . Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005 Oct;58(10):982–90. doi: 10.1016/j.jclinepi.2005.02.022. PMID: 16168343.16168343
82 Bossuyt P, Davenport C, Deeks J, . Chapter 11: Interpreting results and drawing conclusions. In: Deeks JJ, Bossuyt PM, Gatsonis C, eds. Cochrane handbook for systematic reviews of diagnostic test accuracy. Version 9. London, The United Kingdom: The Cochrane Collaboration; 2013.
83 Singh S, Chang SM, Matchar DB, . Grading a body of evidence on diagnostic tests. J Gen Intern Med. 2012;27(1):47–55.
84 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville MD: Agency for Healthcare Research and Quality; September 2010. PMID: 2143333721433337. http://effectivehealthcare.ahrq.gov/
85 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986 Sep;7(3):177–88. PMID: 3802833.3802833
86 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; January 2014. http://effectivehealthcare.ahrq.gov/
87 Schunemann HJ, Oxman AD, Brozek J, . Grading quality of evidence and strength of recommendations for diagnostic tests and strategies. BMJ. 2008 May 17;336(7653):1106–10. doi: 10.1136/bmj.39500.677199.AE. PMID: 18483053.18483053
88 Gratacos E, Figueras F, Barranco M, . Prevalence of bacterial vaginosis and correlation of clinical to Gram stain diagnostic criteria in low risk pregnant women. Eur J Epidemiol. 1999 Nov;15(10):913–6. PMID: 10669125.10669125
89 Mastrobattista JM, Bishop KD, Newton ER. Wet smear compared with gram stain diagnosis of bacterial vaginosis in asymptomatic pregnant women. Obstet Gynecol. 2000 Oct;96(4):504–6. PMID: 11004348.11004348
90 Byun SW, Park YJ, Hur SY. Affirm VPIII microbial identification test can be used to detect gardnerella vaginalis, Candida albicans and trichomonas vaginalis microbial infections in Korean women. J Obstet Gynaecol Res. 2016 Apr;42(4):422–6. doi: 10.1111/jog.12913. PMID: 26787446.26787446
91 Hay PE, Taylor-Robinson D, Lamont RF. Diagnosis of bacterial vaginosis in a gynaecology clinic. Br J Obstet Gynaecol. 1992 Jan;99(1):63–6. PMID: 1547176.1547176
92 Platz-Christensen JJ, Larsson PG, Sundstrom E, . Detection of bacterial vaginosis in wet mount, Papanicolaou stained vaginal smears and in gram stained smears. Acta Obstet Gynecol Scand. 1995 Jan;74(1):67–70. PMID: 7856436.7856436
93 Hellberg D, Nilsson S, Mardh PA. The diagnosis of bacterial vaginosis and vaginal flora changes. Arch Gynecol Obstet. 2001 Mar;265(1):11–5. PMID: 11327086.11327086
94 Schmidt H, Hansen JG. A wet smear criterion for bacterial vaginosis. Scand J Prim Health Care. 1994 Dec;12(4):233–8. PMID: 7863139.7863139
95 Cartwright CP, Lembke BD, Ramachandran K, . Comparison of nucleic acid amplification assays with BD affirm VPIII for diagnosis of vaginitis in symptomatic women. J Clin Microbiol. 2013 Nov;51(11):3694–9. doi: 10.1128/jcm.01537-13. PMID: 23985917.23985917
96 Briselden AM, Hillier SL. Evaluation of affirm VP Microbial Identification Test for Gardnerella vaginalis and Trichomonas vaginalis. J Clin Microbiol. 1994 Jan;32(1):148–52. PMID: 8126171.8126171
97 Lowe NK, Neal JL, Ryan-Wenger NA. Accuracy of the clinical diagnosis of vaginitis compared with a DNA probe laboratory standard. Obstet Gynecol. 2009 Jan;113(1):89–95. doi: 10.1097/AOG.0b013e3181909f63. PMID: 18931272.19104364
98 Witt A, Petricevic L, Kaufmann U, . DNA hybridization test: rapid diagnostic tool for excluding bacterial vaginosis in pregnant women with symptoms suggestive of infection. J Clin Microbiol. 2002 Aug;40(8):3057–9. PMID: 12149379.12149379
99 Schwebke JR, Gaydos CA, Nyirjesy P, . Diagnostic performance of a molecular test versus clinician assessment of vaginitis. J Clin Microbiol. 2018 Apr 11doi: 10.1128/jcm.00252-18. PMID: 29643195.29643195
100 Bradshaw CS, Morton AN, Garland SM, . Evaluation of a point-of-care test, BVBlue, and clinical and laboratory criteria for diagnosis of bacterial vaginosis. J Clin Microbiol. 2005 Mar;43(3):1304–8. doi: 10.1128/jcm.43.3.1304-1308.2005. PMID: 15750100.15750100
101 University of Pittsburgh. A validation study of genzyme diagnostics OSOM Trichomonas rapid test and BVBlue test. ClinicalTrials.gov. Bethesda, MD: National Library of Medicine; 2000-.
102 Myziuk L, Romanowski B, Johnson SC. BVBlue test for diagnosis of bacterial vaginosis. J Clin Microbiol. 2003;41(5):1925–8.12734228
103 Gallo MF, Jamieson DJ, Cu-Uvin S, . Accuracy of clinical diagnosis of bacterial vaginosis by human immunodeficiency virus infection status. Sex Transm Dis. 2011 Apr;38(4):270–4. doi: 10.1097/OLQ.0b013e3181fce4eb. PMID: 21515758.21042232
104 Hilmarsdottir I, Hauksdottir GS, Johannesdottir JD, . Evaluation of a rapid Gram stain interpretation method for diagnosis of bacterial vaginosis. J Clin Microbiol. 2006 Mar;44(3):1139–40. doi: 10.1128/jcm.44.3.1139-1140.2006. PMID: 16427240.16517914
105 Landers DV, Wiesenfeld HC, Heine RP, . Predictive value of the clinical diagnosis of lower genital tract infection in women. Am J Obstet Gynecol. 2004 Apr;190(4):1004–10. doi: 10.1016/j.ajog.2004.02.015. PMID: 15118630.15118630
106 Sha BE, Gawel SH, Hershow RC, . Analysis of standard methods for diagnosing vaginitis: HIV infection does not complicate the diagnosis of vaginitis. J Low Genit Tract Dis. 2007 Oct;11(4):240–50. doi: 10.1097/LGT.0b013e318033dfed. PMID: 17666604.17917568
107 Singh RH, Zenilman JM, Brown KM, . The role of physical examination in diagnosing common causes of vaginitis: a prospective study. Sex Transm Infect. 2013 May;89(3):185–90. doi: 10.1136/sextrans-2012-050550. PMID: 23631602.23019659
108 Schwebke JR, Hillier SL, Sobel JD, . Validity of the vaginal gram stain for the diagnosis of bacterial vaginosis. Obstet Gynecol. 1996 Oct;88(4 Pt 1):573–6. PMID: 8841221.8841221
109 Gutman RE, Peipert JF, Weitzen S, . Evaluation of clinical methods for diagnosing bacterial vaginosis. Obstet Gynecol. 2005 Mar;105(3):551–6. doi: 10.1097/01.Aog.0000145752.97999.67. PMID: 15738023.15738023
110 Chen HM, Chang TH, Lin FM, . Vaginal microbiome variances in sample groups categorized by clinical criteria of bacterial vaginosis. BMC Genomics. 2018 Dec 31;19(Suppl 10):876. doi: 10.1186/s12864-018-5284-7. PMID: 30598080.30598080
111 Carey JC, Klebanoff MA, Hauth JC, . Metronidazole to prevent preterm delivery in pregnant women with asymptomatic bacterial vaginosis. National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. N Engl J Med. 2000 Feb 24;342(8):534–40. doi: 10.1056/NEJM200002243420802. PMID: 10684911.10684911
112 Guaschino S, Ricci E, Franchi M, . Treatment of asymptomatic bacterial vaginosis to prevent pre-term delivery: a randomised trial. Eur J Obstet Gynecol Reprod Biol. 2003 Oct 10;110(2):149–52. PMID: 12969574.12969574
113 Kekki M, Kurki T, Pelkonen J, . Vaginal clindamycin in preventing preterm birth and peripartal infections in asymptomatic women with bacterial vaginosis: a randomized, controlled trial. Obstet Gynecol. 2001 May;97(5 Pt 1):643–8. PMID: 11339909.11339909
114 Kiss H, Petricevic L, Husslein P. Prospective randomised controlled trial of an infection screening programme to reduce the rate of preterm delivery. BMJ. 2004 Aug 14;329(7462):371. doi: 10.1136/bmj.38169.519653.EB. PMID: 15294856.15294856
115 Lamont RF, Duncan SL, Mandal D, . Intravaginal clindamycin to reduce preterm birth in women with abnormal genital tract flora. Obstet Gynecol. 2003 Mar;101(3):516–22. PMID: 12636956.12636956
116 Larsson PG, Fahraeus L, Carlsson B, . Late miscarriage and preterm birth after treatment with clindamycin: a randomised consent design study according to Zelen. BJOG. 2006 Jun;113(6):629–37. doi: 10.1111/j.1471-0528.2006.00946.x. PMID: 16709205.16709205
117 McDonald HM, O’Loughlin JA, Vigneswaran R, . Impact of metronidazole therapy on preterm birth in women with bacterial vaginosis flora (Gardnerella vaginalis): a randomised, placebo controlled trial. Br J Obstet Gynaecol. 1997 Dec;104(12):1391–7. PMID: 9422018.9422018
118 McGregor JA, French JI, Jones W, . Bacterial vaginosis is associated with prematurity and vaginal fluid mucinase and sialidase - results of a controlled trial of topical clindamycin cream. Am J Obstet Gynecol. 1994 Apr;170(4):1048–60. doi: 10.1016/S0002-9378(94)70098-2. PMID: WOS:A1994NG74200011.8166188
119 Subtil D, Brabant G, Tilloy E, . Early clindamycin for bacterial vaginosis in pregnancy (PREMEVA): a multicentre, double-blind, randomised controlled trial. Lancet. 2018 Oct 12doi: 10.1016/S0140-6736(18)31617-9. PMID: 30322724.30322724
120 Ugwumadu A, Manyonda I, Reid F, . Effect of early oral clindamycin on late miscarriage and preterm delivery in asymptomatic women with abnormal vaginal flora and bacterial vaginosis: a randomised controlled trial. Lancet. 2003 Mar 22;361(9362):983–8. doi: 10.1016/S0140-6736(03)12823-1. PMID: 12660054.12660054
121 Hauth JC, Goldenberg RL, Andrews WW, . Reduced incidence of preterm delivery with metronidazole and erythromycin in women with bacterial vaginosis. N Engl J Med. 1995 Dec 28;333(26):1732–6. doi: 10.1056/NEJM199512283332603. PMID: 7491136.7491136
122 Morales WJ, Schorr S, Albritton J. Effect of metronidazole in patients with preterm birth in preceding pregnancy and bacterial vaginosis: a placebo-controlled, double-blind study. Am J Obstet Gynecol. 1994 Aug;171(2):345–7; discussion 8-9. PMID: 8059811.8059811
123 Vermeulen GM, Bruinse HW. Prophylactic administration of clindamycin 2% vaginal cream to reduce the incidence of spontaneous preterm birth in women with an increased recurrence risk: a randomised placebo-controlled double-blind trial. Br J Obstet Gynaecol. 1999 Jul;106(7):652–7. PMID: 10428520.10428520
124 Odendaal HJ, Popov I, Schoeman J, . Preterm labour-is bacterial vaginosis involved? S Afr Med J. 2002;92(3):231–4.12040953
125 Joesoef MR, Hillier SL, Wiknjosastro G, . Intravaginal clindamycin treatment for bacterial vaginosis: effects on preterm delivery and low birth weight. Am J Obstet Gynecol. 1995;173(5):1527–31.7503196
126 Kurkinen-Raty M, Vuopala S, Koskela M, . A randomised controlled trial of vaginal clindamycin for early pregnancy bacterial vaginosis. Br J Obstet Gynaecol. 2000 Nov;107(11):1427–32. doi: 10.1111/j.1471-0528.2000.tb11660.x. PMID: WOS:000165812500017.
127 Andrews WW, Hauth JC, Cliver SP, . Association of asymptomatic bacterial vaginosis with endometrial microbial colonization and plasma cell endometritis in nonpregnant women. Am J Obstet Gynecol. 2006 Dec;195(6):1611–6. doi: 10.1016/j.ajog.2006.04.010. PMID: 16769017.16769017
128 Yudin MH, Landers DV, Meyn L, . Clinical and cervical cytokine response to treatment with oral or vaginal metronidazole for bacterial vaginosis during pregnancy: a randomized trial. Obstet Gynecol. 2003 Sep;102(3):527–34. PMID: 12962937.12962937
129 Diav-Citrin O, Shechtman S, Gotteiner T, . Pregnancy outcome after gestational exposure to metronidazole: a prospective controlled cohort study. Teratology. 2001 May;63(5):186–92. doi: 10.1002/tera.1033. PMID: 11320529.11320529
130 Sorensen HT, Larsen H, Jensen ES, . Safety of metronidazole during pregnancy: a cohort study of risk of congenital abnormalities, preterm delivery and low birth weight in 124 women. J Antimicrob Chemother. 1999 Dec;44(6):854–6. PMID: 10590296.10590296
131 Czeizel AE, Rockenbauer M. A population based case-control teratologic study of oral metronidazole treatment during pregnancy. Br J Obstet Gynaecol. 1998 Mar;105(3):322–7. PMID: 9532994.9532994
132 Thapa PB, Whitlock JA, Brockman Worrell KG, . Prenatal exposure to metronidazole and risk of childhood cancer: a retrospective cohort study of children younger than 5 years. Cancer. 1998 Oct 1;83(7):1461–8. PMID: 9762949.9762949
133 Burtin P, Taddio A, Ariburnu O, . Safety of metronidazole in pregnancy: a meta-analysis. Am J Obstet Gynecol. 1995 1995/02/01/;172(2, Part 1):525–9. doi: 10.1016/0002-9378(95)90567-7.7856680
134 Caro-Paton T, Carvajal A, Martin de Diego I, . Is metronidazole teratogenic? A meta-analysis. Br J Clin Pharmacol. 1997 Aug;44(2):179–82. PMID: 9278206.9278206
135 Wilson JD, Ralph SG, Rutherford AJ. Rates of bacterial vaginosis in women undergoing in vitro fertilisation for different types of infertility. BJOG. 2002 Jun;109(6):714–7. PMID: 12118653.12118653
136 Rouse AG, Gil KM, Davis K. Diagnosis of bacterial vaginosis in the pregnant patient in an acute care setting. Arch Gynecol Obstet. 2009 Apr;279(4):545–9. doi: 10.1007/s00404-008-0766-5. PMID: 19246753.18758800
137 Sonnex C. The amine test: a simple, rapid, inexpensive method for diagnosing bacterial vaginosis. Br J Obstet Gynaecol. 1995 Feb;102(2):160–1. PMID: 7756209.7756209
138 Lamont RF, Taylor-Robinson D, Bassett P. Rescreening for abnormal vaginal flora in pregnancy and re-treating with clindamycin vaginal cream significantly increases cure and improvement rates. Int J STD AIDS. 2012 Aug;23(8):565–9. doi: 10.1258/ijsa.2011.011229. PMID: WOS:000309297400007.22930293
139 Figueroa D, Mancuso MS, Szychowski JM, . Does midtrimester Nugent score or high vaginal pH predict gestational age at delivery in women at risk for recurrent preterm birth? Am J Obstet Gynecol. 2011 Jan;204(1):46.e1–4. doi: 10.1016/j.ajog.2010.08.029. PMID: 20885970.21055721
140 French JI, McGregor JA, Parker R. Readily treatable reproductive tract infections and preterm birth among black women. Am J Obstet Gynecol. 2006 Jun;194(6):1717–26; discussion 26-7. doi: 10.1016/j.ajog.2006.03.004. PMID: 16709205.16731091
141 Hitti J, Nugent R, Boutain D, . Racial disparity in risk of preterm birth associated with lower genital tract infection. Paediatr Perinat Epidemiol. 2007 Jul;21(4):330–7. doi: 10.1111/j.1365-3016.2007.00807.x. PMID: 16648432.17564589
142 Jones NM, Holzman C, Friderici KH, . Interplay of cytokine polymorphisms and bacterial vaginosis in the etiology of preterm delivery. J Reprod Immunol. 2010 Dec;87(1–2):82–9. doi: 10.1016/j.jri.2010.06.158. PMID: 20573348.20965572
143 Nelson DB, Hanlon A, Nachamkin I, . Early pregnancy changes in bacterial vaginosis-associated bacteria and preterm delivery. Paediatr Perinat Epidemiol. 2014 Mar;28(2):88–96. doi: 10.1111/ppe.12106. PMID: 25518272.24405280
144 Johnson HL, Ghanem KG, Zenilman JM, . Sexually transmitted infections and adverse pregnancy outcomes among women attending inner city public sexually transmitted diseases clinics. Sex Transm Dis. 2011 Mar;38(3):167–71. doi: 10.1097/OLQ.0b013e3181f2e85f. PMID: 21275914.20852454
145 Nelson DB, Hanlon A, Hassan S, . Preterm labor and bacterial vaginosis-associated bacteria among urban women. J Perinat Med. 2009;37(2):130–4. doi: 10.1515/jpm.2009.026. PMID: 18591634.18999913
146 Xu J, Holzman CB, Arvidson CG, . Midpregnancy vaginal fluid defensins, bacterial vaginosis, and risk of preterm delivery. Obstet Gynecol. 2008 Sep;112(3):524–31. doi: 10.1097/AOG.0b013e318184209b. PMID: 17986357.18757648
147 Donders GGG. Definition and classification of abnormal vaginal flora. Best Pract Res Clin Obstet Gynaecol. 2007 2007/06/01/;21(3):355–73. doi: 10.1016/j.bpobgyn.2007.01.002.17434799
148 Taylor-Robinson D, Morgan DJ, Sheehan M, . Relation between Gram-stain and clinical criteria for diagnosing bacterial vaginosis with special reference to Gram grade II evaluation. Int J STD AIDS. 2003;14(1):6.
149 Rosenstein IJ, Morgan DJ, Lamont RF, . Effect of intravaginal clindamycin cream on pregnancy outcome and on abnormal vaginal microbial flora of pregnant women. Infect Dis Obstet Gynecol. 2000;8(3–4):158–65.10968599
150 Hillier SL, Krohn MA, Nugent RP, . Characteristics of three vaginal flora patterns assessed by Gram stain among pregnant women. International Journal of Gynecology & Obstetrics. 1992 1992/11/01/;39(3):249–50. doi: 10.1016/0020-7292(92)90677-B.
151 Farr A, Kiss H, Hagmann M, . Role of Lactobacillus species in the intermediate vaginal flora in early pregnancy: a retrospective cohort study. PLoS One. 2015;10(12):e0144181.26658473
152 McDonald HM, Brocklehurst P, Gordon A. Antibiotics for treating bacterial vaginosis in pregnancy. Cochrane Database Syst Rev. 2007;1(1).
153 Honda H, Yokoyama T, Akimoto Y, . The frequent shift to intermediate flora in preterm delivery cases after abnormal vaginal flora screening. Sci Rep. 2014 Apr 25;4:4799. doi: 10.1038/srep04799. PMID: 24762852.24762852
154 Jesse DE, Swanson MS, Newton ER, . Racial disparities in biopsychosocial factors and spontaneous preterm birth among rural low-income women. J Midwifery Womens Health. 2009 Jan–Feb;54(1):35–42. doi: 10.1016/j.jmwh.2008.08.009. PMID: 19114237.19114237
155 Ness RB, Hillier S, Richter HE, . Can known risk factors explain racial differences in the occurrence of bacterial vaginosis? J Natl Med Assoc. 2003 Mar;95(3):201–12. PMID: 12749680.12749680
156 Mancuso MS, Figueroa D, Szychowski JM, . Midtrimester bacterial vaginosis and cervical length in women at risk for preterm birth. Am J Obstet Gynecol. 2011;204(4):342.e1–5. doi: 10.1016/j.ajog.2010.11.003. PMID: 21183154.21183154
157 Nelson DB, Bellamy S, Odibo A, . Vaginal symptoms and bacterial vaginosis (BV): how useful is self-report? Development of a screening tool for predicting BV status. Epidemiol Infect. 2007 Nov;135(8):1369–75. doi: 10.1017/s095026880700787x. PMID: 17532736.17274857
158 Koumans EH, Lane SD, Aubry R, . Evaluation of Syracuse Healthy Start’s program for abnormal flora management to reduce preterm birth among pregnant women. Matern Child Health J. 2011 Oct;15(7):1020–8. doi: 10.1007/s10995-010-0661-0. PMID: 19795485.20824320
159 Dingens AS, Fairfortune TS, Reed S, . Bacterial vaginosis and adverse outcomes among full-term infants: a cohort study. BMC Pregnancy Childbirth. 2016 Sep 22;16(1):278. doi: 10.1186/s12884-016-1073-y. PMID: 27658456.27658456
160 Desseauve D, Chantrel J, Fruchart A, . Prevalence and risk factors of bacterial vaginosis during the first trimester of pregnancy in a large French population-based study. Eur J Obstet Gynecol Reprod Biol; 2012. p. 30–4.
161 Larsson PG, Fahraeus L, Carlsson B, . Predisposing factors for bacterial vaginosis, treatment efficacy and pregnancy outcome among term deliveries; results from a preterm delivery study. BMC Womens Health. 2007 Oct 22;7:20. doi: 10.1186/1472-6874-7-20. PMID: 17510259.17953762
162 Barton JR, Sibai BM. Prediction and prevention of recurrent preeclampsia. Obstet Gynecol. 2008;112(2):359–72.18669736
163 Martin JA, Hamilton BE, Osterman MJK, . Births: final data for 2016. Natl Vital Stat Rep. 2018 January 31;67(1):1–55.
164 Bautista C, Wurapa E, Sateren W, . Association of Bacterial Vaginosis With Chlamydia and Gonorrhea Among Women in the U.S. Army. Am J Prev Med; 2016.
165 Ness RB, Kip KE, Soper DE, . Bacterial vaginosis (BV) and the risk of incident gonococcal or chlamydial genital infection in a predominantly black population. Sex Transm Dis. 2005 Jul;32(7):413–7. PMID: 15976598.15976598
166 Pretorius C, Jagatt A, Lamont RF. The relationship between periodontal disease, bacterial vaginosis, and preterm birth. J Perinat Med. 2007;35(2):93–9. doi: 10.1515/jpm.2007.039. PMID: 16643824.17343541
167 Harper L, Parry S, Stamilio D, . The interaction effect of bacterial vaginosis and periodontal disease on the risk of preterm delivery. Am J Perinatol; 2012. p. 347–52.
168 Luong ML, Libman M, Dahhou M, . Vaginal douching, bacterial vaginosis, and spontaneous preterm birth. J Obstet Gynaecol Can. 2010 Apr;32(4):313–20. doi: 10.1016/s1701-2163(16)34474-7. PMID: 21325838.20500937
169 Gillet E, Meys JFA, Verstraelen H, . Bacterial vaginosis is associated with uterine cervical human papillomavirus infection: a meta-analysis. BMC Infect Dis. 2011;11doi: 10.1186/1471-2334-11-10.
170 Esber A, Vicetti Miguel RD, Cherpes TL, . Risk of bacterial vaginosis among women with herpes simplex virus type 2 infection: a systematic review and meta-analysis. J Infect Dis. 2015;212(1):8–17. doi: 10.1093/infdis/jiv017.25589333
171 Atashili J, Poole C, Ndumbe PM, . Bacterial vaginosis and HIV acquisition: a meta-analysis of published studies. AIDS (London, England). 2008;22(12):1493–501. doi: 10.1097/QAD.0b013e3283021a37. PMID: PMC2788489.
172 Genc MR, Witkin SS, Delaney ML, . A disproportionate increase in IL-1beta over IL-1ra in the cervicovaginal secretions of pregnant women with altered vaginal microflora correlates with preterm birth. Am J Obstet Gynecol. 2004 May;190(5):1191–7. doi: 10.1016/j.ajog.2003.11.007. PMID: 15167817.15167817
173 Wiesenfeld HC, Macio I. The infrequent use of office-based diagnostic tests for vaginitis. Am J Obstet Gynecol. 1999 1999/07/01/;181(1):39–41. doi: 10.1016/S0002-9378(99)70433-3.
174 McGregor JA, Hager WD, Gibbs RS, . Assessment of office-based care of sexually transmitted diseases and vaginitis and antibiotic decision-making by obstetrician-gynecologists. Infect Dis Obstet Gynecol. 1998;6(6):247–51. doi: 10.1155/s1064744998000519. PMID: 9972486.9972486
175 Weisbord JS, Koumans EH, Toomey KE, . Sexually transmitted diseases during pregnancy: screening, diagnostic, and treatment practices among prenatal care providers in Georgia. South Med J. 2001 Jan;94(1):47–53. PMID: 11213942.11213942
176 Brandt M, Abels C, May T, . Intravaginally applied metronidazole is as effective as orally applied in the treatment of bacterial vaginosis, but exhibits significantly less side effects. European Journal of Obstetrics and Gynecology and Reproductive Biology. 2008;141(2):158–62. doi: 10.1016/j.ejogrb.2008.07.022.18775597
177 Menard J-P. Antibacterial treatment of bacterial vaginosis: current and emerging therapies. Int J Women Health. 2011;3:295–305. doi: 10.2147/IJWH.S23814.
178 Donders GGG, Zodzika J, Rezeberga D. Treatment of bacterial vaginosis: what we have and what we miss. Expert Opin Pharmacother. 2014;15(5):645–57. doi: 10.1517/14656566.2014.881800.24579850
179 Schwebke JR. Asymptomatic bacterial vaginosis: response to therapy. Am J Obstet Gynecol. 2000 Dec;183(6):1434–9. doi: 10.1067/mob.2000.107735. PMID: 11120507.11120507
180 Oduyebo OO, Anorlu RI, Ogunsola FT. The effects of antimicrobial therapy on bacterial vaginosis in non-pregnant women. Cochrane Database Syst Rev. 2009 Jul 8(3):CD006055. doi: 10.1002/14651858.CD006055.pub2. PMID: 19588379.19588379
181 Schwebke JR, Desmond RA. Tinidazole vs metronidazole for the treatment of bacterial vaginosis. Am J Obstet Gynecol. 2011;204(3):211.e1–.e6. doi: 10.1016/j.ajog.2010.10.898.21167471
182 Schwebke JR, Marrazzo J, Beelen AP, . A Phase 3, Multicenter, Randomized, Double-Blind, Vehicle-Controlled Study Evaluating the Safety and Efficacy of Metronidazole Vaginal Gel 1.3% in the Treatment of Bacterial Vaginosis. Sex Transm Dis. 2015;42(7):376–81. doi: 10.1097/OLQ.0000000000000300.26222750
183 Hanson JM, McGregor JA, Hillier SL, . Metronidazole for bacterial vaginosis. A comparison of vaginal gel vs. oral therapy. J Reprod Med. 2000 Nov;45(11):889–96. PMID: 11127100.11127100
184 Stein GE, Christensen SL, Mummaw NL, . Placebo-controlled trial of intravaginal clindamycin 2% cream for the treatment of bacterial vaginosis. Ann Pharmacother. 1993 Nov;27(11):1343–5. doi: 10.1177/106002809302701106. PMID: 8286805.8286805
185 Greaves W, Chungafun J, Morris B, . Clindamycin versus metronidazole in the treatment of bacterial vaginosis. Obstet Gynecol. 1988;72(5):799–802. doi: 10.1016/S0196-0644(89)80433-0.3050654
186 Schmitt C, Sobel JD, Meriwether C. Bacterial vaginosis: treatment with clindamycin cream versus oral metronidazole. Obstet Gynecol. 1992;79(6):1020–3.1579299
187 Fischbach F, Petersen E, Weissenbacher E, . Efficacy of Clindamycin Vaginal Cream Versus Oral Metronidazole in the Treatment of Bacterial Vaginosis. Obstet Gynecol. 1993;82(3):405–10.8355942
188 Bradshaw CS, Pirotta M, De Guingand D, . Efficacy of oral metronidazole with vaginal clindamycin or vaginal probiotic for bacterial vaginosis: randomised placebo-controlled double-blind trial. PLoS One. 2012;7(4):e34540. doi: 10.1371/journal.pone.0034540. PMID: 22782818.22509319
189 Beigi RH, Yudin MH, Cosentino L, . Cytokines, pregnancy, and bacterial vaginosis: comparison of levels of cervical cytokines in pregnant and nonpregnant women with bacterial vaginosis. J Infect Dis. 2007 Nov 1;196(9):1355–60. doi: 10.1086/521628. PMID: 18251229.17922400
190 Paavonen J. Pelvic inflammatory disease. From diagnosis to prevention. Dermatol Clin. 1998 Oct;16(4):747–56, xii. PMID: 9891675.9891675
191 Workowski KA, Bolan GA, Centers for Disease C, . Sexually transmitted diseases treatment guidelines, 2015. MMWR Recomm Rep. 2015 Jun 05;64(RR-03):1–137. PMID: 26042815.26042815
192 U. S. Food & Drug Administration. Pregnancy and Lactation Labeling (Drugs) Final Rule. Silver Spring, MD; 2018. https://www.fda.gov/Drugs/DevelopmentApprovalProcess/DevelopmentResources/Labeling/ucm093307.htm. Accessed 05/01/2018.
193 Practice bulletin no. 130: prediction and prevention of preterm birth. Obstet Gynecol. 2012 Oct;120(4):964–73. doi: 10.1097/AOG.0b013e3182723b1b. PMID: 22996126.22996126
194 Yudin MH, Money DM, Boucher M, . Screening and Management of Bacterial Vaginosis in Pregnancy. J Obstet Gynaecol Can. 2008;30(8):702–8. doi: 10.1016/s1701-2163(16)32919-x.18786293
195 Association of Reproductive Health Professionals. Hot topics in sexually transmitted infections and associated conditions. Washington, DC: Association of Reproductive Health Professionals; 2013. http://www.arhp.org/Publications-and-Resources/Quick-Reference-Guide-for-Clinicians/Sexually-Transmitted-Infections-and-Associated-Conditions/Bacterial-Vaginosis. Accessed December 6, 2017.
196 Hay P, Patel S, Daniels D. UK National Guideline for the management of Bacterial Vaginosis 2012. UK: Clinical Effectiveness Group, British Association for Sexual Health & HIV; 2012. https://www.bashh.org/documents/4413.pdf. Accessed November 20, 2017.
197 National Institute for Health and Care Excellence. Antenatal care for uncomplicated pregnancies. NICE clinical guidelines. Updated edition. London. 2008.
198 American Academy of Family P. Bacterial Vaginosis. Leawood, KS: American Academy of Family Physicians; 2008.
199 National Institute of Health and Care Excellence. Antenatal care for uncomplicated pregnancies update. London: National Institute of Health and Care Excellence; n.d. https://www.nice.org.uk/guidance/indevelopment/gid-ng10096. Accessed December 4, 2018.
200 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20:(3 Suppl):21–35. PMID: 11306229.11306229
201 Lin DP, Pan BJ, Fuh JC, . Improving Gram-stained reproducible result by further adding clue cells in diagnosing bacterial vaginosis. Kaohsiung J Med Sci. 2002 Apr;18(4):164–70. PMID: 12164009.12164009
202 Jaeschke R, Guyatt G, Lijmer J. Diagnostic tests. In: Guyatt G, Rennie D, eds. Users’ guide to the medical literature. Chicago: AMA Press; 2002:121–40.