# Chapter 4 Discussion

## Summary of Evidence

Table 11 summarizes the evidence synthesized in this report by KQ and provides our assessment of the SOE. We identified no direct evidence evaluating the benefits (KQ 1) or harms (KQ 3) of screening, and evidence to address variation in effectiveness of treatment in subpopulations (KQ 4) was only available for women with a prior preterm delivery. Evidence for variation in effectiveness of treatment in subpopulations characterized by race/ethnicity, HIV status, or other characteristics was not identified.

Table 11 Summary of Evidence for Screening for Bacterial Vaginosis in Pregnant Adolescents and Women to Prevent Preterm Delivery

Key; Question | No. of Studies and Design;; No. of Participants | Summary of Findings | Consistency/Precision | Other Limitations | EPC Assessment of Strength of Evidence | Applicability
KQ 1 Benefits of screening | No studies identified
KQ 2 Diagnostic test accuracy (by test)
BD Affirm | 5 cross-sectional studies^90,^ ^95–98^;; N=2,936 | Pooled Sn, 0.87 (95% CI, 0.80 to 0.92); Pooled Sp, 0.81 (95% CI, 0.73 to 0.88); Pooled +LR, 4.6 (95% CI, 3.1 to 6.8); Pooled −LR, 0.16 (95% CI, 0.11 to 0.26) | Inconsistent^*^/precise^†^ | 4 of 5 studies with fair methodological quality (unclear enrollment procedures, unclear masking of test results, spectrum bias) | LOW for adequate accuracy | Only 1 study conducted in pregnant women, all studies conducted in symptomatic women
BD Max | 1 cross-sectional study^65,^ ^99^;; N=1,338 | Sn, 0.93 (95% CI, 0.91 to 0.94); Sp, 0.92 (95% CI, 0.90 to 0.94); +LR, 10.9 (95% CI 8.3 to 14.5); -LR, 0.08 (95% CI 0.06 to 0.10) | Unknown consistency/precise^ǂ^ | Excluded participants with intermediate flora from analysis | LOW^§^ for adequate accuracy | Symptomatic women
BV Blue | 3 cross-sectional studies^100–102^;; N=864 | Sn, range 0.61 to 0.92 across studies; Sp, range 0.86 to 0.99 across studies | Inconsistent^‖^ (more inconsistent for Sn than Sp)/precise^¶^ (more precise for Sp than Sn) | All studies with fair methodological quality (unclear enrollment, unclear masking of results, spectrum bias) | LOW for adequate accuracy | Symptomatic, nonpregnant women
Complete Amsel’s criteria | 15 cross-sectional studies^88,^ ^91,^ ^92,^ ^99–110^;; N=7,171 | Based on 14 of the 15 studies:; Pooled Sn, 0.76 (95% CI, 0.63 to 0.85); Pooled Sp, 0.95 (95% CI, 0.89 to 0.98); Pooled +LR, 14.1 (95% CI, 6.8 to 29.2); Pooled −LR, 0.26 (95% CI, 0.17 to 0.39) | Inconsistent^#^/precise^**^ (more precise for Sp than Sn) | 12 of 15 studies with fair methodological quality (unclear enrollment, unclear masking of test results, spectrum bias), heterogeneity in application of clinical criteria and unit of analysis (patients vs. visits) | LOW for adequate accuracy | Only 1 study conducted exclusively in pregnant women; most studies conducted in symptomatic women
Modified Amsel’s criteria | 5 cross-sectional studies^88,^ ^89,^ ^99,^ ^107,^ ^108^;; N=2,674 | Based on 4 of the 5 studies:; Pooled Sn, 0.67 (95% CI, 0.54 to 0.78); Pooled Sp, 0.96 (95% CI, 0.93 to 0.98); Pooled +LR, 17.3 (95% CI, 10.4 to 28.8); Pooled −LR, 0.34 (95% CI, 0.24 to 0.48) | Inconsistent^††^ (more inconsistent for Sn than Sp)/precise^ǂǂ^ (more precise for Sp than Sn) | 4 of 5 studies with fair methodological quality (unclear enrollment, unclear masking of test results, spectrum bias) | LOW for adequate accuracy | 2 studies conducted exclusively in asymptomatic, pregnant women
KQ 3 Harms of screening | No studies identified
KQ 4 Benefits of treatment | 6 RCTs^111,^ ^112,^ ^116–119^;; N=6,307 | All-cause preterm delivery <37 weeks in general obstetric population:; Pooled ARD, 0.20% (95% CI, −1.13% to 1.53%); Pooled RR, 1.02 (95% CI, 0.86 to 1.20) | Consistent/imprecise^§§^ | All but 1 study of good methodological quality; no reporting bias detected | MODERATE for no benefit of treatment | Applies to treatment of asymptomatic patients with oral or vaginal clindamycin or oral metronidazole; history of prior PTD in this population ranged from 1.6% to 10.9%
KQ 4 Benefits of treatment | 8 RCTs^111,^ ^113–117,^ ^119,^ ^120^;; N=7,571 | Spontaneous preterm delivery <37 weeks in general obstetric population:; Pooled ARD, −1.44% (95% CI, −3.31% to 0.43%); Pooled RR, 0.78 (95% CI, 0.56 to 1.07) | Inconsistent^‖‖^/imprecise^¶¶^ | All but 2 studies of good methodological quality; no reporting bias detected | LOW for no benefit of treatment | Same as previous row
KQ 4 Benefits of treatment | 3 RCTs^111,^ ^116,^ ^119^; N=5,564 | Preterm delivery <32 weeks in general obstetric population; Pooled ARD, −0.30% (95% CI, −0.97% to 0.38%); Pooled RR, 0.87 (95% CI, 0.54 to 1.42) | Consistent/precise^##^ | 1 study of fair methodological quality; outcome was spontaneous PTD in 2 studies and all-cause PTD in the other study; no reporting bias detected | HIGH for no benefit of treatment | Same as previous row
KQ 4 Benefits of treatment | 5 RCTs^111,^ ^112,^ ^115,^ ^118,^ ^119^; N=5,377 | Birth weight <2,500 g in general obstetric population; Pooled ARD, 0.39% (95% CI, −1.74% to 2.53%); Pooled RR, 1.03 (95% CI, 0.83 to 1.29) | Consistent/imprecise^***^ | All studies of good methodological quality; no reporting bias detected | MODERATE for no benefit of treatment | Same as previous row
KQ 4 Benefits of treatment | 3 RCTs ^111,^ ^115,^ ^119^; N=5,149 | Birth weight <1,500 g in general obstetric population; Pooled ARD, 0.06% (95% CI, −0.99% to 1.12%); Pooled RR, 1.05 (95% CI, 0.50 to 2.18) | Consistent/precise^†††^ | All studies of good methodological quality; no reporting bias detected | HIGH for no benefit of treatment | Same as previous row
KQ 4 Benefits of treatment | 4 RCTs^112,^ ^117–119^; N=3,568 | PPROM or PROM in general obstetric population; Pooled ARD, 0.10% (95% CI, −1.32% to 1.52%); Pooled RR, 1.11 (0.72 to 1.72) | Consistent/imprecise^ǂǂǂ^ | All studies of good methodological quality; no reporting bias detected; one study reported PROM while others reported PPROM | MODERATE for no benefit of treatment | Same as previous row
KQ 4 Benefits of treatment | 4 RCTs^111,^ ^117,^ ^121,^ ^122^;; N=451 | Preterm delivery <37 weeks (all-cause or spontaneous) in women with prior preterm delivery; ARDs range from −29.4% to 7.5%; RRs range from 0.17 to 1.33; Results statistically significant in 3 of the 4 studies favoring treatment. | Inconsistent^§§§^/imprecise^ǁǁǁ^ | 2 studies of fair methodological quality; findings from 3 studies were from subgroup analyses and it is not clear that they were preplanned. Unable to definitively identify source(s) of inconsistency. | INSUFFICIENT | Applies to treatment of asymptomatic patients with a prior PTD with oral metronidazole
KQ 4 Benefits of treatment | 2 RCTs^122,^ ^123^; N=102 | Preterm delivery <34 weeks in women with prior preterm delivery; ARD 0% in one study and −6.57% (95% CI, −18.5% to 5.4%) in the other study. | Consistent/imprecise^¶¶¶^ | Both studies with fair study quality; results from one were from subgroup analysis. | INSUFFICIENT | Applies to treatment of asymptomatic patients with a prior PTD with vaginal clindamycin or oral metronidazole
KQ 5 Harms of treatment (by harm)
Maternal harms of treatment | Intravaginal clindamycin 4 RCTs^113,^ ^114,^ ^116,^ ^123^; N=1,718 | Heterogenous outcomes reported.; No serious AEs observed in 3 studies.^114,^ ^116,^ ^117^; Infrequent side effects such as candidal vaginitis, troublesome discharge; withdrawals because of itching were infrequent and similar between groups when reported by groups^113,^ ^116,^ ^123^ | Consistent/imprecise^###^ | Although RCTs were mostly of good methodological quality, AE outcome measurement and reporting were not well described and studies were not powered for AEs | MODERATE for no difference in serious AEs or minor harms (intravaginal clindamycin) | Applies to treatment of asymptomatic pregnant women with BV
Maternal harms of treatment | Oral clindamycin 2 RCTs^119,^ ^120^;; N=3,345 | Serious AEs not observed in either group in 1 study;^119^ not reported in the other study^120^ Higher incidence of side effects with active treatment in 1 study (ARD, 1.79% [95% CI, 0.75% to 2.84%])^119^; Higher incidence of stopping medication with active treatment in both studies, but findings were statistically significant in only 1 study (ARD, 3.33% [95% CI, 0.38% to 6.27%];^119^ ARD, 3.65% [95% CI, −0.27% to 7.56%]^120^) | Consistent/imprecise^****^ | Although RCTs were mostly of good methodological quality, AE outcome measurement and reporting were not well described and studies were not powered for AEs | MODERATE for no difference in serious AEs but more minor harms (oral clindamycin and metronidazole) | Same as previous row
Maternal harms of treatment | Oral metronidazole 2 RCTs^111,^ ^117^;; N=2,776 | Higher incidence of side effects/AEs with active treatment in both studies, but findings were statistically significant in only 1 study (ARD, 12.51% [95% CI, 9.33% to 15.69%]^111^; ARD, 2.56% [95% CI, −0.36% to 5.47%]^117^) | Consistent/imprecise^††††^ | Although RCTs were mostly of good methodological quality, AE outcome measurement and reporting were not well described and studies were not powered for AEs | | Same as previous row
Harms to children from in utero exposure to medication | 3 observational studies^129–131^;; N=62,271; 2 meta-analyses of observational studies^133,^ ^134^;; N>199,541^****^ | Congenital malformations among children exposed to metronidazole in utero: ORs and RR estimates from individual studies range from 0.44 to 2.24, CIs range from 0.11 to 4.23; Congenital malformations among children exposed to metronidazole in utero:; Pooled OR, 0.96 (95% CI, 0.75 to 1.22)^133^; Pooled OR, 1.08 (95% CI, 0.90 to 1.29)^134^ | Consistent/imprecise^ǂǂǂǂ^ | Studies of poor to fair methodological quality, did not address confounding, variation in outcome definition, potential for recall bias in case-control study; Older analyses that did not use current methods for conducting and reporting analyses, included studies were not assessed for risk of bias | INSUFFICIENT | Applies to metronidazole exposure across a range of indications (not specific to women with BV)
Harms to children from in utero exposure to medication | 1 observational study^132^;; N=328,846 participants with 1,172,696 person-years | Cancer incidence before age 5 years among children exposed to metronidazole: Adjusted RR, 0.81 (95% CI, 0.41 to 1.59). | Consistency unknown/imprecise^§§§§^ | Fair methodologic quality; baseline imbalances between groups and potential for residual confounding | INSUFFICIENT | Same as previous row

* The 95% prediction region covers nearly one third of the ROC space (Appendix F Figure 1), and visual inspection of the forest plot (Appendix F Figure 2) suggests at least moderate inconsistency in estimates across studies that cannot easily be explained by differences in study populations or settings.

† The 95% confidence region is relatively small, and the CI around the AUC is fairly narrow, suggesting precise estimates (Appendix F Figure 1).

ǂ Based on the upper and lower CIs for sensitivity and specificity, the positive LR would range from 10.67 to 11.11 and the negative LR would range from 0.078 to 0.82, resulting in minimal variation in posttest probabilities, suggesting precise estimates.

§ We downgraded the overall SOE for study limitations and because of a single study body of evidence with unknown consistency.

‖ The range of estimates across the three studies is inconsistent for sensitivity but reasonably consistent for specificity. In particular, one study had markedly lower sensitivity (0.61) than the others, which were 0.88 and 0.917. This study was only reported in clincialtrials.gov, and very little information about the study setting and population was available to understand why this result was inconsistent with the other two studies.

¶ The LR+ and LR− at the upper and lower limits of the sensitivity and specificity CIs for each study are reasonably similar and result in only small differences in posttest probabilities. See Appendix H.

# The 95% prediction region covers over one third of the ROC space (Appendix F Figure 3), and visual inspection of the forest plot (Appendix F Figure 4) identifies moderate inconsistency in estimates of sensitivity and specificity that cannot easily be explained by differences in study populations or settings.

** The confidence region is quite small; thus, we judged this estimate as precise, although more precise for specificity than for sensitivity (Appendix F Figure 3).

†† Although the prediction region covers only one fifth of the SROC space, the shape of the region suggests future studies could lie in the space of relative poor sensitivity and high specificity or equally likely the space of relatively poor specificity and high sensitivity, and visual inspection of the forest plot also suggests inconsistency (Appendix F Figure 5 and Figure 6).

ǂǂ The 95% confidence region suggests reasonable precision for estimates of specificity, but some imprecision in estimates of sensitivity (Appendix F Figure 5).

§§ OIS criteria not met, a sample size of 7,116 is required to detect a 20% RR reduction based on 9% control group risk, alpha=0.05, power=0.80, two-tailed test. Further, we assessed that the width of the CI around the RR could not exclude a clinically meaningful benefit or harm; despite the narrow range of the CI around the ARD, the population burden from even a small increase or decrease in PTD could be clinically meaningful.

‖‖ Although CIs are mostly overlapping, there is some inconsistency in both the direction and magnitude of effect because two studies observed a statistically significant effect of −5.80% and −9.96% compared with the other studies that are much closer to a null effect (ARDs ranging from −2.25% to 1.09%); further, I^2^ statistic is 61.9% for the ARD.

¶¶ OIS criteria not met; a sample size of 9,920 is required to detect a 20% RR reduction based on 7% control group risk (average risk across studies), alpha=0.05, power=0.80, two-tailed test. Further, the CIs for both the ARD and RR span a range that could be considered a clinically meaningful benefit or no difference.

## Low baseline risk (<5%) and sample sizes >2,000 in each group, thus OIS is met. Because of infrequent events, we placed more emphasis on ARD than RR when evaluating precision.

*** OIS criteria not met; a sample size of 7,116 required to detect a 20% RR reduction based on a 9% control group risk (average across these studies), alpha=0.05, power=0.8, two-tailed test.

††† Low baseline risk (<5%) and sample sizes >2,000 in each group, thus OIS is met. Because of infrequent events, we placed more emphasis on ARD than RR when evaluating precision.

ǂǂǂ OIS criteria not met; sample size of 24,798 required to detect a 20% RR reduction based on a 3% control group risk (average across these studies), alpha=0.05, power=0.8, two-tailed test.

§§§ Three studies have statistically significant moderate treatment effect sizes, while one study shows an increase in preterm delivery from treatment but is not statistically significant; the source of inconsistency is unexplained.

ǁǁǁ OIS criteria not met; a sample size of 1,248 required to detect a 20% RR reduction based on a 38% control group risk, alpha=0.05, power=0.80, two-tailed test.

¶¶¶ OIS criteria not met; a sample size of 1,874 required to detect a 20% RR reduction based on a 29% control group risk, alpha= 0.05, power-0.80, two-tailed test.

### OIS criteria not met; infrequent events reported.

**** OIS criteria not met; a sample size of 45,236 is required to detect a 20% relative risk increase based on a 2% control group risk, alpha=0.05, power=0.8, two-tailed test.

†††† One study included 155,504 participants,^133^ and the other study included 199,451 participants;^134^ three studies overlapped between the two analyses.

ǂǂǂǂ OIS criteria met. A sample size of 17,128 is required to detect an elevated RR of 1.20 with alpha=0.05, power=0.80, two-sided test. However, the null effect cannot be excluded, and the CIs from both the individual studies and the meta-analyses span a clinically meaningful range of benefit and harms; thus, we consider the estimate to be imprecise.

§§§§ OIS criteria not met; a sample size of more than 6 million would be required to detect a 20% RR increase based on a 0.0142% control group risk, alpha=0.05, power=0.80, two-tailed test.

Abbreviations: AE=adverse event; ARD=absolute risk difference; AUC=area under the curve; BV=bacterial vaginosis; CI=confidence interval; EPC=Evidence-based Practice Center; KQ=key question; LR=likelihood ratio; N=number of participants; No.=number; OIS=optimal information size; OR=odds ratio; PTD=preterm delivery; RCT=randomized, controlled trial; ROC=receiver operating characteristic; RR=relative risk; Sn=sensitivity; SOE=strength of evidence; SROC=summary receiver operating characteristic; Sp=specificity.

### Diagnostic Test Accuracy (KQ 2)

For diagnostic accuracy of available tests for bacterial vaginosis (KQ 2), we assessed the SOE as low for adequate accuracy for all tests evaluated (BD Affirm, BD Max, BVBLUE, complete Amsel’s clinical criteria, and modified Amsel’s clinical criteria). Across all tests, we downgraded the SOE because this body of evidence largely comprised studies of only fair methodological quality. We further downgraded the SOE because of inconsistency. A low SOE means we have limited confidence in the estimates of test accuracy and that results might not be stable with the addition of future studies.^135^

Most studies were conducted among symptomatic, nonpregnant women; thus, the applicability to asymptomatic pregnant women is not entirely clear. For complete Amsel’s and modified Amsel’s clinical criteria, the sensitivities observed in the two studies^88,^ ^89^ conducted exclusively among pregnant women were lower than the pooled summary estimates, suggesting that the physiologic changes that occur in the vaginal environment during pregnancy may affect the sensitivity of one or more of the clinical criteria used to identify bacterial vaginosis. A lower sensitivity was not observed for the BD Affirm test in the one study conducted exclusively in pregnant women.^98^ The BD Affirm test, which is based on a nucleic acid probe for G. vaginalis, may not be affected by the physiologic changes associated with pregnancy.

Although we did not formally conduct a comparative assessment of test accuracy, the tests do vary somewhat in accuracy. However, we do not think any specific test falls below a threshold of accuracy that would not be clinically useful. All tests have reasonably sufficient specificity; the laboratory-based tests (BD Affirm, BD Max, BVBLUE) have higher sensitivities than those based on Amsel’s clinical criteria but lower specificity. Assuming treatment is effective and harms of treatment are minimal, one might select a test with higher sensitivity to minimize false-negative results. In other contexts (e.g., when harms of false-positive results are more than minimal), a test with higher specificity might be preferred to minimize the harms of unnecessary treatment.

Some researchers have suggested applying likelihood ratios to pretest probabilities to assess how well a positive or negative test would influence the posttest probability of disease as an alternative way to evaluate test accuracy and to assess consistency and precision domains within SOE assessment.^83^ We illustrate this approach in Appendix H. In this example, we assumed a pretest probability of bacterial vaginosis of 17.2 percent, which was the average prevalence of bacterial vaginosis among asymptomatic women evaluated for study entry into the RCTs evaluating the benefits of treatment (KQ 4). A positive BD Affirm test increases the posttest probability of bacterial vaginosis to 48.9 percent, a positive BD Max increases the posttest probability to 69.4 percent, and a positive Amsel’s test (complete criteria) increases the posttest probability to 61.0 percent. The posttest probability after a negative test is 3.2 percent (BD Affirm), 1.6 percent (BD Max), and 2.8 percent (complete Amsel’s clinical criteria). Depending on the clinical treatment threshold one uses to decide to treat, any of these tests might have acceptable accuracy, although some might be considered more accurate based on their larger influence on the posttest probability after a positive test. After a negative test, all would likely decrease the posttest probability of bacterial vaginosis below a threshold for which treatment would likely not be indicated.

### Benefits of Treatment (KQ 4)

Among a general obstetric population, we assessed the evidence as moderate for no benefit of treatment on all-cause preterm delivery and low for no benefit of treatment on spontaneous preterm delivery. The funnel plot (Appendix G Figure 5) of studies reporting preterm delivery does not suggest publication bias. We downgraded the SOE for both outcomes because of imprecision and, in the case of spontaneous preterm delivery, also for inconsistency. With respect to precision, although preterm delivery was a primary outcome for most studies and most were powered based on this outcome, either a lower control group risk was observed than expected or the treatment effect observed was smaller than expected, resulting in imprecise estimates, particularly for RR estimates. This evidence is applicable to asymptomatic women and for use of oral metronidazole and oral or intravaginal clindamycin. Compared with the 2008 review, we added two RCTs and excluded two RCTs that were conducted in countries not categorized as very highly developed on the United Nations Human Development Index. Despite this change in the body of evidence, the overall conclusions about no benefit in a general obstetric population remain unchanged from the prior report.

Among women with a prior preterm delivery, we assessed the evidence as insufficient. We downgraded this evidence for both inconsistency and imprecision and note its applicability is largely for treatment with oral metronidazole. Three of four studies reported a statistically significant reduction, while one (Carey et al^111^) reported a nonstatistically significant increase in preterm delivery at less than 37 weeks. We are not able to explain the inconsistency in findings, as previously discussed in the results section. We also note that findings from three of these four studies were based on subgroup analyses, some of which were post hoc. The two studies reporting preterm delivery at less than 34 weeks did not observe any significant differences between groups, but results were very imprecise.

We did not identify any new studies for the population of women with a prior preterm delivery, but we note that the 2008 review included a study with a subgroup analysis for this population that was conducted in South Africa and that observed a statistically significant increase in preterm delivery for oral metronidazole compared with placebo for this population.^124^ As a result of the inconsistent body of evidence in 2008 review, the report authors were unable to draw a conclusion about benefits, and the USPSTF concluded in 2008 that the evidence was insufficient to make a recommendation in this population. We excluded the study from South Africa in the current body of evidence, and although this results in less inconsistency in findings than the 2008 report, we are still left with a serious unexplained inconsistency that limits our ability to conclude with even low certainty an effect or no effect of treatment in this population.

### Harms of Treatment (KQ 5)

We assessed the SOE for serious maternal AEs related to treatment as moderate for no difference for oral metronidazole and both oral and intravaginal clindamycin. We assessed the SOE for minor AEs as moderate for no difference for intravaginal clindamycin and as moderate for an increase in minor events for both oral metronidazole and oral clindamycin. We downgraded these bodies of evidence for imprecision because of relatively infrequent events.

We assessed the SOE for congenital malformations and incidence of cancer among children exposed to metronidazole in utero as insufficient. This body of evidence is comprised of observational studies with no more than fair methodological study quality, and despite large sample sizes, the incidence of these types of events was rare, resulting in imprecise estimates. This evidence applies to metronidazole exposure during pregnancy across a range of medical indications and is not specific to treatment for bacterial vaginosis.

## Limitations

This review was limited to English-language studies only. Further, we found no available evidence that directly evaluated the health benefits and harms of screening (KQs 1 and 3); thus, we assessed evidence from the indirect pathway on the analytic framework to link screening to health outcomes (KQs 2, 4, and 5).

For diagnostic test accuracy (KQ 2), limited evidence was available for pregnant, asymptomatic populations. We identified no publicly available studies for laboratory-developed multiplex PCR tests that are now available for commercial use from several national laboratories and only one study for the only FDA-approved multiplex PCR assay. Most studies were of only fair methodological quality, and for most tests, we observed moderate to substantial heterogeneity in estimates. Most studies used Gram stain as a reference standard; however, in light of the advances in the molecular and microbiological understanding of bacterial vaginosis, this may be an imperfect standard. We note that the current SOE assessment framework was not originally designed for evaluating diagnostic test accuracy bodies of evidence; such bodies of evidence typically include more inconsistency than bodies of evidence on interventions. Further, limited guidance exists to gauge consistency and precision domains for diagnostic test accuracy; thus, we tried to limit the subjectivity and increase transparency by providing a detailed rationale for each assessment. We did not formally assess the comparative accuracy of available tests. Lastly, we did not assess tests still in development for amine detection and some PCR assays because these tests are not commercially available or feasible for use in a primary care setting at this time.

For benefits of treatment (KQ 4) and maternal AEs (KQ 5), studies varied with respect to dose and duration of treatment, use of a test of cure, and methodological quality. Despite this variation, we were able to draw conclusions about treatment effects in a general obstetric population for preterm delivery at less than 37 weeks, although some uncertainty remains because some studies only reported spontaneous preterm delivery and not all-cause preterm delivery outcomes. The consequences related to preterm delivery generally do not differ for medically indicated deliveries vs. spontaneous deliveries; however, biased estimates of the treatment effect could be observed depending on how the outcomes were defined and ascertained. Because an indicated preterm delivery is a competing risk to a spontaneous preterm delivery, the use of spontaneous delivery outcomes could introduce informative censoring. Further, some studies may have only measured outcomes occurring after a specific gestational age (e.g., 22 weeks or later) and not all outcomes that occurred after the point of randomization. For example, treatment could result in a medical complication that results in an indicated or spontaneous abortion or delivery that occurs after randomization but before the reporting window begins.

The findings in women with a prior preterm delivery are inconsistent, and we were unable to identify sources for this inconsistency. With respect to harms, trials were underpowered for maternal AEs and we did not assess the comparative harms of treatment. This review was limited to only metronidazole and clindamycin, although other treatments for bacterial vaginosis are available but either have not been studied in pregnant women or are not considered first-line treatments in pregnant women.

Only observational studies were available to assess the harms to children related to in utero exposure to medications (KQ 5), and all of these studies included women exposed to metronidazole for any indication, including but not limited to bacterial vaginosis. We included them for continuity with the previous review and also included one study of harms from in utero exposure to medication that was included in the 2008 review but that we rated as poor methodological quality for this update. We note that the current SOE assessment approaches were designed for treatment interventions and favor RCT designs; most SOE approaches are not well suited for assessing harms from exposures, particularly when the evidence base is observational and when outcomes may be rare. Given the infeasibility of conducting randomized studies large enough and over a long enough duration to provide definitive evidence on in utero exposure, it is unlikely that this body of evidence could ever rise above an insufficient rating. However, we note the widespread and longstanding use of these medications in clinical practice.

## Future Research Needs

The most pressing future research need is for an adequately powered, definitive randomized trial of treatment for bacterial vaginosis in women with a previous preterm birth. Further, because bacterial vaginosis is only one of several possible risks that contribute to preterm delivery, future trials should ensure adequate measurement of other preterm delivery risks (e.g., short cervix, genitourinary infections, race/ethnicity) and report using all-cause preterm delivery outcomes. For the general obstetric population, future research may need to focus on screening or interventions for preterm delivery risks other than bacterial vaginosis or alternative treatments beyond a single-antibiotic approach, because existing treatment approaches in this population do not appear to be effective strategies.

Other needs include research on the performance of diagnostic tests for bacterial vaginosis in asymptomatic pregnant women to provide estimates of accuracy applicable to this specific population. Research is also needed to better understand the role of PCR and new molecular sequencing tests with respect to the current biological understanding of bacterial vaginosis and existing methods for clinical diagnosis and laboratory reference standards. Further, the development of new tests or treatments for bacterial vaginosis should ensure testing in pregnant populations to understand the effect on both mother and child.

## Conclusions

We identified no direct evidence that compared screening with no screening and that reported health outcomes. Diagnostic test accuracy studies were mostly conducted in nonpregnant, symptomatic women; across individual studies the sensitivity of the various tests ranged from 0.36 to 1.0 and the specificity ranged from 0.49 to 1.0. RCTs conducted in general obstetric populations reported no difference in the incidence of preterm delivery and related outcomes for treatment with metronidazole or clindamycin compared with placebo. The evidence is inconclusive for treatment in women with a prior preterm delivery. Maternal AEs from treatment with metronidazole or clindamycin are infrequent and minor. The observational study evidence about harms to children from in utero exposure to medication is inconclusive because of study limitations and imprecision.