# Chapter 3 Results

We screened 2,495 titles and abstracts and 368 full-text articles and identified 44 studies from 48 articles for inclusion (Figure 2). The list of articles excluded during full-text review is in Appendix C. We did not identify any direct evidence for benefits (KQ 1) or harms (KQ 3) of screening. We identified 25 studies of test accuracy (KQ 2) and 13 RCTs evaluating the benefits of treatment with respect to preterm delivery and related pregnancy outcomes (KQ 4). We identified 14 studies evaluating the harms of treatment in pregnancy (KQ 5).

Figure 2 Literature Flow Diagram for Systematic Review of Screening for Bacterial Vaginosis in Pregnant Adolescents and Women to Prevent Preterm Delivery

Abbreviation: KQ=key question.

Figure 2 is titled “Literature Flow Diagram for Systematic Review of Screening for Bacterial Vaginosis in Pregnant Adolescents and Women to Prevent Preterm Delivery.” This figure is a flow chart that summarizes the search and selection of articles. We identified 1,944 records through electronic database searches from 2006 through May 2019 and 3 records by hand search for screening at the title and abstract level. We identified an additional 548 from electronic database searches specific to the gap search for KQ 2 (inception to 2005). This resulted in a total of 2,495 titles and abstracts screened. Of these, 368 were deemed appropriate for full-text review to determine eligibility. After full-text review, 320 were excluded: 15 that were systematic reviews that we used for hand search, 32 for ineligible publication type, 57 for ineligible country, 42 for ineligible population, 89 for ineligible screening/intervention, 31 for ineligible or no comparator, 22 for ineligible or no outcome, 12 for ineligible study design, 6 for being a duplicate or outdated (more recent data were available), 4 for being a study protocol or in progress, 4 for ineligible language/non-English, 1 for poor quality, and 5 for other reasons. Forty-eight articles representing 44 studies were included in the synthesis of the systematic review. No studies were identified for KQ 1 or KQ 3. Twenty-five studies in 26 articles were identified for KQ 2. Thirteen studies in 16 articles were identified for KQ 4. Fourteen studies in 14 articles were identified for KQ 5.

## Diagnostic Test Accuracy (KQ 2)

Twenty-five cross-sectional diagnostic test accuracy studies reported test accuracy for BD Affirm, BD Max, BVBLUE, and Amsel’s clinical criteria (complete, modified, or individual components). Two of these studies (Gratacos et al^88^ and Mastrobattista et al^89^) were discussed in the previous update as part of a CQ; the rest are new to this update. Table 1 provides study characteristics and Tables 2–6 provide results organized by test. Appendix E Tables 1–6 provide our assessment of individual study methodological quality. We assessed six studies as good methodological quality;^88,^ ^90–94^ the others were assessed as fair quality generally because of unclear enrollment procedures and unclear information regarding blinding of index and reference test results. More than half of studies in this evidence base did not disclose source of funding. Of those studies disclosing funding sources, a mix of industry, government, and internal hospital/clinic support was identified. The rest of this section describes study characteristics and test accuracy findings organized by test and by pregnancy status when possible.

Table 1 Study Characteristics of Diagnostic Accuracy Studies (Key Question 2)

Author;; Year;; Country;; Tests Evaluated | Study Design and Quality | Study Population and Setting | Sample Size | Mean Age (SD) | Race/Ethnicity | No. (%) Symptomatic and Definition of Symptomatic (if Provided) | No. (%) With HIV | No. (%) Pregnant
Bradshaw et al^100^;; 2005;; Australia;; BVBLUE, complete Amsel’s clinical criteria, individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; fair | Women who presented with symptoms of abnormal vaginal discharge or odor at a single-center sexual health clinic, excluding women who were pregnant, postmenopausal, HIV-infected, menstruating, or who had used lubricant or topical vaginal medication within 72 hours | 288 enrolled and 288 analyzed for BVBLUE and complete Amsel, 252 analyzed for clue cells and vaginal discharge, 251 analyzed for whiff test, 250 analyzed for pH | 29 (8) | NR | 288 (100) (presumably based on study entry criteria); Abnormal vaginal discharge or odor | 0 (0) (presumably based on study entry criteria) | 0 (0) (presumably based on study entry criteria)
Briselden et al^96^;; 1994;; United States;; BD Affirm | Cross-sectional; fair | Women at a single center being seen for new genital complaints at a hospital-based STD clinic | 176 enrolled and analyzed | NR | 300 (93%) African American; 23 (7%) non-Hispanic white | 176 (100) (presumably based on study entry criteria); New genital complaints | NR | NR
Byun et al^90^;; 2016;; South Korea;; BD Affirm | Cross-sectional; good | Women at a single-center outpatient hospital gynecology clinic, excluded menstruating women, coitus within 24 hours, recent antibiotic or antifungal treatment | 200 enrolled, 195 analyzed | 41.7 (10.2) | NR | 152 (76); Odorous vaginal discharge, vaginal itching, dyspareunia, dysuria, vaginal burning | NR | 3 (1.53*)
Cartwright et al^95^;; 2013;; United States;; BD Affirm | Cross-sectional; fair | Women presenting with clinically documented vaginitis syndrome at one of two sexually transmitted infection clinics (one at a local health department and one at a university hospital); no antibiotics or vaginal medication use within previous 14 days | NR enrolled, 305 analyzed | Median 24 (range 19 to 60) | NR | 323 (100) (presumably based on study entry criteria); Presenting with clinically documented vaginitis | NR | NR
Chen et al^110^;; 2018;; Taiwan;; Complete Amsel’s clinical criteria | Cross-sectional; fair | Nonpregnant women with a history of sexual activity who had not taken antibiotics or vaginal antimicrobials within 2 months, recruited from hospital-based department of obstetrics and gynecology | 77 enrolled, 77 analyzed | Median 41 (NR) | NR | NR | NR | 0 (0)
Gallo et al^103^;; 2011;; United States;; Complete Amsel’s clinical criteria | Cross-sectional; fair | Women ages 16 to 55 years who do not have an AIDS-defining clinical diagnosis and are either injection drug users or had high-risk sexual behaviors visiting one of four sites | 1,310 enrolled, 6,135 HIV-positive and 3,005 HIV-negative; visits analyzed from 1,283 participants | Median 35 (NR) | 744* (58%) black; 308* (24%) white; 218* (17%) Hispanic; 13* (1%) other | NR | 862 (67.2*) participants, 6,135 (67.1*) visits | NR
Gratacos et al^88^;; 2005;; Spain;; Complete Amsel’s clinical criteria, modified Amsel’s clinical criteria, individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; good | Asymptomatic women with singleton pregnancies starting their antenatal care before 28 weeks at low-risk pregnancy clinics | NR enrolled, 492 analyzed | 27.5 (5.5) | NR | 0 (0) (presumably based on study entry criteria) | NR | 492 (100) (presumably based on study entry criteria)
Gutman et al^109^;; 2005;; United States;; Complete Amsel’s clinical criteria, individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; fair | Women at a single-center hospital outpatient clinic: primary care, colposcopy, or division of research | NR enrolled, 269 analyzed | NR overall; Positive for BV: 25.4 (7.7); Negative for BV: 23.3 (6.5) | NR | NR overall; Positive for BV: 47 (45); Negative for BV: 41 (25); Vaginal discharge, foul smelling odor, vaginal itching, or vaginal burning | 1 (0.4) | 35 (13)
Hay et al^91^;; 1992;; United Kingdom;; Complete Amsel’s clinical criteria, individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; good | Women at a single center, hospital-based gynecology clinic. | 118 enrolled, 114 analyzed | 36.2 (range 16 to 65) | NR | 3 (2.6); Vaginal discharge | NR | NR
Hellberg et al^93^;; 2001;; Sweden;; Individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; good | Women with certain predetermined positions on the outpatients list attending a family planning clinic for contraceptive advice | 1011 enrolled, 956 analyzed | NR overall; Positive for BV: 26.6 (NR); Negative for BV: 25.7 (NR) | NR | NR | NR | NR
Hillier et al^101^;; 2011;; United States;; BVBLUE, complete Amsel’s clinical criteria | Cross-sectional; fair | Nonmenstruating and nonpregnant women between ages 18 and 60 years, with or without symptoms of vaginitis, recruited from Magee-Womens Hospital of University of Pittsburgh Medical Center and Allegheny County Health Department | 519 enrolled, 519 analyzed | 27.6 (8.6) | NR | 251 (48.4); Abnormal vaginal odor, abnormal vaginal discharge, pruritis, vaginal burning or pain, vaginal irritation, or lower abdominal pain | NR | 0 (0) (presumably based on study entry criteria)
Hilmarsdottir et al^104^;; 2006;; Iceland;; Complete Amsel’s clinical criteria | Cross-sectional; fair | Women at a single-center hospital-based sexually transmitted infection clinic | NR enrolled, 327 analyzed | 22 (range 14 to 58) | NR | NR | NR | NR
Landers et al^105^;; 2004;; United States;; Complete Amsel’s clinical criteria | Cross-sectional; fair | Nonpregnant women between ages 18 and 45 years with one or more untreated genital complaints at three sites associated with an academic medical center | 598 enrolled, 548 analyzed | NR | 363 (60%) African American; 190 (32%) white; 4 (0.6%) Asian; 3 (0.5%) Hispanic; 6 (1%) other; 32 (5%) multiethnic or biracial | 598 (100) (presumably based on study entry criteria) Untreated genital complaint | NR | 0 (0) (presumably based on study entry criteria)
Lowe et al^97^;; 2009;; United States;; BD Affirm | Cross-sectional; fair | Active-duty military women who presented for health care with vulvovaginal symptoms at one of four troop medical clinics in the U.S. Army or Navy; excluded for menstruation or had coitus within previous 24 hours | 547 enrolled, 535 analyzed | 25.7 (5.8) | 230 (43.0%) African American; 97 (18.1%) Hispanic; 168 (31.4%) white; 40 (7.5%) other | 547 (100) (presumably based on study entry criteria); Vulvovaginal symptoms such as abnormal discharge, itching/irritation, malodor, vulvar burning, vulvar pain, vaginal discomfort, and others | NR | NR
Mastrobattista et al^89^;; 2000;; United States;; Modified Amsel’s clinical criteria, individual criteria (pH, clue cells, whiff test) | Cross-sectional; fair | Asymptomatic pregnant women initiating prenatal care in academic obstetric clinics, excluding women with antimicrobial use within 2 weeks, cervical cerclage, vaginal bleeding, placenta previa, spermicide use, recent douching, or sexual intercourse within 8 hours | 69 enrolled, 67 analyzed | 27.3 (6.6) | 28 (41%) African American; 23 (38%) white; 15 (22%) Hispanic; 3 (4%) Asian | 0 (0) (presumably based on study entry criteria) | NR | 69 (100) (presumably based on study entry criteria)
Myziuk et al^102^;; 2003;; Canada;; BVBLUE, complete Amsel’s clinical criteria, individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; fair | Nonmenstruating women age 16 years and older who presented for a pelvic examination, regardless of the reason, at a single-center STD clinic and an infectious disease referral practice | 57 enrolled, 57 analyzed | 30.7 (NR) | NR | 31 (54); Abnormal discharge | 2 (3.5) | NR
Platz-Christensen et al^92^;; 1995;; Sweden;; Complete Amsel’s clinical criteria, individual criteria (clue cells) | Cross-sectional; good | Nonpregnant women of childbearing age without vaginal bleeding and antibiotic treatment within the last month at one university-based hospital outpatient clinic | NR enrolled, 107 analyzed | NR | NR | NR | NR | 0 (0) (presumably based on study entry criteria)
Rouse et al^136^;; 2009;; United States;; Individual criteria (pH, clue cells) | Cross-sectional; fair for pH and clue cells, poor for whiff test and complete Amsel | Pregnant patients presenting for emergency care who were not bleeding but required a speculum examination at a community hospital | 220 enrolled, 193 analyzed for clue cell, 189 analyzed for with pH | NR | NR | 220 (100); Self-reported discharge, pruritis, burning, and odor | NR | 193 (100)
Schmidt et al^94^;; 1994;; Denmark;; Individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; good | Nonpregnant, nonmenstruating women who did or did not complain of vaginal discharge and were gynecologically examined at a general practice | NR enrolled, 188 with complaint of discharge analyzed, 407 without complaint of discharge analyzed | Median 31 | NR | 188 (31.6); Complained of vaginal discharge | NR | 0 (0)
Schwebke et al^108^;; 1996;; United States;; Complete Amsel’s clinical criteria, modified Amsel’s clinical criteria, individual criteria (pH, clue cells) | Cross-sectional; fair | Women undergoing pelvic examination for evaluation of a new complaint at STD clinics and hospital-based gynecology clinics | 617 enrolled, 617 analyzed | 30.2 (NR) | NR | NR | NR | NR
Schwebke et al^99^; Gaydos et al^65^;; 2018/2017;; United States;; BD Max, complete Amsel’s clinical criteria, modified Amsel’s clinical criteria, individual criteria (pH, vaginal discharge, clue cells, whiff test) | Cross-sectional; fair | Women at least age 14 or 18 years (depending on clinic) reporting symptoms of vaginitis at a routine clinical visit at an academic medical center or community clinic identified as a STD, HIV, family planning, and/or gynecology clinic | 1,740 enrolled, 1,301 analyzed for complete and modified Amsel, 1,338 analyzed for BD Max | NR for BV test subgroup Parent study (N=1,667): 29.3 (9.4) | NR | 1,760 (100) (presumably based on study entry criteria); Abnormal discharge; painful or frequent urination; vaginal itching, burning, or irritation; painful or uncomfortable intercourse; vaginal odor | NR for BV test subgroup.; Parent study (N=1,667): 17 (1.0) positive, 257 (15.3) unknown | NR
Sha et al^106^;; 2007;; United States;; Complete Amsel’s clinical criteria | Cross-sectional; fair | HIV-infected women and HIV-negative women who were at risk women at 6 sites | 3,784 enrolled, 16,263 HIV-positive and 4,325 HIV-negative visits analyzed from 3,784 participants | NR | NR | NR | 2,808 (74.2*) participants, 16,263 (80.0*) visits | NR
Singh et al^107^;; 2013;; United States;; Complete Amsel’s clinical criteria, modified Amsel’s clinical criteria | Cross-sectional; fair | Nonpregnant women ages 18 to 45 years with symptoms of abnormal vaginal discharge but no abnormal vaginal bleeding at a single STI clinic | 200 enrolled, 197 analyzed | 28.1 (7.6) | NR | 197 (100) (presumably based on study entry criteria); Symptoms of vaginal discharge | NR | 0 (0) (presumably based on study entry criteria)
Sonnex et al^137^;; 1995;; United Kingdom;; Individual criteria (whiff test) | Cross-sectional; fair | Women attending three general practices or a hospital-based genitourinary clinic in the Cambridge area | 297 recruited and analyzed from general practices; 164 from genitourinary clinic | 35 (NR) general practice; 24 (NR) genitourinary clinic | NR | 135 (45.5) had vaginal discharge;; 46 (15.5) had vaginal discharge and malodor from general practice;; 54 (32.9) had vaginal discharge from genitourinary clinic | NR | NR
Witt et al^98^;; 2002;; Austria;; BD Affirm | Cross-sectional; fair | Pregnant women seen at academic outpatient obstetrics clinic between 12 and 36 weeks gestation | 1,725 enrolled and analyzed | NR | NR | 1,725 (100) (presumably based on study entry criteria); Clinical signs of vaginal infection including increased vaginal discharge, pruritus, burning, cervical incompetence, lower abdominal pain, preterm labor, or preterm rupture of membranes | NR | 1,725 (100) (presumably based on study entry criteria)

Abbreviations: AIDS=acquired immune deficiency syndrome; BV=bacterial vaginosis; HIV=human immunodeficiency virus; KQ=key question; No.=number of participants; NR=not reported; pH=logarithmic scale used to specify the acidity or basicity of an aqueous solution; SD=standard deviation; STD=sexually transmitted disease; STI=sexually transmitted infection.

Table 2 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—BD Affirm VPIII (Key Question 2)

Author;; Year; Country | Reference Test | N (%) With Confirmed BV on Referent Test | Sensitivity (95% CI) | Specificity (95% CI) | Positive Likelihood Ratio | Negative Likelihood Ratio | Other Comments
Briselden et al^96^; 1994;; United States | Gram stain (Nugent score ≥7) | 79 (45.0) | 0.94 (NR) | 0.81 (NR) | 5.1^*^ (3.3^*^ to 7.7^*^) | 0.08^*^ (0.03^*^ to 0.18^*^) | None
Byun et al^90^;; 2016; South Korea | Gram stain (Nugent score ≥7) | 68 (34.9) | 0.75 (NR) | 0.89 (NR) | 6.8^*^ (4.1^*^ 11.4^*^) | 0.28^*^ (0.19^*^ to 0.43^*^) | None
Cartwright et al^95^;; 2013;; United States | Gram stain (Nugent score ≥7) or Gram stain (Nugent score 4 to 6 plus positive for BV based on Amsel’s clinical criteria) | 197 (64.6) | 0.90 (0.86 to 0.94) | 0.68 (0.63 to 0.72) | 2.8^*^ (2.1^*^ to 3.7^*^) | 0.14^*^ (0.09^*^ to 0.21^*^) | If intermediate flora (Nugent score 4 to 6) excluded, then specificity increases to 0.76
Lowe et al^97^;; 2009;; United States | Complete Amsel’s clinical criteria (number of criteria NR) | 319 (59.6) | 0.79^*^ (0.74^*^ to 0.83^*^) | 0.72^*^ (0.66^*^ to 0.78^*^) | 2.8^*^ (2.3^*^ to 3.6^*^) | 0.29^*^ (0.23^*^ to 0.37^*^) | None
Witt et al^98^;; 2002;; Austria | Gram stain (Nugent score ≥7) | 171 (9.9) | 0.89^*^ (0.84^*^ to 0.93^*^) | 0.88^*^ (0.87^*^ to 0.90^*^) | 7.6^*^ (6.6^*^ to 8.8^*^) | 0.12^*^ (0.08^*^ to 0.19^*^) | When participants with Nugent score 4 to 6 are excluded (N=235), the sensitivity is 0.90 (95% CI, 0.85 to 0.94) and the specificity is 0.97 (95% CI, 0.96 to 0.98). When participant with Nugent score 4 to 6 are included and considered positive for BV, the sensitivity is 0.73 (95% CI, 0.69 to 0.78) and specificity is 0.97 (0.96 to 0.98)

* Indicates values that we calculated based on data provided in the study.

Abbreviations: BV=bacterial vaginosis; CI=confidence interval; KQ=key question; N=number of participants; NR=not reported.

Table 3 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—BD MAX (Key Question 2)

Author;; Year; Country | Reference Test | N (%) With Confirmed BV on Referent Test | Sensitivity (95% CI) | Specificity (95% CI) | Positive Likelihood Ratio | Negative Likelihood Ratio | Other Comments
Schwebke et al^99^; Gaydos et al^65^;; 2018/2017;; United States | Gram stain (Nugent score ≥7); participants with Nugent score 4 to 6 were excluded (N=213) | 783 (50.5^*^) | 0.93 (0.91 to 0.94) | 0.92 (0.90 to 0.94) | 10.9^*^ (8.3^*^ to 14.5^*^) | 0.08^*^ (0.06^*^ to 0.10^*^) | Analysis excludes participants with missing Amsel’s clinical criteria test (N=37). In addition, Gaydos et al^65^ includes participants with intermediate Nugent scores and a positive modified Amsel test as positive for BV (N=1,559) and had a sensitivity of 0.905 (95% CI, 0.883 to 0.922) and specificity of 0.858 (95% CI, 0.830 to 0.883)

* Indicates values that we calculated based on data provided in the study.

Abbreviations: BV=bacterial vaginosis; CI=confidence interval; KQ=key question; N=number of participants.

Table 4 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—BV Blue (Key Question 2)

Author;; Year; Country | Reference Test | N (%) With Confirmed BV on Referent Test | Sensitivity (95% CI) | Specificity (95% CI) | Positive Likelihood Ratio | Negative Likelihood Ratio | Other Comments
Bradshaw et al^100^;; 2005;; Australia | Gram stain (Nugent score ≥7) | 108 (38) | 0.88^*^ (0.81^*^ to 0.93^*^) | 0.86^*^ (0.80^*^ to 0.91^*^) | 6.3^*^ (4.4^*^ to 9.2^*^) | 0.14^*^ (0.08^*^ to 0.23^*^) | Excluding participants with intermediate flora had sensitivity of 0.88 (95% CI, 0.81 to 0.93) and specificity of 0.95 (95% CI, 0.91 to 0.98). Considering participants with intermediate flora as positive had sensitivity of 0.79 (95% CI, 0.72 to 0.85) and specificity of 0.97 (95% CI, 0.92 to 0.99).
Bradshaw et al^100^;; 2005;; Australia | Complete Amsel’s clinical criteria (at least three of four) | 118 (41) | 0.88 (0.81 to 0.93) | 0.91 (0.85 to 0.94) | 10.0^*^ (6.1^*^ to 16.3^*^) | 0.13^*^ (0.08^*^ to 0.21^*^) | Excluding participants with intermediate flora had sensitivity of 0.92 (95% CI, 0.85 to 0.96) and specificity of 0.93 (95% CI, 0.88 to 0.96).
Hillier et al^101^;; 2011;; United States | Gram stain (Nugent score ≥7) | NR | 0.61 (0.51 to 0.71) | 0.99 (0.96 to 1.0) | NR | NR | For symptomatic women (N=251), sensitivity is 0.68 (95% CI, 0.60 to 0.76) and specificity is 1.0 (95% CI, 0.96 to 1.0).
Myziuk et al^102^; 2003;; Canada | Gram stain (Nugent score ≥7) | 12 (21.1^*^) | 0.92 (0.65^*^ to 0.996^*^) | 0.98 (0.90^*^ to 0.999^*^) | 41.3^*^ (5.9^*^ to 288.6^*^) | 0.09^*^ (0.01^*^ to 0.56^*^) | None

* Indicates values that we calculated based on data provided in the study.

Abbreviations: BV=bacterial vaginosis; CI=confidence interval; KQ=key question; N=number of participants; NR=not reported.

Table 5 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—Complete Amsel’s Clinical Criteria (Key Question 2)

Author;; Year; Country | Reference Test | N (%) With Confirmed BV on Referent Test | Sensitivity (95% CI) | Specificity (95% CI) | Positive Likelihood Ratio | Negative Likelihood Ratio | Other Comments
Bradshaw et al^100^;; 2005;; Australia | Gram stain (Nugent score ≥7) | 108 (38) | 0.91^*^ (0.84^*^ to 0.95^*^) | 0.90^*^ (0.83^*^ to 0.93^*^) | 8.2^*^ (5.4^*^ to 12.4^*^) | 0.10^*^ (0.06^*^ to 0.19^*^) | Excluding participants with intermediate flora had sensitivity of 0.91 (95% CI, 0.84 to 0.96) and specificity of 0.99 (95% CI, 0.96 to 1.0).
Chen et al^110^;; 2018;; Taiwan | Gram stain (Nugent score ≥7) | 12 (15.6^*^) | 0.92^*^ (0.65^*^ to 0.99^*^) | 0.49^*^ (0.37^*^ to 0.61^*^) | 1.8^*^ (1.4^*^ to 2.4^*^) | 0.17^*^ (0.03^*^ to 1.1^*^) | None
Gallo et al^103^;; 2011;; United States | Gram stain (Nugent score ≥7) | HIV positive: 1,046 (34.8); HIV negative: 2,347 (38.3); (from visits, not number of participants) | HIV positive: 0.58 (0.56 to 0.60); HIV negative: 0.63 (0.60 to 0.66) | HIV positive: 0.90 (0.89 to 0.91); HIV negative: 0.91 (0.90 to 0.92) | HIV positive: 5.6^*^ (5.1^*^ to 6.2^*^); HIV negative: 6.8^*^ (5.9^*^ to 7.9^*^) | HIV positive: 0.47^*^ (0.45^*^ to 0.49^*^); HIV negative: 0.41^*^ (0.38^*^ to 0.44^*^) | Only data from the HIV-negative population was used in our synthesis (i.e., SROC and forest plot)
Gratacos et al^88^;; 2005;; Spain | Gram stain (Nugent score ≥7) | 22 (4.5) | 0.36 (0.20^*^ to 0.57^*^) | 0.99 (0.98^*^ to 1.0^*^) | 34.2^*^ (12.2^*^ to 96.0^*^) | 0.64^*^ (0.47^*^ to 0.88^*^) | None
Gutman et al^109^;; 2005;; United States | Gram stain (Nugent score ≥7) | 104 (38.7) | 0.69 (0.59 to 0.78) | 0.93 (0.87 to 0.96) | 9.5^*^ (5.4^*^ to 16.7^*^) | 0.33^*^ (0.25^*^ to 0.44^*^) | AUC is 0.8
Hay et al^91^;; 1992;; U.K. | Gram stain (Spiegel’s criteria) | 13 (11.4) | 1.0^*^ (0.77^*^ to 1.0^*^) | 1.0 (0.96^*^ to 1.0^*^) | Infinite^*^ | 0^*^ | None
Hillier et al^101^;; 2011;; United States | Gram stain (Nugent score ≥7) | NR | 0.67 (0.57 to 0.76) | 1.0 (0.98 to 1.0) | NR | NR | For symptomatic women (N=251), sensitivity is 0.82 (95% CI, 0.75 to 0.88) and specificity is 0.94 (95% CI, 0.87 to 0.98)
Hilmarsdottir et al^104^;; 2006;; Iceland | Gram stain (Nugent score ≥7) | 115 (35.2) | 0.79 (0.71^*^ to 0.86^*^) | 0.93 (0.89^*^ to 0.96^*^) | 11.2 (6.9 to 18.4) | 0.23^*^ (0.16^*^ to 0.32^*^) | LR+: 11.2 (6.9 to 18.4); Note: The number of false-positive results was incorrectly reported in the text.
Landers et al^105^;; 2004;; United States | Gram stain (not described, presumably Nugent score ≥7) | 276 (46) | 0.92 (0.88^*^ to 0.95^*^) | 0.77 (0.71^*^ to 0.81^*^) | 4.0^*^ (3.2^*^ to 4.9^*^) | 0.11^*^ (0.07^*^ to 0.16^*^) | None
Myziuk et al^102^;; 2003;; Canada | Gram stain (Nugent score ≥7) | 12 (21.1^*^) | 0.50^*^ (0.25^*^ to 0.75^*^) | 1.0^*^ (0.92^*^ to 1.0^*^) | Infinite^*^ | 0.50^*^ (0.28^*^ to 0.88^*^) | None
Platz-Christensen et al^92^;; 1995;; Sweden | Gram stain (Spiegel’s criteria) | 36 (33.3^*^) | 0.94^*^ (0.82^*^ to 0.98^*^) | 1.0^*^ (0.95^*^ to 1.0^*^) | Infinite^*^ | 0.06^*^ (0.01^*^ to 0.21^*^) | Note: The study authors report sensitivity and specificity for Amsel’s clinical criteria as the referent test and Gram stain as the index test.
Sha et al^106^;; 2007;; United States | Gram stain (Nugent score ≥7) | HIV positive: 6,050 (37.2^*^); HIV negative: 1,880 (43.5^*^); (from visits, not number of participants) | HIV positive: 0.36 (0.35 to 0.37); HIV negative: 0.39 (0.36 to 0.41) | HIV positive: 0.971 (0.967 to 0.974); HIV negative: 0.978 (0.971 to 0.983) | HIV positive: 12.2^*^ (10.8^*^ to 13.7^*^); HIV negative: 17.2^*^ (13.2^*^ to 22.5^*^) | HIV positive: 0.66^*^ (0.65^*^ to 0.68^*^); HIV negative: 0.63^*^ (0.61^*^ to 0.65^*^) | Only data from the HIV-negative population were used in our synthesis (i.e., SROC and forest plot).
Schwebke et al^108^;; 1996;; United States | Gram stain (Nugent score ≥7) | 243 (39.4) | 0.62 (0.55^*^ to 0.68^*^) | 0.97 (0.94^*^ to 0.98^*^) | 17.8^*^ (10.3^*^ to 30.6^*^) | 0.40^*^ (0.34^*^ to 0.47^*^) | If “any clue cells” criteria used in place of 20% clue cells, the sensitivity is 0.704 and specificity is 0.944.
Schwebke et al^99^; Gaydos et al^65^;; 2018/2017;; United States | Gram stain (Nugent score ≥7); participants with Nugent score 4 to 6 were excluded (N=213) | 783 (50.5^*^) | 0.76 (0.72 to 0.79) | 0.94 (0.92 to 0.96) | 12.8^*^ (9.2^*^ to 18.0^*^) | 0.26^*^ (0.23^*^ to 0.30^*^) | None
Singh et al^107^;; 2013;; United States | Gram stain (Nugent score ≥7) | 125 (63.5^*^) | 0.72^*^ (0.64^*^ to 0.79^*^) | 0.79^*^ (0.68^*^ to 0.87^*^) | 3.5^*^ (2.2^*^ to 5.5^*^) | 0.35^*^ (0.26^*^ to 0.48^*^) | None

* Indicates values that we calculated based on data provided in the study.

Abbreviations: AUC=area under the curve; CI=confidence interval; HIV=human immunodeficiency virus; KQ=key question; LR+= positive likelihood ratio; N=number of participants; SROC=summary receiver operating characteristics.

Table 6 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—Modified Amsel’s Clinical Criteria (Key Question 2)

Author;; Year;; Country | Reference Test | N (%) with Confirmed BV on Referent Test | Sensitivity (95% CI) | Specificity (95% CI) | Positive Likelihood Ratio | Negative Likelihood Ratio | Other Comments
Gratacos et al^88^;; 2005;; Spain | Gram stain (Nugent score ≥7) | 22 (4.5) | 0.64 (0.43^*^ to 0.80^*^) | 0.98 (0.96^*^ to 0.99^*^) | 33.2^*^ (16.2^*^ to 68.3^*^) | 0.37^*^ (0.21^*^ to 0.64^*^) | None
Mastrobattista et al^89^;; 2000;; United States | Gram stain (Nugent score ≥7) | 18 (26.9^*^) | 0.56 (0.32 to 0.78) | 0.96 (0.90 to 1.0) | 13.6^*^ (3.3^*^ to 56.2^*^) | 0.46^*^ (0.28^*^ to 0.78^*^) | None
Schwebke et al^108^;; 1996;; United States | Gram stain (Nugent score ≥7) | 243 (39.4) | 0.63 (0.57 to 0.69) | 0.96 (0.94 to 0.98) | 16.8^*^ (10.0^*^ to 28.4^*^) | 0.39^*^ (0.33^*^ to 0.45^*^) | None
Schwebke et al^99^; Gaydos et al^65^;; 2018/2017;; United States | Gram stain (Nugent score ≥7); participants with Nugent score 4 to 6 were excluded (N=213) | 783 (50.5^*^) | 0.82 (0.79 to 0.85) | 0.91 (0.88 to 0.93) | 8.8^*^ (6.7^*^ to 11.4^*^) | 0.20^*^ (0.17^*^ to 0.23^*^) | None
Singh et al^107^;; 2013;; United States | Gram stain (Nugent score ≥7) | 125 (63.5^*^) | 0.54^*^ (NR) | NR | NR | NR | None

* Indicates values that we calculated based on data provided in the study.

Abbreviations: BV=bacterial vaginosis; CI=confidence interval; KQ=key question; N=number of participants; NR=not reported.

### BD Affirm

Five cross-sectional diagnostic test accuracy studies conducted among 2,936 participants evaluated the BD Affirm VPIII microbial identification test, which is a nonamplified nucleic acid probe-based test specific to G. vaginalis and T. vaginalis.^90,^ ^95–98^ One study (Witt et al) was performed exclusively in a population of pregnant women.^98^ Four studies (Briselden et al,^96^ Cartwright et al,^95^ Lowe et al,^97^ and Witt et al^98^) exclusively enrolled symptomatic women, and 76 percent of the study population in the fifth study (Byun et al^90^) was symptomatic. Briselden et al^96^ and Cartwright et al^95^ recruited participants from STI clinics in the United States. Lowe et al recruited participants from U.S. military health clinics.^97^ Byun et al^90^ recruited participants from a hospital-based outpatient gynecology clinic in South Korea, and Witt et al^98^ recruited participants from an academic obstetrics clinic in Austria. Race/ethnicity of participants was reported by only two studies; 93 percent of participants were African American in Briselden et al^96^ and 43 percent were African American in Lowe et al. HIV status of participants was not reported by any study. The reference test in four studies was a Gram stain of vaginal secretions interpreted according to the criteria of Nugent et al (i.e., score of 7 or higher was positive for bacterial vaginosis), while Lowe et al^97^ used complete Amsel’s clinical criteria as the reference test. The prevalence of bacterial vaginosis in the enrolled study populations according to the reference standards used in each study ranged from 9.9 to 64.6 percent. We assessed Byun et al^90^ as having good methodological quality and assessed the other four studies as having fair methodological quality.

Table 2 provides results from individual studies. Appendix F Figure 1 depicts the SROC curve comparing BD Affirm with the reference test, and Appendix F Figure 2 displays a forest plot with individual study characteristics and sensitivity and specificity estimates. The pooled sensitivity based on five studies (2,936 participants) was 0.87 (95% CI, 0.80 to 0.92) and the pooled specificity was 0.81 (95% CI, 0.73 to 0.88). The pooled positive likelihood ratio was 4.6 (95% CI, 3.1 to 6.8), and the pooled negative likelihood ratio was 0.16 (95% CI, 0.11 to 0.26). The AUC associated with the SROC curve was 0.91 (95% CI, 0.87 to 0.94). The 95 percent prediction region covered nearly one third of the ROC space, suggesting moderate heterogeneity in the pooled estimates beyond what would be expected due to chance variation. We were unable to qualitatively identify any specific study or population characteristics (e.g., country, mean age of enrolled participants, percentage with symptoms, prevalence of bacterial vaginosis in enrolled population, setting of enrollment, pregnancy status, reference test used) that could explain this heterogeneity.

### BD Max

One cross-sectional diagnostic test accuracy study among 1,338 participants evaluated the BD Max Vaginal panel, which is a multiplex PCR assay that uses nucleic acid amplification to identify up to five species associated with bacterial vaginosis.^65,^ ^99^ In this study, reported in Schwebke et al^99^ and Gaydos et al,^65^ participants were recruited from 10 U.S. academic or community-based gynecology clinics and had symptomatic vaginitis. The authors did not report the race/ethnicity, pregnancy status, or HIV status of women in this analysis. The reference test used in this study was a Gram stain of vaginal secretions interpreted according to the criteria of Nugent et al. Notably, participants with Nugent scores between 4 and 6 were excluded from the analysis. We assessed this study as fair methodological quality. The prevalence of bacterial vaginosis in the study population according to the reference test was 50.5 percent. Table 3 provides results for this study. Authors reported the sensitivity of BD Max as 0.93 (95% CI, 0.91 to 0.94) and the specificity as 0.92 (95% CI, 0.90 to 0.94). We calculated the positive likelihood ratio as 10.9 and the negative likelihood ratio as 0.08.

### BVBLUE

Three cross-sectional diagnostic test accuracy studies conducted among 864 participants reported test accuracy characteristics for the BVBLUE test, which is an assay of vaginal secretions for sialidase enzyme activity.^100–102^ Two studies (Bradshaw et al,^100^ Hillier et al^101^) specifically excluded pregnant women; one study (Myziuk et al^102^) did not report the pregnancy status of enrolled women. Bradshaw et al^100^ recruited women from sexual health clinics in Australia and exclusively enrolled symptomatic women. About half of the women in the other two studies were symptomatic; Hillier et al^101^ recruited participants from a U.S. academic gynecology clinic and a local health department clinic, and Myziuk et al^102^ recruited participants from a single STI clinic in Canada. Race/ethnicity was not reported by any study, and the HIV prevalence was 0 percent in Bradshaw et al,^100^ 3.5 percent in Myziuk et al,^102^ and not reported by Hillier et al.^101^

All studies used a Gram stain interpreted using the criteria of Nugent et al as the reference test. The prevalence of bacterial vaginosis based on the reference test used was 38 and 21.1 percent in two studies and was not reported in Hillier et al.^101^ We assessed all three studies as fair methodological quality. We were unable to generate pooled estimates of test accuracy because of incomplete data provided in Hillier et al.^101^

Table 4 provides results from individual studies. Bradshaw et al reported test accuracy characteristics of the BVBLUE test with respect to two different reference tests. Using the reference test of a Gram stain interpreted according to the criteria of Nugent et al, the sensitivity was 0.88 (95% CI, 0.81 to 0.93) and the specificity was 0.86 (95% CI, 0.80 to 0.91).^100^ Using the reference test of Amsel’s clinical criteria (positive findings on three of the four criteria), the sensitivity was the same, but the specificity was slightly higher (0.91 [95% CI, 0.85 to 0.94]). Hillier et al reported a sensitivity of 0.61 (95% CI, 0.51 to 0.71) and a specificity of 0.99 (95% CI, 0.96 to 1.0); estimates were higher when limited to only symptomatic individuals.^101^ Myziuk et al reported a sensitivity of 0.92 (95% CI, 0.65 to 0.996) and a specificity of 0.98 (95% CI, 0.90 to 0.999).

### Complete Amsel’s Clinical Criteria

Fifteen cross-sectional diagnostic test accuracy studies conducted among 7,171 participants reported test accuracy characteristics of complete Amsel’s clinical criteria.^88,^ ^91,^ ^92,^ ^99–110^ One study (Gratacos et al;^88^ N=492) exclusively enrolled asymptomatic pregnant women, and one study (Gutman et al;^109^ N=269) included pregnant women, but they represented only 13 percent of the study population. The rest of the studies either excluded pregnant women or did not report on the pregnancy status of enrolled participants. Studies differed in the percentage of included women who were reported as being symptomatic. The study populations in two studies (Gratacos et al^88^ and Hay et al^91^) were nearly all asymptomatic. Six studies did not report the symptom status of enrolled participants, and the rest of the studies either exclusively enrolled symptomatic participants or nearly third to half of the enrolled populations were symptomatic. The settings used to enroll participants varied from single-center STI clinics to multicenter academic or hospital-based gynecology clinics. Eight studies were conducted in the United States. Two of the U.S. studies recruited participants enrolled in longitudinal prospective cohort studies of participants with HIV or at risk for HIV.^103,^ ^106^ The prevalence of HIV among participants in these studies was 67 percent in Gallo et al and 74 percent in Sha et al. Results for these studies were stratified by HIV status. The rest of the studies either excluded HIV-positive participants or did not report the HIV status of enrolled participants.

Two studies (Platz-Christensen et al^92^ and Hay et al^91^) used a Gram stain of vaginal secretions interpreted according to the criteria of Spiegel et al as the reference test; the rest of the studies used a Gram stain interpreted according to the criteria of Nugent et al. The prevalence of bacterial vaginosis based on the reference test used ranged from 4.5 to 63.5 percent across studies. We assessed three studies (Gratacos et al,^88^ Hay et al,^91^ and Platz-Christensen et al^92^) as good methodological quality and assessed the rest as fair methodological quality.

Table 5 provides results from individual studies. Appendix F Figure 3 depicts the SROC curve for complete Amsel’s clinical criteria compared with the reference test, and Appendix F Figure 4 displays a forest plot with individual study characteristics and sensitivity and specificity estimates. The pooled sensitivity based on 14 studies (5,790 participants) was 0.76 (95% CI, 0.63 to 0.85), and the pooled specificity was 0.95 (95% CI, 0.89 to 0.98). The pooled positive likelihood ratio was 14.1 (95% CI, 6.8 to 29.2), the pooled negative likelihood ratio was 0.26 (95% CI, 0.17 to 0.39), and the AUC was 0.93 (95% CI, 0.89 to 0.95). The 95 percent prediction region covered more than one third of the SROC space, indicating substantial heterogeneity with respect to the estimate of sensitivity and specificity that cannot be explained by chance variation. We explored several potential sources of heterogeneity, including how participants with intermediate flora were handled in the analysis (included or excluded), the number of Amsel’s clinical criteria required for a “positive” test (three vs. four), the threshold used for the clue cell criteria (unspecified vs. 20% or more clue cells), different Gram stain interpretation criteria (Spiegel vs. Nugent), whether participants were symptomatic or asymptomatic, and use of different units of analysis (person vs. visits). We note that the only study conducted exclusively among pregnant women (Gratacos et al) reported the lowest sensitivity among all studies (0.36 [95% CI, 0.20 to 0.57]); its specificity was 0.99 (95% CI, 0.98 to 1.0).^88^ The women in this study were all asymptomatic. None of the studies that enrolled both symptomatic and asymptomatic women reported findings stratified by symptom status. Further, among the four studies that enrolled exclusively symptomatic women, the sensitivity ranged from 0.72 to 0.92 and the specificity ranged from 0.77 to 0.94. Thus, we could not explain heterogeneity of findings based on symptom status of enrolled participants or any other characteristics that we evaluated.

Hillier et al did not report complete data, so we could not include it in our quantitative synthesis. The reported sensitivity and specificity in this study were 0.67 (95% CI, 0.57 to 0.76) and 1.0 (95% CI, 0.98 to 1.0), respectively.^101^ When limited to the subgroup of symptomatic women, the estimate of sensitivity was higher (0.82) and specificity was lower (0.94) in this study.^101^

### Modified Amsel’s Clinical Criteria

Five cross-sectional diagnostic test accuracy studies conducted among 2,674 participants reported on test accuracy characteristics of modified Amsel’s clinical criteria.^88,^ ^89,^ ^99,^ ^107,^ ^108^ Study authors modified Amsel’s clinical criteria by not including the criteria for the presence of vaginal discharge; all but one study^108^ required two of three criteria to be present for a positive test. Two studies (Gratacos et al^88^ and Mastrobattista et al^89^) exclusively enrolled asymptomatic pregnant women, and two studies (Singh et al^107^ and Schwebke et al^99^) exclusively enrolled symptomatic women. All but one study^88^ was conducted in the United States. Two studies enrolled participants from obstetric clinics;^88,^ ^89^ one study enrolled participants from a single STI clinic;^107^ one study enrolled participants from academic and community-based STI, HIV, family planning, and generally gynecology clinics;^65,^ ^99^ and one study enrolled participants from STI and hospital-based gynecology clinics.^108^ No studies reported the HIV status of enrolled participants and only one study reported race/ethnicity (Mastrobattista et al;^89^ 41% African American). All studies used a Gram stain of vaginal secretions interpreted according to the criteria of Nugent et al as the reference test. The prevalence of bacterial vaginosis based on the study’s reference test ranged from 4.5 to 63.5 percent across studies. We assessed the Gratacos et al^88^ study as good methodological quality and the rest as fair methodological quality.

Table 6 provides results from individual studies. Appendix F Figure 5 depicts the SROC curve comparing the modified Amsel’s clinical criteria with the reference test, and Appendix F Figure 6 displays the forest plot with individual study characteristics and sensitivity and specificity estimates. The pooled sensitivity based on four studies (2,477 participants) was 0.67 (95% CI, 0.54 to 0.78), and the pooled specificity was 0.96 (95% CI, 0.93 to 0.98). The pooled positive likelihood ratio was 17.3 (95% CI, 10.4 to 28.8), and the pooled negative likelihood ratio was 0.34 (95% CI, 0.24 to 0.48). The 95 percent prediction region covers about one fifth of the SROC space, but its shape suggests at least moderate heterogeneity. Potential sources of heterogeneity include how participants with intermediate flora were handled (included or excluded), the threshold used for the clue cell criteria (unspecified vs. 20% or more clue cells), the number of Amsel’s clinical criteria required for a positive test (two vs. three), and symptom status of participants. Sensitivity was the highest and specificity the lowest in the only study conducted exclusively among symptomatic participants (Schwebke et al^99^); the pregnancy status of participants in this study was not reported. Among the two studies conducted exclusively in asymptomatic pregnant women, the sensitivity was 0.56 in one study^89^ and 0.64 in the other.^88^ The specificities were similar (0.96 and 0.98, respectively).

Singh et al,^107^ which was conducted in symptomatic, nonpregnant women, did not report complete data, so we could not include it in our quantitative synthesis. We calculated a sensitivity of 0.54 and were unable to calculate the specificity for this study.

A number of included studies also reported test accuracy for the individual components that comprise Amsel’s clinical criteria (i.e., positive whiff test, pH >4.5, presence of clue cells, vaginal discharge) compared with a Gram stain reference test or compared with complete Amsel’s clinical criteria. These findings are available in Appendix D Tables 1–4.

## Benefits of Treatment (KQ 4)

Thirteen RCTs reported findings related to preterm delivery, other pregnancy outcomes, or clearance of bacterial vaginosis.^111–123^ Data from two of these studies are new to this update; one study was published in 2018^119^ and one study was previously included only for harms but has eligible data for benefits that we have now included.^120^ We excluded two studies previously included for this KQ because they did not meet the inclusion criterion for geographic setting of very high Human Development Index established for this update; one was conducted in South Africa^124^ and the other in Indonesia.^125^ In addition, we determined that one previously included study^126^ was a companion article to another previously included study;^113^ thus, we did not count the companion article as a separate study for this update. Seven trials were funded by nonprofit and government agencies,^111,^ ^114,^ ^116,^ ^117,^ ^120,^ ^121,^ ^123^ two were funded by hospitals,^118,^ ^122^ one was funded by a pharmaceutical manufacturer,^115^ one was funded by various government and commercial entities,^113^ and the funding source was not reported by two studies.^112,^ ^119^ Appendix E Tables 7–12 provide our assessment of individual study methodological quality. The rest of this section describes study characteristics and findings organized by outcome and population, including results for subgroups specified in the KQ when possible.

### Study Characteristics

Table 7 provides study characteristics with additional characteristics provided in Appendix D Table 5. Four studies were conducted in the United States;^111,^ ^118,^ ^121,^ ^122^ the others were conducted in Australia^117^ and Europe.^112–116,^ ^119,^ ^120,^ ^123^

Table 7 Study Characteristics of Randomized, Controlled Trials Reporting Benefits or Maternal Harms of Treating Bacterial Vaginosis on Pregnancy Outcomes (Key Questions 4 and 5)

Author; Year | Country | Study Quality | Interventions (N randomized) | N (%) with BV Symptoms | N (%) Nulliparous | N (%) Nonwhite | N (%) With Prior PTD | Outcomes Reported
Carey et al^111^; Andrews et al^127^; 2000 | U.S. | Good | G1: Placebo (987); G2: Oral metronidazole 1,000 mg dose four times on days 0, 2,14, and 16 (966) | 0 (0) | G1: 407 (41.2); G2: 436 (45.1) | G1: 841 (85.2); G2: 822 (85.1) | G1: 110 (11.1); G2: 103 (10.7) | - All-cause and spontaneous PTD <37, 35, and 32 weeks; - Birth weight <2,500 and 1,500 g; - Subgroup findings for women with prior PTD; treatment for chlamydia, and BV clearance; - Any maternal tolerability-related side effects; GI symptoms; candidiasis
Guaschino et al^112^; 2003 | Italy | Fair | G1: No treatment (57); G2: Intravaginal clindamycin 2% cream once daily for 7 days (55) | 0 (0) | G1: 35 (61.4); G2: 39 (70.9) | NR | G1: 3 (5.3); G2: 5 (9.1) | - All-cause PTD <37 weeks;; - Birthweight <2,500 g; - Preterm or term PROM
Hauth et al^121^; 1995 | U.S. | Fair | G1: Placebo (87)^*^; G2: Oral metronidazole (750 mg daily) for 7 days and erythromycin (999 mg daily) for 14 days (176) | NR | For parent study; G1: 30 (16); G2: 84 (19) | For parent study; G1: 150 (79); G2: 309 (71) | For subgroup with BV; G1: 56 (65.1); G2: 121 (70.3) | - All-cause PTD <37 weeks; - Subgroup findings among women with prior PTD
Kekki et al^113^; 2001; Kurkinen-Raty et al^126^; 2000 | Finland | Good | G1: Placebo (188); G2: Intravaginal clindamycin 2% cream once daily for 7 days (187) | 0 (0) | Mean parity; G1: 1.9; G2: 1.7 | NR | 0 (0) | - Spontaneous PTD <37 weeks; - Maternal peripartum infection; - Subgroup findings among participants with clearance of BV and participants with IF; - Maternal candidiasis
Kiss et al^114^; 2004 | Austria | Fair | G1: No treatment (179)^†^; G2: Intravaginal clindamycin 2% cream once daily for 6 days and treatment with oral clindamycin (300 mg twice a day) if still positive at 24 to 27 weeks gestation (177) | 0 (0) | G1: NR (47.8); G2: NR (47.9) | NR (2) | Between 33 and 36 weeks:; G1: 45 (2.1); G2: 47 (2.2); Between 23 and 32 weeks:; G1: 24 (1.1); G2: 22 (1.1) | - Spontaneous PTD <37 weeks; - Any maternal AEs
Lamont et al^115^; 2003 | U.K. | Good | G1: Placebo (201); G2: Intravaginal clindamycin 2% cream, once daily for 3 days (208) | 0 (0) | G1: 112 (56); G2: 111 (53) | G1: 63 (31); G2: 58 (28) | G1: 11 (8); G2: 10 (7) | - Spontaneous PTD <37 weeks; - Birth weight <2,500 and 1,500 g; - Stillborn fetus
Larsson et al^116^; 2006 | Sweden | Fair | G1: No treatment (411); G2: Intravaginal clindamycin 2% cream, once daily for 7 days (408) | 0 (0) | G1: 187 (45.5); G2: 186 (45.5) | NR | Among parous women; G1: 13/218 (6.0); G2: 20/217 (9.2) | - All-cause PTD <37 weeks; - Spontaneous PTD <37 and <32 completed weeks; - Any maternal severe AEs; - Treatment withdrawal
McDonald et al^117^; 1997 | Australia | Good | G1: Placebo (440); G2: Oral metronidazole 800 mg daily for 2 days repeated at 28 weeks for women with persistence (439) | 0 (0) | G1: 144 (32.7); G2: 139 (31.7) | G1: 53 (12.3); G2: 47 (10.8) | G1: 24 (5.5); G2: 22 (5.0) | - All-cause and spontaneous PTD <37 weeks; - Preterm PROM; - Subgroup findings for women with prior PTD; - Any maternal AEs or tolerability-related side effects; - Treatment withdrawal
McGregor et al^118^; 1994 | U.S. | Good | G1: Placebo (69 analyzed); G2: Intravaginal clindamycin 2% cream, once daily for 7 days (60 analyzed) | 0 (0) | Mean parity 1.0 (range 0 to 6) | 87 (61.2) | 15 (10.9) | - All-cause PTD <37 weeks; - Preterm PROM; - Preterm labor; - Birthweight <2,500 g
Morales et al^122^; 1994 | U.S. | Fair | G1: Placebo (36 analyzed); G2: Oral metronidazole 750 mg daily for 7 days (44 analyzed) | NR | Mean parity; G1: 2.2 (1.1); G2: 2.4 (1.2) | G1: 18 (50); G2: 20 (45) | 80 (100) | - Spontaneous PTD <37 and 34 weeks; - Preterm labor; - PROM; - Birthweight <2,500 g
Subtil et al^119^; 2018 | France | Good | G1: Placebo (956); G2: Oral clindamycin 600 mg daily for 4 days or 3 courses of 600 mg daily for 4 days, each 1 month apart (1904) | NR | NR | NR | NR | - All-cause and spontaneous PTD <37 weeks; - Spontaneous PTD <32 weeks; - Neonatal mortality; - Any maternal severe AEs; any tolerability-related side effects; GI symptoms; - Treatment withdrawal
Ugwumadu et al^120^; 2003 | U.K. | Good | G1: Placebo (245)^‡^; G2: Oral clindamycin 600 mg daily for 5 days (249) | NR | Mean parity; G1: 0.8 (1.0); G2: 0.8 (1.1) | G1: 93 (39); G2: 86 (36) | G1: 22 (9); G2: 24 (10) | - Spontaneous PTD <37 weeks; - Subgroup findings among participants with intermediate flora; - Any maternal AEs or tolerability-related side effects; GI symptoms; - Treatment withdrawal
Vermeulen et al^123^; 1999 | The Netherlands | Good | G1: Placebo (11)^§^; G2: Intravaginal clindamycin 2% cream once daily for 7 days at 26 weeks and again at 32 weeks (11) | NR | Mean parity; G1: 1.4 (0.9); G2: 1.6 (0.9) | NR | G1: 11 (100); G2: 11 (100) | - All-cause PTD <34 weeks; - Neonatal sepsis; - Maternal candidiasis; - Treatment withdrawal

* This study assessed the effect of treatment among a population of women with and without BV. This N represents the number of women with BV who are eligible for this review. The total N of the placebo group was 191, and the total N of the treatment group was 433. Some population characteristics reported here are for the full study population because characteristics were not reported separately for women with BV.

† This study randomized a total of 4,429 participants to vaginal smear screening, but only a subset of participants tested positive for BV and received treatment; we only abstracted data for the BV-positive subset of the study population.

‡ Represents the full randomized population; we only reported findings for the subgroup of women with BV, which was 203 participants for the placebo group and 207 participants for the treatment group.

§ This represents the number of women with BV who were allocated to placebo and treatment; the total number of women randomized in the study was 168 (placebo [N=85] and active treatment [N=83]).

Abbreviations: AE=adverse event; BV=bacterial vaginosis; G=group; GI=gastrointestinal; IF=intermediate flora; N=number of participants; NR=not reported; PROM=premature rupture of membranes; PTD=preterm delivery; SD=standard deviation; U.K.=United Kingdom; U.S.=United States.

Ten studies were conducted among general obstetric populations, meaning that participants were enrolled without regard to their risk for preterm delivery. The percentage of participants with a prior preterm delivery in these studies ranged from 0 to 10.9 percent.^111–120^ Two of these studies also reported findings among subgroups considered high risk for preterm delivery, which was defined as having a prior preterm delivery.^111,^ ^117^ Three studies were conducted solely among participants considered high risk for preterm delivery.^121–123^ All three defined high risk as a previous preterm delivery; however, one study also considered women with a prepregnancy weight of less than 50 kg and no previous preterm delivery as high risk.^121^ In this study, 68.6 percent of the analyzed population with bacterial vaginosis were high risk based on a prior preterm delivery, and the study reported outcomes for both the overall study population and the subgroup of women with prior preterm delivery.

Most studies identified asymptomatic patients during routine prenatal visits and enrolled participants during the second trimester, although criteria for enrollment varied. Eight RCTs screened potential participants and then enrolled those who met diagnostic criteria for bacterial vaginosis, although the diagnostic criteria varied by study.^111–113,^ ^116–119,^ ^122^ Five of these eight studies used Gram stain for diagnosis; four studies^111,^ ^116,^ ^118,^ ^119^ interpreted using Nugent’s criteria, and one study interpreted using Spiegel’s criteria.^113^ One of these eight studies used complete Amsel’s clinical criteria,^122^ and the remaining two studies used other methods (morphotype screening on vaginal smear,^112^ combination of culture for Gardnerella in conjunction with Gram stain^117^). The prevalence of bacterial vaginosis among the women tested for study entry ranged from 5.9 to 33.6 percent in these eight studies. Two studies enrolled women who met diagnostic criteria for bacterial vaginosis or intermediate flora based on Gram stain interpreted using Nugent’s criteria,^115,^ ^120^ and one of these reported findings from the subgroup of participants with bacterial vaginosis not including intermediate flora.^120^ Three studies enrolled participants without regard to bacterial vaginosis status but reported findings for the subgroup of participants testing positive for bacterial vaginosis at study entry (two based on Gram stain interpreted using Nugent’s criteria^114,^ ^123^ and one using both Amsel’s criteria and Gram stain). We report findings only from the subgroups with bacterial vaginosis for these studies.^114,^ ^121,^ ^123^

Three studies evaluated the use of oral metronidazole,^111,^ ^117,^ ^122^ two studies evaluated oral clindamycin,^119,^ ^120^ one study evaluated oral metronidazole and erythromycin,^121^ and seven evaluated intravaginal clindamycin.^112–116,^ ^118,^ ^123^ The dosages and duration of treatment varied across studies, and most, but not all, used a placebo control. Two studies repeated treatment if a test of cure demonstrated persistent bacterial vaginosis,^114,^ ^117^ and three studies repeated dosing at a later followup point in time without regard to results from a test of cure for some or all participants.^111,^ ^119,^ ^123^

Studies within this body of evidence reported a variety of outcomes. Some studies reported all-cause preterm delivery, defined as delivery prior to 37 weeks completed gestation regardless of whether delivery was induced for medical indications or a result of spontaneous preterm labor or PROM. Some studies reported only spontaneous preterm deliveries, and some studies reported both spontaneous and all-cause preterm deliveries. In one study, spontaneous abortions occurring at 16 weeks or later were included as part of this outcome.^116^ Other outcomes reported included preterm delivery prior to 35, 34, or 32 completed weeks gestation, maternal peripartum infections, low birth weight, very low birth weight, PROM, and neonatal infection or mortality.

We assessed nine RCTs^111–113,^ ^115,^ ^117–120,^ ^123^ as good methodological quality and four RCTs^114,^ ^116,^ ^121,^ ^122^ as fair methodological quality, primarily because of concerns related to lack of information on allocation concealment and lack of data to assess adequacy of randomization,^116^ lack of treatment blinding,^114,^ ^116^ post hoc subgroup analyses,^114,^ ^121^ or lack of intent to treat analyses.^122^

### Preterm Delivery

Twelve of the 13 RCTs^111–122^ reported findings related to preterm delivery prior to 37 weeks gestational age; one RCT^123^ only reported preterm delivery defined as delivery prior to 34 weeks. Results are provided in Table 8.

Table 8 Benefit Outcomes From Randomized, Controlled Trials of Treatment of Bacterial Vaginosis to Prevent Preterm Delivery (Key Question 4)

Author et al;; Publication Year;; Intervention (N Analyzed); Comparator (N Analyzed) | PTD <37 Weeks; N (%); Effect Estimates (95% CI) | Other PTD Outcomes; N (%); Effect Estimates (95% CI) | Other Pregnancy Outcomes; N (%); Effect Estimates (95% CI) | Subgroup Analyses
Carey et al^111^;; 2000;; Andrews et al^127^;; 2003;; G1: Placebo (966); G2: Oral metronidazole 1,000 mg dose four times (953) | All-cause PTD (primary outcome); G1: 121 (12.5); G2: 116 (12.2); Calculated ARD, −0.35% (−3.30% to 2.59%); RR, 1.0 (0.8 to 1.2); Calculated RR, 0.97 (0.77 to 1.23); Spontaneous PTD; G1: 91 (9.4); G2: 89 (9.3); Calculated ARD, −0.08% (−2.69% to 2.53%); Calculated RR, 0.99 (0.75 to 1.31) | All-cause PTD <35 weeks; G1: 49 (5.1); G2: 48 (5.0); Calculated ARD, −0.04% (−2.00% to 1.92%); RR, 1.0 (0.7 to 1.5); Calculated RR, 0.99 (0.67 to 1.46); All-cause PTD <32 weeks; G1: 26 (2.7); G2: 22 (2.3); Calculated ARD, −0.38% (−1.78% to 1.01%); RR, 0.9 (0.5 to 1.5); Calculated RR, 0.86 (0.49 to 1.50) | Birth weight <2,500 g; G1: 109/956 (11.4); G2: 103/943 (10.9); Calculated ARD, −0.48% (−3.31% to 2.35%); RR, 1.0 (0.7 to 1.2); Calculated RR, 0.96 (0.74 to 1.24); Birth weight <1,500 g; G1: 26/956 (2.7); G2: 19/943 (2.0); Calculated ARD, −0.70% (−2.07% to 0.66%); RR, 0.7 (0.4 to 1.3); Calculated RR, 0.74 (0.41 to 1.33) | Among women with prior PTD:; All-cause PTD <37 weeks; G1: 18/80 (22.5); G2: 24/80 (30.0); Calculated ARD, 7.50% (−6.09% to 21.09%); RR, 1.3 (0.8 to 2.0); Calculated RR, 1.33 (0.79 to 2.26); No significant difference in PTD <37 weeks or <35 weeks between treatment and placebo for chlamydia-positive vs. chlamydia-negative participants; Among 1,687 women in both groups who had a followup Gram stain and for whom information on delivery was available, preterm birth occurred in 77 of 718 women who had BV at followup (10.7%) and 103 of 969 women whose BV remitted (10.6%) (p=0.95), regardless of treatment
Guaschino et al^112^;; 2003;; G1: no treatment (51); G2: Intravaginal clindamycin 2% daily for 7 days (49) | All-cause PTD (primary outcome); G1: 8 (15.7); G2: 6 (12.2); p=0.78; Calculated ARD, −3.44% (−17.00% to 10.12%); Calculated RR, 0.78 (0.29 to 2.09) | NR | Birth weight <2,500 g; G1: 7 (13.7); G2: 3 (6.1); p=0.32; Calculated ARD, −7.60% (−19.19% to 3.98%); Calculated RR, 0.45 (0.12 to 1.63); PROM (preterm or term per study author confirmation); G1: 3 (5.9); G2: 7 (14.3); p=0.19; Calculated ARD, 8.40% (−3.33% to 20.14%); Calculated RR, 2.43 (0.67 to 8.86) | NR
Hauth et al^121^;; 1995;; G1: Placebo (190); G2: Oral metronidazole for 7 days with oral erythromycin for 14 days (426)^*^ | All-cause PTD (primary outcome; women with prior history of PTD or prepregnancy weight <50 kg with or without bacterial vaginosis); G1: 68 (36); G2: 110 (26); RR, 1.4 (1.1 to 1.8) for G1 vs. G2 | NR | NR | All-cause PTD <37 weeks among women with bacterial vaginosis and prior PTD:; G1: 32/56 (57); G2: 47/121 (39); p=0.02; Calculated ARD, −18.30% (−33.90% to −2.70%); RR, 1.5 (1.1 to 2.0) reported for G1 vs. G2; Calculated RR, 0.68 (0.49 to 0.93) for G2 vs. G1; All-cause PTD <37 weeks among women with BV and prior PTD or prepregnancy weight <50 kg:; G1: 42 (48.8); G2: 54 (31.4); Calculated ARD, −18.30% (−33.90% to −2.70%); RR, 1.6 (1.1 to 2.1) reported for G1 vs. G2; Calculated RR, 0.68 (0.49 to 0.93) for G2 vs. G1
Kekki et al^113^;; 2001;; Kurkinen-Raty et al^126^;; 2000; G1: Placebo (188); G2: Intravaginal clindamycin 2% cream once daily for 7 days (187) | All-cause PTD; NR; Spontaneous PTD (study powered based on this outcome); G1: 7 (3.7); G2: 9 (4.8); OR, 1.3 (0.5 to 3.5); Calculated ARD, 1.09% (−3.00% to 5.18%); Calculated RR, 1.29 (0.49 to 3.40) | NR | Maternal peripartum infection (postpartum endometritis, postpartum sepsis, cesarean wound infection, episiotomy wound infection); G1: 33 (17.6); G2: 21 (11.2); OR, 1.6 (0.9 to 2.8) (study reported, comparing G1 with G2); Calculated ARD, −6.32% (−13.4% to 0.75%); Calculated RR, 0.64 (0.38 to 1.06) | PTD in patients with complete followup who demonstrated clearance of BV 1-week posttreatment:; G1: 0/42 (0%); G2: 2/79 (2.5%); Calculated ARD, 2.30% (−1.45% to 6.06%); Calculated RR, 10.66 (0.02 to 6,039); PTD in participants with intermediate Gram stain findings:; G1: 4/18 (22%); G2: 5/17 (29%); OR, 1.2 (95% CI, 0.5 to 2.9); Calculated ARD, 7.19% (−21.76% to 36.14%); Calculated RR, 1.32 (0.43 to 4.12)
Kiss et al^114^;; 2004;; G1: No treatment (176)^†^; G2: Intravaginal clindamycin 2% cream once daily for 6 days with test of cure and further treatment if positive (175) | Spontaneous PTD (primary outcome); G1: 10 (5.7); G2: 6 (3.4); Calculated ARD, −2.25% (−6.61% to 2.10%); Calculated RR, 0.60 (0.22 to 1.62)
Lamont et al^115^;; 2003;; Lamont et al^138^;; 2012;; G1: Placebo (193); G2: Intravaginal clindamycin 2% cream, once daily for 3 days (198) | Spontaneous PTD (primary outcome); G1: 19 (9.8); G2: 8 (4.0); OR, 0.38 (0.16 to 0.90 adjusted for gestational age at treatment; Calculated ARD, −5.80% (−10.82% to −0.79%); Calculated RR, 0.41 (0.18 to 0.92) | NR | Birth weight <2,500 g; G1:15/193 (7.8); G2: 18/204 (8.8); Calculated ARD, 1.05% (−4.37% to 6.48%); Calculated RR, 1.14 (0.59 to 2.19); Birth weight <1,500 g; G1: 4/193 (2.1); G2: 3/204 (1.5); Calculated ARD, −0.60% (−3.20% to 2.00%); Calculated RR, 0.71 (0.16 to 3.13); Stillborn fetus; G1: 3/140 (2.1); G2: 1/142 (0.7); Calculated ARD, −1.44% (−4.20% to 1.33%); Calculated RR, 0.33 (0.03 to 3.12) | NR
Larsson et al^116^;; 2006;; G1: no treatment (411); G2: Intravaginal clindamycin 2% cream, once daily for 7 days (408) | All-cause PTD (primary outcome); G1: 25 (6.1); G2: 21 (5.2); OR, 0.84 (0.48 to 1.47); Calculated ARD, −0.94% (−4.09% to 2.22%); Calculated RR, 0.85 (0.48 to 1.49); Spontaneous PTD (between 16 and 37 weeks); G1: 12/390 (3.1); G2: 11/395 (2.8); OR, 0.90 (0.40 to 2.02); Calculated ARD, −0.29% (−2.65% to 2.07%); Calculated RR, 0.91 (0.40 to 2.03) | Spontaneous PTD (between 16 and <32 completed weeks); G1: 5/390 (1.3); G2: 1/395 (0.25); Calculated ARD, −1.03% (−2.25% to 0.19%); Calculated RR, 0.20 (0.02 to 1.68) | NR | NR
McDonald et al^117^;; 1997;; G1: Placebo (428); G2: Oral metronidazole 800 mg daily for 2 days and repeated at 28 weeks gestation for positive test of cure (429) | All-cause PTD; G1: 32 (7.5); G2: 31 (7.2); Calculated ARD, −0.95% (−5.54% to 3.64%); Calculated RR, 0.87 (0.46 to 1.67); Spontaneous PTD (primary outcome); G1: 24 (5.6); G2: 20 (4.7); OR, 0.82 (0.43 to 1.57); Calculated ARD, −1.76% (−5.81% to 2.29%); Calculated RR, 0.72 (0.34 to 1.54) | NR | PPROM; G1: 14 (3.3); G2: 12 (2.8); OR, 0.85 (0.36 to 1.98); Calculated ARD, −1.72% (−4.94% to 1.49%); Calculated RR, 0.59 (0.22 to 1.60) | All-cause PTD <37 weeks among subgroup of women who were smear positive (i.e., not including women with heavy growth of G. vaginalis); G1: 18/238 (7.6); G2: 16/242 (6.6); OR, 0.87 (0.41 to 1.83); Calculated ARD, −0.95% (−5.54% to 3.64%); Calculated RR, 0.87 (0.46 to 1.67); Spontaneous PTD <37 weeks among subgroup of women who were smear positive (i.e., not including women with heavy growth of G. vaginalis); G1: 15/238 (6.3); G2: 11/242 (4.5); OR, 0.71 (95% CI, 0.30 to 1.68); Calculated ARD, −1.76% (−5.81% to 2.30%); Calculated RR, 0.72 (0.34 to 1.54); Spontaneous PTD <37 weeks among subgroup of women with prior PTD; G1: 10/24 (41.7); G2: 2/22 (9.1); OR, 0.14 (0.01 to 0.84); Calculated ARD, −29.41% (−54.73% to −4.09%); Calculated RR, 0.17 (0.02 to 1.24)
McGregor et al^118^;; 1994;; G1: Placebo (69); G2: Intravaginal clindamycin 2% cream, once daily for 7 days (60) | All-cause PTD; G1: 5 (7.3); G2: 9 (15.0); Calculated ARD, 7.75% (−3.16% to 18.66%); Calculated RR, 2.07 (0.73 to 5.84) | NR | PPROM; G1: 3/68 (4.4); G2: 3 /60 (5.0); Calculated ARD, 0.59% (−6.78% to 7.95%); Calculated RR, 1.13 (0.24 to 5.41); Preterm labor; G1: 10 (14.5); G2: 13 (21.7); Calculated ARD, 7.17% (−6.15% to 20.50%); Calculated RR, 1.50 (0.71 to 3.16); Birth weight <2,500 g; G1: 3 (4.4); G2: 8 (13.6); Calculated ARD, 9.21% (−0.76% to 19.18%); Calculated RR, 3.12 (0.87 to 11.22) | NR
Morales et al^122^;; 1994;; G1: Placebo (36); G2: Oral metronidazole 750 daily (44) | Spontaneous PTD (primary outcome); G1: 16 (44.4); G2: 8 (18.2); p<0.05; Calculated ARD, −26.26% (−46.10% to −6.43%); Calculated RR, 0.41 (0.20 to 0.85) | Spontaneous PTD <34 weeks; G1: 4 (11.1); G2: 2 (4.6); P NS; Calculated ARD, −6.57% (−18.53% to 5.40%); Calculated RR, 0.41 (0.08 to 2.11) | Preterm labor; G1: 28 (77.8); G2: 12 (27.3); p<0.05; Calculated ARD, −50.51% (−69.41% to −31.60%); Calculated RR, 0.35 (0.21 to 0.59); Birth weight <2,500 g; G1: 12 (33.3); G2: 6 (13.6); p<0.05; Calculated ARD, −19.7% (−38.13% to −1.26%); Calculated RR, 0.41 (0.17 to 0.98); PROM; G1: 12 (33.3); G2: 2 (4.6); p<0.05; Calculated ARD, −28.79% (−45.37% to −12.21%); Calculated RR, 0.14 (0.03 to 0.57)
Subtil et al^119^;; 2014;; G1: Placebo (956); G2: Oral clindamycin 600 mg daily for 4 days; G3: Oral clindamycin 600 mg daily for 4 days repeated twice at 1-month intervals (G2/G3 combined 1,904) | All-cause PTD; G1: 56 (5.9); G2/G3: 128 (6.7); RR, 1.15 (0.85 to 1.56; p=0.37); Calculated ARD, 0.86% (−1.00% to 2.73%); Spontaneous PTD; G1: 39 (4.1); G2/G3: 91 (4.8); RR, 1.17 (0.81 to 1.69; p=0.40); Calculated ARD, 0.70% (−0.88% to 2.28%) | Late miscarriage (>16 weeks) or spontaneous PTD <32 completed weeks (primary outcome):; G1: 10 (1.0); G2/G3: 22 (1.2); RR, 1.10 (0.53 to 2.32, p=0.82); Calculated ARD, 0.11% (−0.69% to 0.91%) | PPROM; G1: 18 (1.9); G2/G3: 42 (2.2); RR, 1.18 (0.65 to 2.13; p=0.57); Calculated ARD, 0.32% (−0.76% to 1.41%); Neonatal mortality; G1: 2/955 (0.21); G2: 3/1898 (0.16); Calculated ARD, −0.05% (−0.39% to 0.29%); Calculated RR, 0.75 (0.13 to 4.51); Neonatal sepsis; G1: 31/955 (3.2); G2/G3: 48/1898 (2.5); RR; 0.77 (0.49 to 1.22; p=0.27); Calculated ARD, −0.72% (−2.05% to 0.61%); Birth weight <2,500 g; G1: 75/955 (7.9); G2/G3: 160/1898 (8.4); Calculated ARD, 0.58% (−1.54% to 2.69%); Calculated RR, 1.07 (0.83 to 1.40); Birth weight <1,500 g; G1: 6/955 (0.63); G2/G3: 25/1898 (1.3); Calculated ARD, 0.69% (−0.03% to 1.41%); Calculated RR, 2.10 (0.86 to 5.09); Maternal need for antibiotic within 24 hours of delivery; G1: 113 (11.8); G2/G3: 220 (11.6); RR, 0.98 (0.79 to 1.21; p=0.83); Calculated ARD, −0.27% (−2.77% to 2.23%); Fetal death (>22 weeks); G1: 6/955 (0.63); G2/G3: 9/1898 (0.47); RR, 0.75 (0.27 to 2.11; p=0.59); Calculated ARD, −0.15% (−0.74% to 0.43%) | NR
Ugwumadu et al^120^;; 2003;; G1: Placebo (203); G2: Oral clindamycin 600 mg daily (in two divided doses) for 5 days (207) | Spontaneous PTD (between 24 and 37 weeks) ^ǂ^; G1: 31 (15.3); G2: 11 (5.3); Calculated ARD, −9.96% (−15.77% to −4.14%); Calculated RR, 0.35 (0.18 to 0.67); Spontaneous PTD (delivery between 24 and up to 37 weeks) or late miscarriage (between 13 and up to 24 weeks) (primary outcome); G1: 38/241 (15.7); G2: 13/244 (5.3); ARD 10.4% (95% CI, 5.0 to 15.8) | NR | NR | Spontaneous PTD for women with intermediate flora or BV; G1: 28 (11.6%); G2: 11 (4.5%); Calculated ARD, −7.11% (−11.92% to −2.30%); Calculated RR, 0.39 (0.20 to 0.76); Spontaneous PTD for women with intermediate flora; G1: 7/38 (18.4); G2: 2/37 (5.4); Calculated ARD, −13.02% (−27.33% to 1.30%); Calculated RR, 0.29 (0.07 to 1.32)
Vermeulen et al^123^;; 1999;; G1: Placebo (11)^§^; G2: Intravaginal clindamycin 2% cream once daily for 7 days at 26 weeks and again at 32 weeks (11) | NR for women with bacterial vaginosis but was the primary outcome for the overall study | NR | Neonatal sepsis; G1: 0 (0); G2: (0) | All-cause PTD <34 weeks among women with bacterial vaginosis; G1: 1 (9.1); G2: 1 (9.1); ARD 0% (95% CI, −24.03% to 24.03%)

* This study assessed the effect of treatment among a population of women with and without BV. This N represents the number of women with BV who are eligible for this review. The total N of placebo group was 191, and the total N of the treatment group was 433.

† This study randomized a total of 4,429 participants to vaginal smear screening, but only a subset of participants tested positive for BV and received treatment; we only abstracted data for the BV-positive subset of the study population.

ǂ Although the study included women with either intermediate flora or BV, the outcome reported here is for the subgroup with BV (Nugent score ≥7).

§ This represents the number of women with BV who were allocated to placebo and treatment; the total number of women randomized in the study was 168 (placebo [N=85] and active treatment [N=83]).

Abbreviations: ARD=absolute risk difference; BV=bacterial vaginosis; CI=confidence interval; G=group; G. vaginalis=Gardnerella vaginalis; KQ=key question; N=number of participants; NR=not reported; OR=odds ratio; PROM=premature rupture of membranes; PPROM=preterm premature rupture of membranes; PTD=preterm delivery; RR=relative risk.

#### Preterm Delivery in General Obstetric Populations

Ten RCTs conducted among general obstetric populations (i.e., participants enrolled without regard to risk for preterm delivery) reported preterm delivery outcomes, and most either designated preterm delivery as the primary outcome or were powered based on this outcome. The absolute risk of delivery prior to 37 weeks gestational age in the control groups ranged from 3.1 to 15.7 percent. Some studies reported all-cause preterm delivery and others reported spontaneous preterm delivery; initial forest plots clearly depicted differences in point estimates based on the outcome used (Appendix G Figures 1 and 2), and the statistical tests for heterogeneity were significant. Thus, we stratified the analysis by outcome (Figures 3 and 4). Among the six studies reporting all-cause preterm delivery, the pooled ARD comparing active treatment with control was 0.20 percent (95% CI, −1.13% to 1.53%; 6,307 participants; I^2^=0%), and the pooled RR was 1.02 (95% CI, 0.86 to 1.20).^111,^ ^112,^ ^116–119^ No individual studies reported a significant difference between active treatment and control. Among the eight studies reporting spontaneous preterm deliveries, the pooled ARD comparing active treatment with control was −1.44 percent (95% CI, −3.31% to 0.43%; 7,571 participants; I^2^=61.9%), and the pooled RR was 0.78 (95% CI, 0.56 to 1.07).^111,^ ^113–117,^ ^119,^ ^120^ Two of the eight studies reported statistically significant reductions in spontaneous preterm delivery for active treatment compared with control,^115,^ ^120^ while the other six reported no significant differences between active treatment and control. One of the studies that reported a significant association enrolled participants with either bacterial vaginosis or intermediate flora; other than this difference, we could not identify other study, population, or intervention (e.g., medication) characteristics that might explain this inconsistency.

Figure 3 Absolute Risk Difference on Delivery at Less than 37 Weeks Gestation from Treatment of Bacterial Vaginosis Among a General Obstetric Population

Figure Note: Mixed-methods test of moderators for all-cause vs. spontaneous preterm delivery: QM(df=1)=3.7044, p=0.0543.

* Includes spontaneous late abortion (≥16 weeks).

Abbreviations: CI=confidence interval; OC=oral clindamycin; OM=oral metronidazole; N=number of participants; PTD=preterm delivery; RE=random effects; VC=intravaginal clindamycin.

Figure 3 is titled “Absolute Risk Difference for Delivery at Less than 37 Weeks Gestation From Treatment of Bacterial Vaginosis Among a General Obstetric Population.” This figure displays a forest plot reporting the absolute risk difference of all-cause preterm delivery for six studies and spontaneous preterm delivery for eight studies. Among the six studies assessing all-cause preterm delivery, two (Carey, 2000; McDonald, 1997) compared oral metronidazole with control, three (Guaschino, 2003; Larsson, 2006; McGregor, 1994) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. The pooled absolute risk difference comparing active treatment with control was 0.20 percent (95% CI, −1.13% to 1.53%; 6,307 participants, I2=0%). No individual studies reported a significant difference between active treatment and control. Among the eight studies assessing spontaneous preterm delivery, two (Carey, 2000; McDonald, 1997) compared oral metronidazole with control, four (Kekki, 2001; Kiss, 2004; Lamont, 2003; Larsson, 2006) compared intravaginal clindamycin with control, and two (Subtil, 2018; Ugwumadu, 2003) compared oral clindamycin with control. The pooled absolute risk difference comparing active treatment with control was 1.44 percent (95% CI, −3.31% to 0.43%; 7,571 participants, I2=61.9%). Two of the eight studies reported statistically significant reductions in spontaneous preterm delivery for active treatment compared with control (Lamont, 2003; Ugwumadu, 2003), while the other six reported no significant differences between active treatment and control.

Figure 4 Risk Ratio for Delivery at Less than 37 Weeks Gestation from Treatment of Bacterial Vaginosis Among a General Obstetric Population

Figure Notes: Mixed-methods test of moderators for all-cause vs. spontaneous preterm delivery: p=0.0020.

* Includes spontaneous late abortion (≥16 weeks).

Abbreviations: CI=confidence interval; OC=oral clindamycin; N=number of participants; OM=oral metronidazole; PTD=preterm delivery; RE=random effects; VC=intravaginal clindamycin.

Figure 4 is titled “Risk Ratio for Delivery at Less than 37 Weeks Gestation From Treatment of Bacterial Vaginosis Among a General Obstetric Population.” This figure displays a forest plot reporting the risk ratio for all-cause preterm delivery in six studies and spontaneous preterm delivery in eight studies. Among the six studies assessing all-cause preterm delivery, two (Carey, 2000; McDonald, 1997) compared oral metronidazole with control, three (Guaschino, 2003; Larsson, 2006; McGregor, 1994) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. The pooled risk ratio comparing active treatment with control was 1.02 (95% CI, 0.86 to 1.20; 6,307 participants, I2=0%). No individual studies reported a significant difference between active treatment and control. Among the eight studies assessing spontaneous preterm delivery, two (Carey, 2000; McDonald, 1997) compared oral metronidazole with control, four (Kekki, 2001; Kiss, 2004; Lamont, 2003; Larsson, 2006) compared intravaginal clindamycin with control, and two (Subtil, 2018 and Ugwumadu, 2003) compared oral clindamycin with control. The pooled risk ratio comparing active treatment with control was 0.78 (95% CI, 0.56 to 1.07; 7,571 participants, I2=55.0%). Two of the eight studies reported statistically significant reductions in spontaneous preterm delivery for active treatment compared with control (Lamont, 2003 and Ugwumadu, 2003), while the other six reported no significant differences between active treatment and control.

Three RCTs reported the incidence of preterm delivery prior to 32 weeks completed gestation among a general obstetric population (Appendix G Figures 3 and 4).^111,^ ^116,^ ^119^ The pooled ARD was −0.30 percent (95% CI, −0.97% to 0.38%; 5,564 participants; I^2^=15.4%), and the pooled RR was 0.87 (95% CI, 0.54 to 1.42). Two of these studies reported spontaneous preterm delivery,^116,^ ^119^ and one reported all-cause preterm delivery.^111^ All three studies observed no significant differences between active treatment and control. One RCT also reported no difference in preterm delivery at less than 34 weeks gestation (ARD, −0.04% [95% CI, −2.0% to 1.92%]; RR, 1.0 [95% CI, 0.7 to 1.5]).^111^

#### Preterm Delivery in Women With Prior Preterm Delivery

Consistent with the previous report, we did not pool findings for this subgroup because of the observed heterogeneity in findings. Five RCTs reported this outcome; four reported the incidence of preterm delivery at less than 37 weeks,^111,^ ^117,^ ^121,^ ^122^ and one reported the incidence of preterm delivery at less than 34 weeks.^123^

In the four RCTs conducted among participants with a previous preterm delivery or that reported subgroup findings for such women, the incidence of preterm delivery at less than 37 weeks gestation in control groups ranged from 22.5 to 57.1 percent (Figures 5 and 6).^111,^ ^117,^ ^121,^ ^122^ Carey et al^111^ and Hauth et al^121^ reported all-cause preterm delivery, and Morales et al^122^ and McDonald et al^117^ reported spontaneous preterm delivery. Three of the four RCTs reported a statistically significant favorable treatment effect (ARDs ranging from −18.3% to −29.4%), while Carey et al^111^ observed no significant treatment effect (ARD, 7.50% [95% CI, −6.09% to 21.09%]).

Figure 5 Absolute Risk Difference for Preterm Delivery Outcomes from Treatment of Bacterial Vaginosis Among Participants With a Prior Preterm Delivery

Figure Note: Mixed-methods test of moderators for all-cause vs. spontaneous preterm delivery at less than 37 weeks gestation: p=0.1362. For Hauth et al,^121^ we used data from the subgroup of participants with bacterial vaginosis and history of prior PTD. For Carey et al,^111^, we used data from the subgroup of participants with a history of prior PTD. For McDonald et al,^117^ we used data from the subgroup of participants with bacterial vaginosis and history of prior PTD. For Vermeulen et al,^123^ we used data from the subgroup of participants with bacterial vaginosis.

Abbreviations: CI=confidence interval; N=number of participants; OM=oral metronidazole; PTD=preterm delivery; VC=intravaginal clindamycin.

Figure 5 is titled “Absolute Risk Difference for Preterm Delivery Outcomes From Treatment of Bacterial Vaginosis Among Participants With a Prior Preterm Delivery.” This figure displays a forest plot reporting the absolute risk difference in preterm delivery less than 37 weeks among women with a prior preterm delivery in four studies and preterm delivery at less than 34 weeks in two studies among women with a prior preterm delivery. Among the four studies assessing preterm delivery at less than 37 weeks, two (Carey, 2000; Hauth, 1995) reported all-cause preterm delivery, and two (Morales, 1994; McDonald, 1997) reported spontaneous preterm delivery. All four studies compared oral metronidazole with control. Three of the studies reported statistically significant treatment effects favoring treatment. Hauth et al. reported an absolute risk difference that was 18.30 percent lower in the treatment group compared with control; the 95 percent confidence interval ranged from −33.90 to −2.70. Morales et al. reported an absolute risk difference that was −26.26 percent lower in the treatment group compared with control; the 95 percent confidence interval ranged from −46.10 to −6.43. McDonald reported an absolute risk difference that was 29.41 percent lower in the treatment group compared with control; the 95 percent confidence interval ranged from −54.73 to −4.09. The absolute risk difference in the Carey et al study was 7.50 percent higher in the treatment group compared with control; however, the results were not statistically significant as the confidence interval ranged from −6.09 to 21.09. Among the two studies reporting preterm delivery prior to 34 weeks, Vermeulen et al. reported a 0 percent difference in all-cause preterm delivery (95% confidence interval −24.03 to 24.03) comparing intravaginal clindamycin with control, and Morales et al. reported a 6.57 percent decrease in the risk for spontaneous preterm delivery with a 95 percent confidence interval from −18.54 to 5.40 comparing oral metronidazole with control.

Figure 6 Risk Ratio for Preterm Delivery Outcomes from Treatment of Bacterial Vaginosis Among Participants With a Prior Preterm Delivery

Figure Note: Mixed-methods test of moderators for all-cause vs. spontaneous preterm delivery at less than 37 weeks gestation: p=0.0892.

Abbreviations: CI=confidence interval; N=number of participants; OM=oral metronidazole; PTD=preterm delivery; VC = intravaginal clindamycin.

Figure 6 is titled “Risk Ratio for Preterm Delivery Outcomes From Treatment of Bacterial Vaginosis Among Participants With a Prior Preterm Delivery.” This figure displays a forest plot reporting the risk ratio for preterm delivery at less than 37 weeks among women with a prior preterm delivery in four studies and for preterm delivery less than 34 weeks among women with a prior preterm delivery in two studies. Among the four studies assessing preterm delivery at less than 37 weeks, two (Carey, 2000; Hauth, 1995) reported all-cause preterm delivery, and two (Morales, 1994; McDonald, 1997) reported spontaneous preterm delivery. All four studies compared oral metronidazole with control. Two of the studies reported statistically significant treatment effects favoring treatment. Hauth et al. reported a relative risk ratio of 0.68 (95% confidence interval, 0.49 to 0.93). Morales et al. reported a relative risk ratio of 0.41 (95% confidence interval 0.20 to 0.85). The relative risk ratio was not significant in the other two studies. McDonald reported a relative risk ratio of 0.17 (95% confidence interval, 0.02 to 1.24). Carey et al. reported a relative risk ratio of 1.33 (95% confidence interval of 0.79 to 2.26). Among the two studies reporting preterm delivery at less than 34 weeks, Vermeulen et al. reported a relative risk ratio of 1.00 (95% confidence interval, 0.07 to 14.05) comparing intravaginal clindamycin with control, and Morales et al. reported a relative risk ratio of 0.41 (95% confidence interval, 0.08 to 2.11) comparing oral metronidazole with control.

We were not able to definitively explain the inconsistency in findings based on study or population characteristics. All studies used oral metronidazole; two used similar doses of 750 mg or 800 mg daily for 7 days. However, Hauth et al also included erythromycin for 14 days as part of its treatment regimen.^121^ McDonald et al used 800 mg daily for 2 days and repeated dosing at 28 weeks gestation if a test of cure remained positive.^117^ Carey et al used 1,000-mg doses repeated four times (day of randomization and 48 hours later, and two doses administered 48 hours apart between 24 and 30 weeks gestation and at least 14 days after the very first dose).^111^ All studies enrolled participants during the second trimester. Carey et al^111^ enrolled participants based on a Gram stain interpreted according to the criteria of Nugent et al, while the other studies used other criteria (Amsel’s clinical criteria alone,^122^ Amsel’s clinical criteria plus mixed flora using Spiegel’s criteria on Gram stain,^121^ or heavy growth of G. vaginalis or Gram stain with G. vaginalis and absence of lactobacilli^117^). Carey et al^111^ enrolled the highest percentage of nonwhite participants (approximately 85%), but this percentage was reasonably similar to the percentage enrolled by Hauth et al^121^ and Morales et al.^122^ We could also not explain the inconsistency in findings based on study methodological quality, and all studies were conducted over the same decade (1989 to 1998). The incidence of preterm delivery in the control group was 22.5 percent in Carey et al,^111^ which was lower than in the other three studies (35.3%, 44.4%, and 57.1%), suggesting some heterogeneity in the underlying study populations.

Two RCTs reported the incidence of preterm delivery at less than 34 weeks gestation among participants with a prior preterm delivery (Figures 5 and 6).^122,^ ^123^ In Morales et al, four (11.1%) and two (4.6%) participants in the placebo and oral metronidazole group, respectively, had a spontaneous preterm delivery at less than 34 weeks (calculated ARD, −6.57% [95% CI, −18.5% to 5.40%]).^122^ Vermeulen et al reported the incidence of all-cause preterm delivery at less than 34 weeks gestation among a subgroup of 22 participants with bacterial vaginosis and observed one event in both the vaginal clindamycin and placebo groups.^123^

#### Preterm Delivery Based on Bacterial Vaginosis Clearance Status

Some studies reported preterm delivery outcomes for subgroups of participants who had documented clearance or persistence of bacterial vaginosis following treatment. Among a subgroup of participants who had a followup Gram stain after initial testing and treatment, Carey et al reported no difference in preterm delivery among women with clearance of bacterial vaginosis (incidence, 10.6%) vs. those with persistence of bacterial vaginosis (incidence, 10.7%).^111^ Kekki et al also reported no difference in preterm delivery between active treatment and control among a subgroup of women with documented clearance of bacterial vaginosis 1 week posttreatment (calculated ARD, 2.30% [95% CI, −1.45% to 6.06%]).^113^

#### Other Subgroups

Andrews et al (a companion article to the Carey et al RCT) reported no difference in preterm delivery at less than 35 or 37 weeks among women who received treatment for a positive chlamydia test at study entry compared with women who tested negative for chlamydia.^111,^ ^127^ No studies reported subgroup findings by maternal or gestational age, race/ethnicity, HIV status, or other population characteristics specified by our KQs.

### Other Pregnancy Related Outcomes

Appendix G Figures 3 and 4 depict other pregnancy-related outcomes for which we were able to calculate pooled summary estimates for the general obstetric population. The pooled ARD for the effect of active treatment compared with control on birth weight less than 2,500 g was 0.39 percent (95% CI, −1.74% to 2.53%; 5 studies; 5,377 participants; I^2^=24.2%) and was 0.06 percent (95% CI, −0.99% to 1.12%; 3 RCTs; 5,149 participants; I^2^=45.3%) for birth weight less than 1,500 g. The pooled ARD for PROM was 0.10 percent (95% CI, −1.32% to 1.52%; 4 RCTs; 3,568 participants; I^2^=9.4%) comparing treatment with control.

Within the body of evidence for the general obstetric population, studies reported outcomes for which we could not generate pooled summary estimates and for which authors observed no significant difference between active treatment and control. These outcomes include maternal peripartum infection,^113^ stillborn fetus,^114^ preterm labor,^118^ and neonatal mortality.^119^

Within the body of evidence for participants with a previous preterm delivery, Morales et al reported a significant treatment effect on preterm labor (calculated ARD, −50.51% [95% CI, −69.41% to −31.60%]), PROM (calculated ARD, −28.79% [95% CI, −45.37% to −12.21%]), and birth weight less than 2,500 g (calculated ARD, −19.7% [95% CI, −38.13% to −1.26%]).^122^ Vermeulen et al reported no significant treatment effect on neonatal sepsis.^123^

### Clearance of Bacterial Vaginosis

Six RCTs that reported preterm delivery outcomes also reported outcomes related to the clearance of bacterial vaginosis; however, differences in outcome measurement and timing precluded a quantitative synthesis (Appendix D Table 6). Some studies conducted followup testing on all participants; in other studies, followup testing was optional. Across this body of evidence, active treatment was more effective in producing short-term clearance of bacterial vaginosis than control treatment; findings were mixed for longer-term clearance and persistence of clearance throughout pregnancy.

In the largest RCT (Carey et al), 657 (77.8%) participants had clearance of vaginosis at the first followup visit after the first course of treatment with oral metronidazole compared with 321 (37.4%) of participants who received placebo.^111^ By design, the study protocol included initial dosing on day 0 and day 2, followed by a repeat dose between 24 and 30 weeks gestation and at least 14 days after the very first dose. Thus, the outcome reported provides the incidence of clearance after receiving only the initial portion of the protocol dose.

In Guaschino et al, authors reported clearance in 25 (75.8%) participants treated with intravaginal clindamycin daily for 7 days compared with 26 (70.3%) in the no treatment group.^112^ These findings were reported among participants who had an optional vaginal smear at 28 to 30 weeks gestation.

In Morales et al, an RCT conducted among women with a prior preterm delivery, the authors reported on clearance at the time of delivery. Significantly more participants who received oral metronidazole had clearance (88.6%) compared with participants who received placebo (13.9%); we calculated the ARD as 74.8 percent (95% CI, 60.1% to 89.4%).^122^

Several RCTs reported both short-term and long-term clearance incidence. Kekki et al reported significantly higher short-term (within 1 week) and long-term (at 30 to 36 weeks gestation) clearance among participants who received intravaginal clindamycin daily for 7 days compared with placebo.^113^ Lamont et al compared multiple clearance outcomes between participants receiving intravaginal clindamycin daily for 3 days and those receiving placebo, including short-term clearance (within 20 to 24 days posttreatment), sustained clearance (at 40 to 48 days posttreatment), and clearance after failing initial treatment.^115^ Significantly more participants who received intravaginal clindamycin had clearance or improvement, defined as a Nugent Gram stain score of 4 or less, at 20 to 24 days compared with placebo; we calculated the ARD as 58.7 percent (95% CI, 50.5% to 67.0%). Sustained clearance or improvement at 40 to 48 days and 30 to 36 weeks did not differ significantly between groups. For those who failed initial treatment and were retreated with a 7-day course of intravaginal clindamycin or placebo, significantly more participants who received intravaginal clindamycin had clearance or improvement at 40 to 48 days (calculated ARD, 17.1% [95% CI, 2.32% to 31.9%]) and 30 to 36 weeks (calculated ARD, 24.8% [95% CI, 7.75% to 41.8%]) compared with placebo.^115^ McGregor et al reported a higher incidence of clearance at multiple timepoints after treatment with intravaginal clindamycin compared with placebo, although significance testing was not performed and the actual numeric values were not provided (values were depicted on a figure at 1, 4, and 8 weeks posttreatment and at greater than 36 weeks gestation).^118^

## Harms of Treatment (KQ 5)

We included a total of 14 studies reporting on the harms of treatment. We excluded four previously included studies because they reported on comparative harms of alternative active treatments,^128^ reported on harms in women without bacterial vaginosis,^121,^ ^127^ or reported a single adverse event (AE) but did not attribute it to a specific group.^112^ We first present the studies that report maternal adverse effects and then those that present adverse outcomes in children exposed to medication in utero. Eight RCTs reported on maternal adverse effects;^111,^ ^113,^ ^114,^ ^116,^ ^117,^ ^119,^ ^120,^ ^123^ four of these studies are new to this update. One was published in 2018^119^ and three were previously included only for benefits but have eligible data for harms that we have now included.^116,^ ^117^ Six studies reported on adverse outcomes in children exposed to medication in utero; all were included in the previous update, and we identified no new studies.^129–134^ Appendix E Tables 13–29 provide our assessment of individual study methodological quality.

### Maternal Adverse Effects

#### Study Characteristics

Among the 13 RCTs reporting on the benefits of treatment for bacterial vaginosis during pregnancy (KQ 4), eight reported on maternal adverse effects, including vaginal itching or yeast infection and gastrointestinal symptoms. These eight RCTs included four trials of intravaginal clindamycin,^113,^ ^114,^ ^116,^ ^123^ two trials of oral clindamycin,^119,^ ^120^ and two trials of oral metronidazole.^111,^ ^117^ Study characteristics for the RCTs reporting maternal adverse effects are described in the previous section (KQ 4 benefits of treatment) and in Table 7.

#### Findings

Results from individual studies are presented in Table 9. Across this body of evidence, maternal adverse effects from treatment with oral clindamycin or oral metronidazole occurred at a higher incidence compared with control treatment but were not severe in nature. AEs from intravaginal clindamycin were infrequent and mild in nature. The rest of this section presents findings by medication and route of administration.

Table 9 Maternal Harm Outcomes From Randomized, Controlled Trials of Treatment of Bacterial Vaginosis to Prevent Preterm Delivery (Key Question 5)

Author et al;; Publication Year;; Intervention (N Analyzed); Comparator (N Analyzed) | Maternal Harms
Carey et al^111^;; 2000;; G1: Placebo (859); G2: Oral metronidazole 1000 mg dose four times (845) | Side effects; G1: 88/966 (9.1%); G2: 206/953 (21.6%); Calculated ARD, 12.51% (95% CI, 9.33% to 15.69%); Calculated RR, 2.37 (95% CI, 1.88 to 3.00); GI symptoms; G1: 72/966 (7.45%); G2: 188/953 (19.73%); Calculated ARD, 12.27% (95% CI, 9.25% to 15.29%); Calculated RR, 2.65 (95% CI, 2.05 to 3.42); Vomiting; G1: 27/966 (2.80%); G2: 92/953 (9.65%); Calculated ARD, 6.86% (95% CI, 4.72% to 9.00%); Calculated RR, 3.45 (95% CI, 2.27 to 5.25); Treatment of candida infection; G1: 47/966 (4.87%); G2: 114/953 (11.96%); Calculated ARD, 7.10% (95% CI, 4.63% to 9.56%); Calculated RR, 2.46 (1.78 to 3.41)
Kekki et al^113^;; 2001;; Kurkinen-Raty et al^126^;; 2000;; G1: Placebo (188); G2: Intravaginal clindamycin 2% cream once daily for 7 days (187) | Vulvovaginal itching consistent with yeast infection; G1: 6/188 (3.19%); G2: 6/187 (3.21%); Calculated ARD, 0.02% (95% CI, −3.55% to 3.58%); Calculated RR, 1.01 (95% CI, 0.33 to 3.06)
Kiss et al^114^;; 2004; G1: No treatment (176)^†^; G2: Intravaginal clindamycin 2% cream once daily for 6 days with test of cure and further treatment if positive (175) | AEs; G1: 0; G2: 0
Larsson et al^116^;; 2006;; G1: No treatment (411); G2: Intravaginal clindamycin 2% cream, once daily for 7 days (408) | Withdrew from treatment for persistent itching; 3/353 (0.85%) (group unknown); Severe treatment-related AEs; G1: NR; G2: 0
McDonald et al^117^;; 1997;; G1: Placebo (428); G2: Oral metronidazole 800 mg daily for 2 days and repeated at 28 weeks gestation for positive test of cure (429) | Total AEs (includes nausea, vomiting, diarrhea, headache, dizziness, rash, thrush, back pain); G1: 16/428 (3.74%); G2: 27/429 (6.29%); Calculated ARD, 2.56% (95% CI, −0.36% to 5.47%); Calculated RR, 1.68 (95% CI, 0.92 to 3.08); Discontinued treatment (unknown whether because of AEs); G1: 14/428 (3.27%); G2: 19/429 (4.43%); Calculated ARD, 1.16% (95% CI, −1.42% to 3.73%); Calculated RR, 1.35 (95% CI, 0.69 to 2.67)
Subtil et al^119^;; 2014;; G1: Placebo (956); G2: Oral clindamycin 600 mg daily for 4 days; G3: Oral clindamycin 600 mg daily for 4 days repeated twice at 1-month intervals (G2/G3 combined 1,904) | Any side effects; G1: 12/956 (1.26%); G2/G3: 58/1904 (3.05%); Calculated ARD, 1.79% (95% CI, 0.75% to 2.84%); Calculated RR, 2.43 (95% CI, 1.31 to 4.50); Any serious AE; G1: 0/956; G2: 0/1904; Stopped taking treatment (unclear whether because of side effects); G1: 156/956 (16.32%); G2: 374/1904 (19.64%); Calculated ARD, 3.33% (95% CI, 0.38% to 6.27%); Calculated RR, 1.20 (95% CI, 1.02 to 1.43); Diarrhea; G1: 4/956 (0.42%); G2: 30/1904 (1.58%); Calculated ARD, 1.16% (95% CI, 0.46% to 1.85%); Calculated RR, 3.77 (1.33 to 10.66); Abdominal pain; G1: 0/956 (0%); G2: 9/1904 (0.5%); Calculated ARD, 0.42% (95% CI, 0.08% to 0.76%); Calculated RR, 9.04 (95% CI, 0.52 to 155.8)
Ugwumadu et al^120^;; 2003;; G1: Placebo (203); G2: Oral clindamycin 600 mg daily (in two divided doses) for 5 days (207) | Side effects leading to discontinuation of treatment; G1: 8/241 (3.32%); G2: 17/244 (6.97%); Calculated ARD, 3.65% (95% CI, −0.27% to 7.56%); Calculated RR, 2.10 (95% CI, 0.92 to 4.78); Gastrointestinal upset; G1: 1/241 (4.15%); G2: 5/244 (2.05%); Calculated ARD, −2.1% (95% CI, −5.18% to 0.98%); Calculated RR, 0.49 (95% CI, 0.17 to 1.42); Rash; G1: 1/241 (0.41%); G2: 1/244 (0.41%); Vulvovaginal candidiasis; G1: 2/242 (0.83%); G2: 1/244 (0.41%); Throat irritation; G1: 1/241 (0.41%); G2: 0/244 (0%); Headache; G1: 1/241 (0.41%); G2: 4/244 (1.64%)
Vermeulen et al^123^;; 1999;; G1: Placebo (11)^§^; G2: Intravaginal clindamycin 2% cream once daily for 7 days at 26 weeks and again at 32 weeks (11) | Withdrawals because of serious AEs; G1: 0/85^*^; G2: 0/83^*^; Candida vaginitis; G1: 1/85^*^; G2: 1/83^*^; Troublesome discharge; G1: 0/85^*^; G2: 3/83^*^

* Represents the full study population, not just women with BV.

† This study randomized a total of 4,429 participants to vaginal smear screening, but only a subset of participants tested positive for BV and received treatment; we only abstracted data for the BV-positive subset of the study population.

§ This represents the number of women with BV who were allocated to placebo and treatment; the total number of women randomized in the study was 168 (placebo [N=85] and active treatment [N=83].

Abbreviations: AE=adverse event; ARD=absolute risk difference; CI=confidence interval; G=group; GI=gastrointestinal; KQ=key question; N=number of participants; RR=relative risk.

##### Intravaginal Clindamycin

Four RCTs evaluating intravaginal clindamycin reported on maternal adverse effects.^113,^ ^114,^ ^116,^ ^123^ Vermeulen et al^123^ reported no withdrawals because of serious AEs, and Larsson et al^116^ reported no serious treatment-related maternal AEs in the treatment group. Kiss et al reported no AEs observed during the treatment period.^114^ Kekki et al^113^ reported an incidence of vulvovaginal itching of 3.2 percent in both the treatment and placebo groups, and in Larsson et al,^116^ three women withdrew from treatment because of persistent itching (study group unknown). Other side effects reported in Vermeulen et al, a study that included both women with and without bacterial vaginosis, were two cases of candida vaginitis (1 in each study group) and three cases of troublesome discharge (all in the clindamycin group).^123^

##### Oral Clindamycin

Two RCTs reported maternal AEs from oral clindamycin;^119,^ ^120^ one was new to this update.^119^ Subtil et al reported no serious AEs but a significantly higher incidence of any side effects in the treatment group compared with the placebo group (3.1% vs. 1.3%; calculated p=0.0035).^119^ Incidence of treatment discontinuation was also significantly higher in the treatment group (19.6% vs. 16.3%; calculated p=0.031); reasons for discontinuation were not reported. Ugwumadu et al observed no significant difference in side effects resulting in discontinuation of treatment between clindamycin and placebo groups (7% vs. 3%; p=0.10).^120^ Both studies also reported on gastrointestinal side effects. In Subtil et al, participants in the treatment group had a significantly higher incidence of diarrhea (1.6% vs. 0.4%; calculated p=0.0071) but not abdominal pain (0.5% vs. 0%; p=0.062) compared with the placebo group.^119^ In Ugwumadu et al, the frequency of gastrointestinal upset was not significantly higher in the placebo group compared with the clindamycin group (4.2% compared with 2.1%; calculated p=0.18).^120^ Other reported side effects in Ugwumadu et al include rash (1 in each group), vulvovaginal candidiasis (2 in clindamycin and 1 in placebo group), throat irritation (1 in placebo group), and headache (4 in clindamycin and 1 in placebo group).

##### Oral Metronidazole

Two RCTs reported maternal AEs from oral metronidazole.^111,^ ^117^ Women randomized to oral metronidazole were more likely to experience one or more side effects compared with those randomized to placebo in both studies.^111,^ ^117^ In Carey et al, 21.6 percent in the metronidazole group experienced one or more side effects compared with 9.1 percent in the placebo group (calculated p<0.001).^111^ Participants treated with metronidazole had a significantly higher incidence of gastrointestinal symptoms (19.7% vs. 7.5%; calculated p>0.001) and vomiting (9.7% vs. 2.8%; calculated p<0.001), as well as a higher incidence of treatment for vaginal yeast infections (12% vs. 4.9%; calculated p<0.001) compared with placebo. In McDonald et al, 27 (6.3%) participants in the treatment group reported AEs compared with 16 (3.7%) participants in the placebo group (calculated p=0.09). Further, 19 (4.4%) and 14 (3.3%) participants discontinued treatment in the metronidazole and placebo groups, respectively (calculated p=0.38), although the reasons for discontinuation were not reported.^117^

### Adverse Childhood Outcomes From in Utero Exposure to Medication

#### Study Characteristics

We included six studies reporting adverse childhood outcomes from in utero exposure to metronidazole;^129–134^ all studies were included in the prior review. We provide a summary of study characteristics and results in Table 10. Appendix D Tables 7–12 provide additional study characteristics and detailed outcomes. Three observational studies^129–131^ and two meta-analyses^133,^ ^134^ reported on outcomes related to congenital abnormalities and malformations, and one observational study^132^ reported on incidence of childhood cancer. We assessed one study as poor methodological quality because of confounding and because of a large amount of missing data;^129^ however, we retained it in our synthesis for continuity with the previous review. We assessed all other studies as fair methodological quality.

Table 10 Study Characteristics and Outcomes of Observational Studies and Meta-Analyses Reporting Harms in Children Related to In Utero Metronidazole (Key Question 5) Exposure

Author (Year); Study Quality | Study Design, Years Covered | Number of Participants, Study Population(s) | Exposure Description | Summary of Outcomes
Burtin et al (1995)^133^; Fair | Meta-analysis of 7 single or controlled-cohort studies published 1964 to 1987 | N not reported; Studies that included at least 10 women exposed to metronidazole during pregnancy; further details NR | Exposed to oral or intravaginal metronidazole during the first trimester compared with not exposed or exposed during the third trimester | Incidence of major congenital anomalies; Summary OR, 0.93 (95% CI, 0.73 to 1.18); Incidence of any congenital anomalies; Summary OR, 0.96 (95% CI, 0.75 to 1.22)
Caro-Paton et al (1997)^134^; Fair | Meta-analysis of 5 studies (4 cohort and 1 case control) published 1977 to 1994 | N=199,451; Studies in women exposed to metronidazole during pregnancy for whatever its indication; further details NR | Exposed to metronidazole during the first trimester compared with not exposed | Incidence of congenital anomalies; Summary OR, 1.08 (95% CI, 0.90 to 1.29)
Czeizel et al (1998)^131^; Fair | Case control, 1980 to 1991 | N=47,963; Pregnant women in Hungary identified through registries | Use of oral or intravenous metronidazole during pregnancy based on self-report, clinician prenatal care log books, or both | Incidence of congenital abnormalities:; Exposure during 1st month: OR, 2.24 (95% CI, 1.30 to 3.85); Exposure during 2^nd^ or 3^rd^ month: OR, 1.14 (95% CI, 0.89 to 1.46); Exposure during 5^th^ through 9^th^ month: OR, 1.07 (95% CI, 0.95 to 1.20)
Diav-Citrin et al (2001)^129^; Poor | Prospective cohort, 1989 to 1998 | N=857; Pregnant women who contacted the Israeli Teratogen Information Service for information about gestational exposure to metronidazole or to nonteratogenic agents | Self-report of gestational exposure to metronidazole or to nonteratogenic agents | Incidence of major birth defects; RR, 1.13 [95% CI, 0.30 to 4.23)
Sorensen et al (1999)^130^; Fair | Retrospective cohort, 1991 to 1996 | N=13,451; Women in Denmark who gave birth in North Jutland County between 1991 and 1996 identified using the Danish Medical Birth Registry | Pharmaco-Epidemiological Prescription Database of North Jutland capturing prescriptions for metronidazole during pregnancy | Incidence of congenital anomalies; Adjusted OR, 0.44 (95% CI, 0.11 to 1.81)
Thapa (1998)^132^; Fair | Retrospective cohort, 1975 to 1992 | Women ages 15 to 44 years enrolled in Tennessee’s Medicaid program at any point during their pregnancy | Tennessee Medicaid pharmacy database capturing prescriptions for metronidazole during pregnancy | Incidence of first primary cancer before age 5 years; Adjusted RR, 0.81 (95% CI, 0.41 to 1.59)

Abbreviations: N=number of participants; NR=not reported.

One case-control study in Hungary (Czeizel et al; N=47,963) identified congenital anomaly cases from the Hungarian Congenital Abnormality Registry and matched them with controls from the national birth registry. Authors obtained data on metronidazole use from clinician log books, self-report during interview, and a mailed questionnaire.^131^ Diav-Citrin et al conducted a prospective controlled cohort study in Israel comparing participants who contacted the Teratogen Information Service because of an exposure to metronidazole (N=228) with women contacting the service for exposure to nonteratogenic agents (N=629).^129^ Outcomes were self-reported by participants and then verified by medical records or the participant’s clinician; we assessed this study as poor quality. Sorensen et al conducted a population-based retrospective cohort study in Denmark that compared an exposed group identified from the Pharmaco-Epidemiological Prescription Database of North Jutland (N=124) with a pregnancy cohort (N=13,327); outcome data were obtained from the Danish Medical Birth Registry and the Danish Hospital Discharge Summary.^130^ Lastly, Thapa et al conducted a retrospective cohort study of pregnant participants in Tennessee that compared Medicaid claims files with the state’s childhood cancer database (N=328,846 participants; 1,172,696 person-years followup).^132^

We included two meta-analyses of observational studies of in utero exposure to metronidazole;^133,^ ^134^ three studies overlapped between the meta-analyses. The 1995 Burtin et al meta-analysis^133^ included seven cohort studies (total N not reported), four of which were excluded from the subsequent 1997 Caro-Paton et al meta-analysis^134^ because they used participants exposed to metronidazole in the third trimester rather than unexposed participants as the control group. Caro-Paton et al included five studies (total N=199,451), including four cohort studies and one unpublished case-control study.^134^

The studies we included for this KQ do not provide information about the indication for metronidazole treatment; the setting of treatment (i.e., inpatient vs. outpatient); or the dose, duration, and route of treatment. Further, the populations evaluated were not focused on pregnant women exposed to metronidazole specifically for the treatment of bacterial vaginosis, which may limit applicability; however, we retained these studies in this update for continuity with the previous update.

#### Findings

##### Congenital Anomalies

The two included meta-analyses found no evidence of an association between metronidazole and congenital malformations (OR, 0.96 [95% CI, 0.75 to 1.22]^133^ and OR, 1.08 [95% CI, 0.90 to 1.29]^134^). Similarly, with one exception, the three observational studies (one poor quality, two fair quality) found no association between metronidazole and congenital abnormalities.^129–131^ The exception was reported by Czeizel et al.^131^ In this fair-quality study, a significant association between congenital anomalies and exposure to metronidazole during the first month of gestation (OR, 2.24 [95% CI, 1.30 to 3.85]) but not for the second through third or fourth through ninth months.^131^ The authors note that because the first month of gestation is counted from the first day of the last menstrual period, several of these weeks of exposure may be before conception or during the all or none phase of fetal development; thus, this finding may be spurious or the result of recall bias or uncontrolled confounding.^131^

##### Cancer

One fair-quality cohort study among women enrolled in Tennessee Medicaid did not find an association between metronidazole exposure during pregnancy and diagnosis of first cancer before age 5 years among exposed children (adjusted RR, 0.81 [95% CI, 0.41 to 1.59]).^132^