# Chapter 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and key questions (KQs) for this review. The analytic framework illustrates the KQs that guided the review (Figure 1). The KQs were as follows:

1. Does screening for bacterial vaginosis in asymptomatic pregnant adolescents and women reduce preterm delivery and related morbidity and mortality?
  a) Does the effect of screening vary by baseline risk (e.g., low- vs. high-risk) for preterm delivery?
  b) Does the effect of screening vary by race/ethnicity?
  c) Does the effect of screening vary by maternal age?
  d) Does the effect of screening vary by gestational age?
  e) Does the effect of screening vary by other risks for preterm delivery (e.g., coinfection with STIs, HIV status)?
2. What is the diagnostic accuracy of tests used to screen for bacterial vaginosis?
  a) Does diagnostic accuracy vary based on whether an individual is pregnant?
3. What are the harms of screening for bacterial vaginosis in asymptomatic pregnant adolescents and women?
4. Does treatment of bacterial vaginosis during pregnancy reduce preterm delivery and related morbidity and mortality?
  a) Does the effect of treatment vary by baseline risk (e.g., low- vs. high-risk) for preterm delivery?
  b) Does the effect of treatment vary by race/ethnicity?
  c) Does the effect of treatment vary by maternal age?
  d) Does the effect of treatment vary by gestational age?
  e) Does the effect of treatment vary by other risks for preterm delivery (e.g., coinfection with STIs, HIV status)?
5. What are the harms of treatment of bacterial vaginosis in pregnant adolescents and women?
  a) What are harms to pregnant adolescents and women?
  b) What are harms to the fetus or newborn?

Figure 1 Analytic Framework for Systematic Review of Screening for Bacterial Vaginosis in Pregnant Adolescents and Women to Prevent Preterm Delivery

Abbreviation: KQ=key question.

Figure 1 is titled “Analytic Framework for Systematic Review of Screening for Bacterial Vaginosis in Pregnant Adolescents and Women to Prevent Preterm Delivery.” This figure depicts the key questions (KQs) within the context of the eligible populations, screenings/interventions, comparisons, outcomes, timing, and settings. On the left, the population of interest is specified as asymptomatic pregnant adolescents and women. Moving from left to right, the figure illustrates the overarching question: Does screening for bacterial vaginosis improve health outcomes (i.e., reduce preterm delivery and related morbidity and mortality) in pregnant adolescents and women (KQ 1)? The figure depicts the pathway from screening for bacterial vaginosis to diagnosis of bacterial vaginosis to illustrate the question: What is the diagnostic accuracy of tests used to screen for bacterial vaginosis (KQ 2)? Screening may result in harms (KQ 3). The figure also illustrates the question: Does treatment of bacterial vaginosis during pregnancy reduce preterm delivery and related morbidity and mortality? (KQ 4)? Along this pathway, the intermediate outcome of clearing of bacterial vaginosis is depicted. Treatment may also result in harms (KQ 5).

In addition to our KQs, we looked for evidence related to five CQs.

1. What is the association between bacterial vaginosis, intermediate flora, or abnormal vaginal flora and preterm delivery in U.S. populations or in similar populations if no U.S. data are available or are limited?
2. Is treatment of intermediate flora and abnormal flora associated with reduced preterm delivery?
3. What is the association between bacterial vaginosis and other known risks for preterm delivery?
4. What is the uptake or use of various diagnostic tests for bacterial vaginosis in clinical practice?
5. What are the adverse drug events related to metronidazole or clindamycin when used to treat bacterial vaginosis in nonpregnant women and adolescents?

We do not show these CQs in the analytic framework because they were not analyzed using the same systematic review process as the KQs. Findings related to the CQs are summarized in Appendix A.

## Data Sources and Searches

We searched MEDLINE (via PubMed), Embase, and the Cochrane Library for English-language articles from January 1, 2006, through May 29, 2019, building on the literature included in the prior 2008 evidence review for the USPSTF.^2,^ ^3^ Because the previous reviews on this topic for the USPSTF did not include a systematic search for KQ 2 (diagnostic test accuracy), we conducted a separate PubMed search from inception through December 31, 2005, to supplement our main search for this update. We used Medical Subject Headings (MeSH) terms when available and keywords to describe relevant screening tests, treatment interventions, populations, and study designs. The complete search terms and limits are detailed in Appendix B Tables B1 and B2. We also searched the clinicaltrials.gov registry and the World Health Organization International Clinical Trials Registry Platform. To supplement the electronic database searches, we screened relevant systematic reviews and reference lists of included articles. We conducted surveillance of the literature through December 31, 2019.

## Study Selection

We developed inclusion and exclusion criteria for selecting studies based on populations, interventions, comparators, outcomes, timing, settings, and study designs; these are described in detail in Appendix B3. Briefly, for KQs 1, 3, 4, and 5, we selected controlled trials (randomized or nonrandomized) conducted in pregnant women or adolescents; for KQs 1 and 3, we also required participants to be asymptomatic with respect to vaginal symptoms. For KQs 1 and 3, we selected studies that compared screening with no screening and reported health outcome benefits (e.g., preterm delivery) or harms (e.g., anxiety). For KQs 4 and 5, we selected trials that compared treatment with metronidazole or clindamycin with placebo or no treatment in symptomatic or asymptomatic pregnant women with bacterial vaginosis and that reported health outcomes related to preterm delivery, other adverse pregnancy outcomes, or adverse maternal effects of treatment. For KQ 5, we also selected observational studies that reported on adverse maternal effects or outcomes related to fetal exposure to metronidazole or clindamycin, such as carcinogenesis or congenital malformations. For KQ 2, we selected studies that reported on diagnostic test accuracy for Amsel’s clinical criteria or laboratory-based tests in commercial use or feasible for use in primary care settings. We did not require participants to be pregnant in studies selected for KQ 2. Systematic reviews similar in scope to our review were also eligible for study selection for all KQs. Two independent reviewers screened titles and abstracts and then full-text articles for selection; disagreements were resolved by discussion or by a third reviewer.

We included English-language studies that met all study selection criteria, that were fair or good methodological quality, and that were conducted in the 58 countries categorized as very highly developed by the 2017 Human Development Index.^75^ We reassessed studies from the prior 2008 review against the study selection and methodological quality criteria for this update.

## Quality Assessment and Data Abstraction

For each included study, one reviewer abstracted relevant study characteristics (i.e., population, intervention, comparator) and data for eligible outcomes into a structured form. A second reviewer checked all data for completeness and accuracy, and the lead investigator reviewed all abstracted information for consistency across included studies. We contacted some study authors to clarify some data. We did not use data included in the previous review that we could not verify from the original source publication or from study authors.

Two senior reviewers independently assessed each study’s methodological quality. Disagreements in study quality ratings were resolved through discussion or with an independent assessment from a third senior investigator. For randomized, controlled trials (RCTs), we used a risk of bias instrument (RoB 2.0) from the Cochrane Collaboration, which assesses the following risk of bias domains: bias arising from selection or randomization, bias due to missing outcome data, bias due to departures from intended interventions, bias from measurement of outcomes, and bias from selective reporting of results.^76^ For controlled cohort studies, we used the ROBINS-I instrument, which includes similar domains as the RoB 2.0 instrument, but includes additional domains related to confounding and measurement of the exposure.^77^

For case-control studies, we used a methodology checklist from the Scottish Intercollegiate Guidelines Network.^78^ For systematic reviews and meta-analyses, we used the ROBIS instrument to assess methodological quality.^79^ For studies of diagnostic test accuracy, we used the QUADAS-2 instrument.^80^ We translated our risk of bias assessments using these instruments into an overall study quality rating using the predefined criteria developed by the USPSTF (Appendix B3), which uses study methodological quality ratings of poor, fair, and good. Studies reporting multiple outcomes may have been assigned different quality ratings for different outcomes.

## Data Synthesis and Analysis

For diagnostic test accuracy (KQ 2), we synthesized data related to sensitivity, specificity, and likelihood ratios in tabular and narrative formats. When at least three studies using the same index test and test threshold were available, we performed a quantitative synthesis by fitting the bivariate model described by Reitsma et al^81^ with the metandi package in Stata (version 15) to generate a summary receiver operating characteristics curve (SROC) and a pooled summary point estimate of sensitivity and specificity. We generated a 95 percent confidence region around the pooled summary point on the SROC curve, which represents a measure of sampling variation (i.e., chance) and can be used to assess precision of the pooled summary estimate. We also generated a 95 percent prediction region around the pooled summary estimate on the SROC curve. The prediction region provides a visual estimate of between-study variability and is used to determine whether there is more variability in results than can be expected due to sampling variability (i.e., chance) alone. For diagnostic test accuracy studies, the use of prediction regions is preferred to the I^2^ statistic for assessing heterogeneity because prediction regions take into account the correlation between sensitivity and specificity and account for variation in test thresholds used.^82^ Unlike the confidence region, which identifies the region where we expect the “true” summary pooled estimate to lie, the prediction region represents the region where we expect an estimate from a future single study to lie. We assessed the heterogeneity of pooled findings by visual inspection of the forest plots and by the size and shape of the 95 percent prediction region in the ROC space. A prediction region that is much larger than the 95 percent confidence region indicates a high degree of between-study variability that cannot be explained by chance alone.^82,^ ^83^ Further, we assessed the symmetry of both the confidence and prediction regions; regions that cover more space in the vertical direction relative to the horizontal direction indicate less precision (confidence region) and more heterogeneity (prediction region) in the estimate of sensitivity compared with the estimate for specificity.

For benefits of treatment (KQ 4), we synthesized findings using both absolute risk differences (ARDs) and RR ratios. For harms of treatment (KQ 5), we also used ORs to synthesize findings. We assessed whether a quantitative synthesis was appropriate for KQs 4 and 5 by evaluating the number of studies available and the clinical and methodological heterogeneity present among available studies based on established guidance,^84^ which includes evaluating the similarities in study population, medication, dose, and frequency and similarities in timing and specification of outcomes. When a quantitative synthesis was possible, we used random-effects models with the inverse-variance weighted method of DerSimonian and Laird with the metafor package in R (version 2.0-0).^85^ We assessed statistical heterogeneity of findings with the I^2^ statistic; an I^2^ between 0 and 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, and 50 to 90 percent may represent substantial heterogeneity.^76^ We considered pooled findings statistically significant when the 95% CIs excluded the null value. We assessed the potential for publication bias through visual inspection of a funnel plot when at least 10 studies were included in an analysis.

We assessed the strength of evidence (SOE) based on AHRQ’s “Methods Guide for Effectiveness and Comparative Effectiveness Reviews,” which specifies the assessment of study limitations, directness, consistency, precision, and reporting bias for each intervention comparison and major outcome of interest.^86^ Two senior reviewers independently developed initial SOE assessments for each relevant outcome and comparison across the KQs; discrepancies were resolved through discussion and the independent assessment of a third senior reviewer.

For diagnostic test accuracy (KQ 2), we made a single SOE assessment for the outcome of test accuracy for each test evaluated relying on AHRQ’s Methods Guide and additional guidance specific to assessing SOE for diagnostic test accuracy.^83,^ ^86^ We based our SOE assessment on sensitivity and specificity measures that are more clinically useful than global measures of test accuracy (e.g., area under the curve [AUC], diagnostic OR) because they distinguish between the two dimensions of test accuracy (false-positive and false-negative results).^82^ For these SOE assessments, we started all ratings at a “high.”^87^ Because test accuracy was explicitly identified as an outcome of interest for KQ 2, we considered all test accuracy outcomes as direct with respect to the directness domain of SOE assessment even though diagnostic accuracy is part of the indirect evidence path on the analytic framework. We evaluated the consistency domain using the 95 percent prediction region for outcomes that were quantitatively synthesized or by evaluating the range of sensitivity and specificity estimates for outcomes where a quantitative synthesis was not possible and considered whether any inconsistency could be explained by differences in population, test threshold, or other study characteristics. We evaluated the precision domain by assessing the size of the 95 percent confidence regions for pooled estimates and the CI range around individual study estimates where a quantitative synthesis was not possible.

For the benefits of treatment (KQ 4), we conducted SOE assessments for each pooled outcome, and conducted separate assessments for the general obstetric population and for the population with a prior preterm delivery. Because preterm delivery outcomes were explicitly identified as an outcome of interest for KQ 4, we considered them to be direct. We evaluated the consistency domain by visual inspection of the forest plot and with the I^2^ statistic and by whether any inconsistency could be explained by study population or design characteristics. We evaluated the precision domain by calculating the optimal information size (i.e., sample size needed in a single adequately powered trial) required to generate a precise estimate and by evaluating whether the CIs around pooled estimates crossed clinically meaningful thresholds of benefit (or harm).

For the harms of treatment (KQ 5), we assessed the SOE separately for maternal harms and harms in children exposed to medication in utero. For maternal harms, we aggregated comparisons and outcomes to generate a single SOE rating when possible. For harms in children exposed to medication in utero, we evaluated the SOE for the outcome of congenital malformations separately from the outcome of incident childhood cancer. Because each of these harms was explicitly identified as an outcome of interest for KQ 5, we considered them all to be direct. We evaluated consistency and precision similar to KQ 4 outcomes.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF Web site from February 22, 2018, to March 21, 2018. In response to public comments, the USPSTF added additional subpopulations for assessing variation in benefits and harms of screening and treatment. In addition, the USPSTF clarified terminology related to populations, screening tests, interventions, and comparators in the Research Plan. A final Research Plan was posted on the USPSTF’s Web site on May 17, 2018.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate.

A draft version of this evidence report was posted for public comment on the USPSTF Web site from October 8, 2019, to November 4, 2019. A few comments were received, but no changes were made to the evidence or to our conclusions.