# Chapter 1 Introduction

## Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its 2008 recommendation on screening for bacterial vaginosis in pregnancy to prevent preterm delivery.^1^ The 2008 recommendation was an update to the 2001 recommendation on this topic and is summarized as follows:

- The USPSTF recommended against screening for bacterial vaginosis in asymptomatic pregnant women at low risk for preterm delivery (D recommendation).
- The USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening for bacterial vaginosis in asymptomatic pregnant women at high risk for preterm delivery (I statement).

The USPSTF made the 2008 recommendation based on an updated systematic review published in 2008.^2,^ ^3^

## Condition Definition

### Bacterial Vaginosis

Bacterial vaginosis is a common lower genital tract syndrome defined as a shift from normal hydrogen peroxide–producing lactobacilli to mixed anaerobes, such as Gardnerella species, Prevotella species, and Atopobium species.^4,^ ^5^ Lactobacillus species comprise between 90 and 95 percent of the total bacteria count in the healthy vaginal flora and play a key role in maintaining balance and host defense against pathogens by producing several substances that inhibit the growth of deleterious microorganisms.^6,^ ^7^ Symptoms of bacterial vaginosis typically include off-white, thin, homogenous discharge or vaginal “fishy” odor, or both; however, many women with bacterial vaginosis are asymptomatic.

### Preterm Delivery

Preterm delivery is defined as birth before 37 completed weeks of gestation.^8^ Preterm deliveries can be classified into two broad subtypes: (1) spontaneous preterm delivery following the spontaneous onset of preterm labor or following premature rupture of membranes (PROM) and (2) provider-initiated preterm delivery (i.e., medically indicated or elective inductions of labor or caesarean births). Although the 37-week cutoff is the conventional definition of preterm delivery, adverse outcomes associated with prematurity are inversely related to the gestational age at delivery and may continue until 39 weeks, albeit at lower rates.^9^

## Prevalence and Burden of Disease/Illness

### Bacterial Vaginosis

Worldwide bacterial vaginosis prevalence estimates range from 12 percent in Australian women and 29 percent in North American women to more than 50 percent in women from Eastern and Southern Africa.^10^ The prevalence of bacterial vaginosis in the United States is estimated to be 29.2 percent among all women ages 14 to 49 years (some of whom are pregnant), corresponding to 21 million women, according to National Health and Nutrition Examination Survey (NHANES) data from 2001 through 2004, the most recent years for which nationally representative estimates are available.^11^ Prevalence varies most notably by race/ethnicity. The NHANES data from 2001 through 2004 showed significantly higher rates among African Americans (52.6%) and Mexican Americans (32%) than among non-Hispanic whites (23%).^11^ Among five studies published between 1995 and 2014, a higher prevalence of bacterial vaginosis (range, 25% to 50%) was observed among women who have sex with women.^12^ In the United States, the prevalence of bacterial vaginosis among pregnant women ranges from 5.8 to 19.3 percent and is influenced by the study population and the diagnostic criteria. The prevalence is higher in some races/ethnicities.^13^

Studies conducted between 1983 and 2006 estimate that only 25 to 50 percent of women with bacterial vaginosis report symptoms.^14–16^ Disease recurrence within 12 months of treatment occurs in more than half of cases; some suggest this is because bacterial vaginosis results from a disturbance of the vaginal microflora as opposed to definitive infection caused by a single organism.^17^ In symptomatic women, studies have shown that recurrent bacterial vaginosis is associated with a significant adverse effect on self-esteem, sexual relationships, and quality of life.^18^ Further, women who have bacterial vaginosis are at increased risk for the development of infection with herpes simplex virus type 2, Trichomonas vaginalis, Neisseria gonorrhoeae, Chlamydia trachomatis, and human immunodeficiency virus (HIV).^19^ Based on epidemiological studies, bacterial vaginosis has been associated with a range of adverse gynecologic and obstetric outcomes, including early miscarriage and recurrent pregnancy loss (adjusted relative risk [RR], 2.03 [95% confidence interval {CI}, 1.09 to 3.78]),^20^ pregnancy loss before 22 weeks (RR range, 3.1 [95% CI, 1.4 to 6.9]),^21^ pelvic inflammatory disease (magnitude not well defined),^22^ postabortion sepsis (magnitude not well defined),^23^ postpartum endometritis (odds ratio [OR], 5.8 [95% CI, 3.0 to 10.9]),^24^ and low birth weight (OR, 1.4 [95% CI, 1.1 to 1.8]).^25^

### Preterm Delivery

Worldwide, an estimated 11.1 percent (14.9 million) of all live births in 2010 were preterm.^26^ In 2018 in the United States, 10.0 percent of live births were preterm, and its complications, such as major intraventricular hemorrhage, acute respiratory illnesses, and sepsis, are the leading causes of death among infants.^27–30^ The U.S. National Vital Statistics Reports from 2013 reported that two thirds of all infant deaths in the United States occurred among infants born preterm; the mortality incidence for infants born less than 32 weeks, 32 to 33 weeks, 34 to 36 weeks, and 37 to 38 weeks was 163.7, 16.02, 7.23, and 3.01 per 1,000 live births, respectively, compared with 1.85 for full-term infants.^27^ Preterm birth rates vary by race/ethnicity in the United States; the 2018 preterm birth rate was 8.6 percent among Asian women, 11.8 among Native Hawaiian or Other Pacific Islander women, 9.7 percent among Hispanic women, 11.5 percent among American Indian or Alaska Native women, 14.1 percent among black women, and 9.1 percent among white women.^29^ In an epidemiologic review of 16 studies reporting on the pattern of preterm delivery, spontaneous preterm labor was reported as the etiology in 27.9 to 64.1 percent of preterm deliveries, preterm PROM (PPROM) was reported as the etiology in 7.1 to 51.2 percent of preterm deliveries, and medical indication was reported in 18.7 to 35.2 percent of preterm deliveries.^31^

The frequency and severity of adverse outcomes from preterm delivery are higher with earlier gestational age and lower quality of health care during the puerperium. Most babies born at less than 28 weeks of gestational age need neonatal intensive care services to survive, and most babies born at 28 to 32 weeks need special newborn care at a minimum. Babies born before 32 weeks are at especially high risk of cerebral palsy, intellectual impairment, and vision and hearing loss.^32^ The vast majority (84%) of all preterm deliveries occur between 32 and 37 weeks.^33^ Most babies born between 32 and 37 weeks survive with adequate supportive care but are still at increased risk of neonatal and infant death, cerebral palsy leading to neurodevelopmental delays, and lower school performance. Large economic costs are associated with preterm delivery, including neonatal intensive care and long-term complex health needs and disabilities. In the United States, the costs related to preterm delivery exceeded $26 billion annually in 2006, not including indirect costs.^34^

## Etiology and Risk Factors

### Bacterial Vaginosis

Bacterial vaginosis is caused by a disruption of the microbiotic environment in the lower genital tract.^35^ Mucosal homeostasis is normally maintained in the vaginal canal by an intricate balance between the host mucosal immune response and the microbiota that colonize the mucosal surfaces.^7^ Lactobacillus species play a key role in maintaining balance and host defense against pathogens by producing several substances that inhibit the growth of deleterious microorganisms.^6,^ ^7^ Lactobacillus species are thought to inhibit the growth of pathogenic bacteria by generating hydrogen peroxide and other antimicrobials and by maintaining a highly acidic environment (lower pH through lactic acid), which can disrupt bacterial cell membranes and stimulate host immunity.^36^ Bacterial vaginosis is characterized by a marked depletion of Lactobacillus species and a 1,000-fold increase in the number of anaerobic bacteria.^6,^ ^7^ Although it was previously thought that the Gardnerella species was the defining organism, multiple anaerobic bacteria, including Gardnerella, Prevotella, Atopobium, Megasphera, and others, have been identified.^37,^ ^38^ In some women with bacterial vaginosis, up to 35 unique species have been identified.^38^ The availability of inexpensive and efficient gene-sequencing assays have allowed for the objective identification of communities of microorganisms and fastidious organisms that were difficult to identify through traditional culture techniques. These laboratory advances have provided data to solidify the concept of bacterial vaginosis as a disbalance in the vaginal microbiome ecosystem.^38^ Further research also supports the concept of bacterial vaginosis as a biofilm, which is a community of microorganisms attached to epithelial surfaces and encased in matrices of polysaccharides, proteins, and nucleic acids.^38–40^ Biofilms can persist even in the presence of lactic acid–producing bacteria and despite antibiotic usage.

Bacterial vaginosis is sometimes thought of as sexually transmitted. Although several studies have shown the presence of bacterial vaginosis in women who report never having sex,^11,^ ^35,^ ^41^ this may be due to varying study definitions of sex (only penetrative or including nonpenetrative sex) and bias surrounding self-reporting.^42–44^ Evidence shows that certain sexual behaviors increase the incidence of bacterial vaginosis, including a higher number of partners, lack of condom or contraceptive use, vaginal sex, sex with a female partner, and concurrent sexually transmitted infections (STIs).^45^ The RR for incident bacterial vaginosis associated with having a new sexual partner is 1.13 (95% CI, 1.02 to 1.25).^45^ The risk for recurrent or persistent bacterial vaginosis over 12 months from sex with the same partner (adjusted RR, 3.1 [95% CI, 1.6 to 6.3]) and any female sexual partner (adjusted RR, 3.6 [95% CI, 1.5 to 8.5]) is also elevated.^17^

Race/ethnicity is also a significant risk for bacterial vaginosis; African American women have the highest prevalence and non-Hispanic white women have the lowest prevalence.^11^ Some have postulated this difference could be explained by genetics, socioeconomic status, psychosocial stress, or sexual networks.^7,^ ^46,^ ^47^ Research on the relationship between vaginal pH and microbiota also suggests some underlying racial/ethnic variation in microbiota composition.^48^ Women of European ancestry are more likely to have microbiota dominated by Lactobacilli species whereas African American women are more likely to exhibit a diverse microbial profile and higher pH.^48^ Some investigators have also suggested that nutritional factors may play a role; higher dietary fat intake is associated with bacterial vaginosis, while higher consumption of folate, vitamin E, and calcium have an inverse relationship with bacterial vaginosis.^49^ Other factors associated with bacterial vaginosis include poverty, smoking, increased body mass index, vaginal douching, and low educational attainment.^12^

### Preterm Delivery

Preterm delivery likely has multiple causes, and although several risk factors have been identified as predictive of preterm delivery, it is unclear whether these factors are causal or simply intermediate markers for some other underlying cause(s). A 2007 meta-analysis suggested that the risk of preterm delivery is doubled in the presence of asymptomatic bacterial vaginosis (pooled OR, 2.16 [95% CI, 1.56 to 3.00]; 32 studies; 30,518 participants).^50^ Appendix A (Contextual Questions [CQs] 1, 2, and 3) provides additional contextual information about the relationship between bacterial vaginosis and preterm delivery and the relationship between bacterial vaginosis and other risks for preterm delivery. An exact causal mechanism is poorly understood, but early hypotheses were that bacterial vaginosis causes infection of the upper genital tract, which may contribute to preterm labor, PPROM, or both.^25,^ ^51^ More recent research suggests a more complicated etiology. The mucosal immune response, which is influenced by many factors, including genetics, race/ethnicity, stress, hormones, and the vaginal microbiome, may influence both the risk for acquiring bacterial vaginosis and preterm labor or PPROM.^46^ Some experts have also suggested that the risk of preterm delivery may depend less on the type of vaginal flora and more on the type of host immune response to the flora, in particular the presence and response to biofilms.^50,^ ^52^

A significant predictor of preterm delivery is having a prior spontaneous preterm delivery. A secondary analysis of the Preterm Prediction Study dataset reported that women with a history of spontaneous preterm delivery had a 2.5-fold increased risk (95% CI, 1.9 to 3.2) of spontaneous preterm delivery in a subsequent pregnancy compared with women with no history of spontaneous preterm delivery.^53^

Cervical insufficiency, the failure of the cervix to remain closed during pregnancy, is also a risk factor for preterm delivery. Cervical insufficiency is largely assessed with cervical length as measured by digital or ultrasound examinations; the shorter the cervix, the higher the risk for preterm delivery.^54^ One study showed that the risk of spontaneous preterm delivery before 35 weeks decreased by 6 percent for each additional millimeter of cervical length (OR, 0.94 [95% CI, 0.92 to 0.95]),^55^ and another study found that treatment of women with short cervix using vaginal progesterone was associated with a significant reduction in the risk of preterm birth at less than 33 weeks of gestation (RR, 0.62 [95% CI, 0.47 to 0.81]).^56^

Other risk factors for preterm delivery include genitourinary infections, HIV infection, maternal medical conditions, young or advanced maternal age, low maternal body mass index, inadequate prenatal care, short interpregnancy intervals, nonsingleton pregnancies, and maternal race/ethnicity.^34,^ ^51,^ ^52,^ ^57^ Other factors that increase the risk of spontaneous preterm delivery include extreme psychosocial stress,^58^ excessive physical strain and exhaustion,^59^ smoking,^60^ and periodontal disease.^61^

In the United States, the rate of preterm delivery among nulliparous African American women is twice as high and the rate of recurrent preterm delivery is four times as high as the rate among white women.^52^ Researchers have hypothesized that racial/ethnic differences in preterm delivery incidence are partly due to commensurate racial/ethnic differences in bacterial vaginosis prevalence.^62^

## Rationale for Screening/Screening Strategies

The rationale for screening for bacterial vaginosis in asymptomatic pregnant women is to identify women with bacterial vaginosis early so that they can be offered treatment. Early identification and treatment of bacterial vaginosis may reduce the incidence of preterm delivery and the morbidity and mortality associated with preterm delivery.

The availability of gene sequencing techniques has advanced our understanding of the vaginal microbiome and the dysbiotic and biofilm properties that characterize bacterial vaginosis. However, existing diagnostic techniques largely predate this most current understanding. The epidemiologic and laboratory reference test standard for the diagnosis of bacterial vaginosis is a Gram stain of vaginal secretions, most commonly interpreted using the Nugent scoring system, which scores a specimen from 0 to 10. Scores of 0 to 3 indicate normal flora, scores of 4 to 6 indicate intermediate flora, and scores of 7 to 10 indicate bacterial vaginosis.^63,^ ^64^ Additional information about intermediate flora is in Appendix A (CQs 1 and 2). Amsel’s clinical criteria are widely used in research and clinical practice. Both the Nugent scoring system and Amsel’s clinical criteria are described in detail in Appendix A Table 1. A clinical diagnosis is made with Amsel’s clinical criteria by fulfilling three of four criteria (we refer to these as “complete Amsel’s criteria” in this report): vaginal pH greater than 4.5, the presence of clue cells (typically at least 20% of vaginal epithelial cells) on wet mount microscopy, thin homogeneous discharge, and an amine (i.e., fishy) odor when potassium hydroxide is added to the vaginal secretions. A modified version of Amsel’s test omits the criteria for vaginal discharge. The degree of interobserver and intraobserver variability in the Gram stain interpretation is lower compared with Amsel’s clinical criteria and offers the added ability to quantify and classify bacterial load, but scoring of morphotypes can be subjective and interpretation requires specific skills and volume of testing to be proficient.^38,^ ^64^

In recent years, other tests have been approved by the U.S. Food and Drug Administration (FDA) for aiding in the diagnosis of bacterial vaginosis. These include assays based on nucleic acids from a single swab of secretions to detect vaginosis-associated bacterial species; these tests can also detect nonvaginosis-associated organisms such as T. vaginalis and Candida species. The BD Affirm Vaginal Panel III (Becton, Dickinson and Co., Franklin Lakes, NJ) uses a nonamplified DNA probe specific to Gardnerella vaginalis, while the BD MAX Vaginal Panel is a multiplex polymerase chain reaction (PCR) assay that tests for five vaginosis-associated organisms: Lactobacillus species, G. vaginalis, Atopobium vaginae, Bacterial Vaginosis Associated Bacteria-2 (BVAB-2), and Megasphaera-1.^65^ Several other multiplex PCR assays are commercially available (NuSwab [LabCorp, Burlington, NC], SureSwab [Quest Diagnostics, Secaucus, NJ]) but evaluate slightly different panels of vaginosis-associated bacteria. These assays are offered by large, national laboratories and are considered laboratory developed tests within the Clinical Laboratory Improvement Amendment (CLIA) program and are not required to be approved by the FDA. AmpliSens Florocenosis-BV (InterLabService, Moscow, Russia) is approved for use in the European Union but is not FDA approved.^66,^ ^67^ Assays that detect elevated vaginal fluid sialidase activity (OSOM BVBLUE [Sekisui Diagnostics, Burlington, MA], FDA approved) associated with vaginosis and pH paper-coated vaginal swabs (VS-SENSE Pro [McKesson, Irving, TX], FDA approved) to detect alterations in vaginal pH commonly seen with bacterial vaginosis are also available.^65,^ ^68–72^

## Interventions/Treatment

Bacterial vaginosis is typically treated with medications that provide broad-spectrum anaerobic coverage, most commonly, metronidazole or clindamycin (see Appendix A Table 2 for commonly recommended doses, routes, and frequencies). Vaginal Cleocin (clindamycin) cream is the only medication with an FDA-label indication for the treatment of bacterial vaginosis in pregnant women (second trimester only). However, the Centers for Disease Control and Prevention recommend either clindamycin or metronidazole in oral or vaginal preparations for the treatment of bacterial vaginosis in pregnant women.^15^

Although short-term cure rates following first-line recommended regimens (i.e., clindamycin and metronidazole) are equivalent and approach 80 percent, studies with extended followup report recurrence rates in excess of 50 percent within 6 to 12 months.^17,^ ^73^ Recurrence may be due to partner reinfection or the persistence of the biofilm—the bacteria within a slimy extracellular matrix adherent to the vaginal surface that can be difficult to eradicate and that has been documented by vaginal biopsy after therapy with metronidazole.^17,^ ^74^ Other drugs, such as tinidazole and secnidazole, have FDA indications for the treatment of bacterial vaginosis, but data are limited regarding their use in pregnancy. Rifaximin is FDA approved but does not have a label indication for bacterial vaginosis and dequalinium chloride is not FDA approved for any indication in the United States. Nutriceuticals and probiotic agents are marketed with claims of “preserving vaginal health,” but none have been FDA approved for the treatment of bacterial vaginosis.

Treatment of bacterial vaginosis in nonpregnant women is typically limited to symptomatic cases. For context, we summarized the harms of treatment of bacterial vaginosis in nonpregnant women in Appendix A (CQ 5).

## Current Clinical Practice

Appendix A Table 3 summarizes recommendations of professional organizations related to screening for bacterial vaginosis in asymptomatic women in pregnancy. For organizations with recommendations on this topic, all either do not recommend routine screening for women at low risk for preterm birth or state the evidence is insufficient to support routine screening. However, the recommendations conflict with respect to screening among women at high risk for preterm birth. One recommends screening and/or treatment among women at increased risk for preterm birth, one recommends against, while others do not specifically address a higher-risk population. A limited amount of research is available that describes current practice patterns among clinicians with regard to screening for bacterial vaginosis; this information is summarized in Appendix A (CQ 4).