# Appendix H Evaluation of Test Accuracy Using Likelihood Ratios and Posttest Probabilities

The purpose of this appendix is to provide a more nuanced assessment of test accuracy. We used the likelihood ratios reported by studies or that we calculated based on data reported in the studies to show the influence of a positive and negative test on the posttest probability of bacterial vaginosis. We assumed a pretest probability of 17.2 percent, which was the average prevalence of bacterial vaginosis among asymptomatic women evaluated for study entry into the RCTs evaluating the benefits of treatment (KQ 4).

Appendix H Table 1 Likelihood Ratios and Posttest Probabilities After Positive and Negative Tests

Test | +LR | Posttest Probability After Positive Test | −LR | Posttest Probability After Negative Text
BD Affirm (pooled) | 4.6 | 48.9% | 0.16 | 3.2%
Lower 95% CL | 3.1 | 39.2% | 0.11 | 2.2%
Upper 95% CL | 6.8 | 58.6% | 0.26 | 5.1%
BD Max (Schwebke et al.) | 10.9 | 69.4% | 0.08 | 1.6%
Lower 95% CL | 10.7 | 68.9% | 0.08 | 1.6%
Upper 95% CL | 11.1 | 69.8% | 0.08 | 1.7%
BDBLUE (Bradshaw et al) | 6.3 | 56.6% | 0.14 | 2.8%
Lower 95% CL | 5.8 | 54.6% | 0.13 | 2.7%
Upper 95% CL | 6.6 | 58.0% | 0.15 | 3.0%
BDBLUE (Hillier et al) | 61 | 92.7% | 0.39 | 7.6%
Lower 95% CL | 51 | 91.4% | 0.39 | 7.5%
Upper 95% CL | 72 | 93.7% | 0.41 | 7.8%
BDBLUE (Myziuk et al) | 41.7 | 89.6% | 0.09 | 1.7%
Lower 95% CL | 29.6 | 86.0% | 0.08 | 1.7%
Upper 95% CL | 45.5 | 90.4% | 0.09 | 1.9%
Complete Amsel’s clinical criteria (pooled) | 14.1 | 61.0% | 0.26 | 2.8%
Lower 95% CL | 6.8 | 58.6% | 0.17 | 3.4%
Upper 95% CL | 29.2 | 85.8% | 0.39 | 7.5%
Modified Amsel’s clinical criteria (pooled) | 17.3 | 78.2% | 0.34 | 6.6%
Lower 95% CL | 10.4 | 68.4% | 0.24 | 4.7%
Upper 95% CL | 28.8 | 85.7% | 0.48 | 9.1%

Table Notes: Positive likelihood ratios greater than 10 and negative likelihood ratios less than 0.1 have been suggested as thresholds for indicating an accurate test that will result in clinically useful changes to the pretest probability. However, such universally applied thresholds do not take into account differences in pretest probability. A very rare condition may need a positive likelihood ratio much higher than 10 to result in a meaningful increase in the probability of disease after a positive test that would result in a decision to treat, and likewise a very common condition may need a negative likelihood ratio much lower than 0.1 to result in a meaningful decrease in the probability of disease after a negative test that would result in a decision not to treat.^82,^ ^202^

Abbreviations: CL = confidence limit; LR = likelihood ratio.