# Appendix G Additional Results for Benefits of Treatment (Key Question 4)

Appendix G Figure 1 Initial Analysis of Treatment Effect (Absolute Risk Difference) on Preterm Delivery Unstratified by Outcome in General Obstetric Population

Abbreviations: CI=confidence interval; OC=oral clindamycin; N=number of participants; OM=oral metronidazole; PTD=preterm delivery; VC=intravaginal clindamycin.

Appendix G Figure 1 is titled “Initial Analysis of Treatment Effect (Absolute Risk Difference) on Preterm Delivery Unstratified by Outcome in General Obstetric Population.” This figure displays a forest plot reporting the absolute risk difference of preterm delivery (all cause or spontaneous) at less than 37 weeks gestation for 10 studies. Among the 10 studies, two (Carey, 2000; McDonald, 1997) compared oral metronidazole with control, six (Guaschino, 2003; Larsson, 2006; McGregor, 1994; Kekki, 2001; Kiss, 2004; Lamont, 2003) compared intravaginal clindamycin with control, and two (Subtil, 2018; Ugwumadu, 2003) compared oral clindamycin with control. Two of the studies (Larsson, 2006; Kiss, 2004) were considered fair quality, while the remaining eight were considered good quality. Two of the 10 studies reported statistically significant reductions in preterm delivery for active treatment compared with control (absolute risk difference of −5.80% with 95% CI of −10.82% to −0.79% among 391 participants reported by Lamont [2003] and −9.96% with 95% CI of −15.77% to −4.14% among 410 participants reported by Ugwumadu [2003]), while the other eight reported no significant differences between active treatment and control.

Appendix G Figure 2 Initial Analysis of Treatment Effect (Risk Ratio) on Preterm Delivery Unstratified by Outcome in General Obstetric Population

Abbreviations: CI=confidence interval; OC=oral clindamycin; N=number of participants; OM=oral metronidazole; PTD=preterm delivery; VC=intravaginal clindamycin.

Appendix G Figure 2 is titled “Initial Analysis of Treatment Effect (Risk Ratio) on Preterm Delivery Unstratified by Outcome in General Obstetric Population.” This figure displays a forest plot reporting the risk ratio of preterm delivery (all-cause or spontaneous) at less than 37 weeks gestation for 10 studies. Among the 10 studies, two (Carey, 2000; McDonald, 1997) compared oral metronidazole with control; six (Guaschino, 2003; Larsson, 2006; McGregor, 1994; Kekki, 2001; Kiss, 2004; Lamont, 2003) compared intravaginal clindamycin with control; and two (Subtil, 2018; Ugwumadu, 2003) compared oral clindamycin with control. Two of the studies (Larsson, 2006; Kiss, 2004) were considered fair quality, while the remaining eight were considered good quality. Two of the 10 studies reported statistically significant reductions in preterm delivery for active treatment compared with control (risk ratio of 0.41 with 95% CI of 0.18 to 0.92 among 391 participants reported by Lamont [2003] and 0.35 with 95% CI of 0.18 to 0.67 among 410 participants reported by Ugwumadu [2003]), while the other eight reported no significant differences between active treatment and control.

Appendix G Figure 3 Absolute Risk Difference of Various Preterm Delivery Outcomes From Treatment of Bacterial Vaginosis Among a General Obstetric Population

* Includes spontaneous late abortion (≥16 weeks).

Abbreviations: CI=confidence interval; OC=oral clindamycin; N=number of participants; OM=oral metronidazole; PPROM=preterm premature rupture of membranes; PROM=premature rupture of membranes; PTD=preterm delivery; RE=random effects; VC=intravaginal clindamycin.

Appendix G Figure 3 is titled “Absolute Risk Difference of Various Preterm Delivery Outcomes From Treatment of Bacterial Vaginosis Among a General Obstetric Population.” This figure displays forest plots reporting the absolute risk difference for preterm delivery (all cause or spontaneous) at less than 32 weeks gestation for three studies, low birth weight (<2,500g) for five studies, very low birth weight (<1,500 g) for three studies, and preterm premature rupture of membranes or premature rupture of membranes for four studies. Among the three studies assessing preterm delivery at less than 32 weeks gestation, one (Carey, 2000) compared oral metronidazole with control, one (Larsson, 2006) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. One study (Larsson, 2006) was considered fair quality, while the remaining two were considered good quality. The pooled absolute risk difference comparing active treatment with control was −0.30% (95% CI, −0.97% to 0.38%; 5,564 participants, I2=15.4%). No individual studies reported a significant difference between active treatment and control. Among the five studies assessing low birth weight, one (Carey, 2000) compared oral metronidazole with control, three (Guaschino, 2003; Lamont, 2003; and McGregor, 1994) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. All five studies were considered good quality. The pooled absolute risk difference comparing active treatment with control was 0.39% (95% CI, −1.74% to 2.53%; 5,377 participants; I2=24.2%). No individual studies reported a significant difference between active treatment and control. Among the three studies assessing very low birth weight, one (Carey, 2000) compared oral metronidazole with control, one (Lamont, 2003) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. All three studies were considered good quality. The pooled absolute risk difference comparing active treatment with control was 0.06% (95% CI, −0.99% to 1.12%; 5,149 participants; I2=45.3%). No individual studies reported a significant difference between active treatment and control. Among the four studies assessing preterm premature rupture of membranes or premature rupture of membranes, one (McDonald, 1997) compared oral metronidazole with control, two (McGregor, 1994; Guaschino, 2003) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. All four studies were considered good quality. The pooled absolute risk difference comparing active treatment with control was 0.10% (95% CI, −1.32% to 1.52%; 3,568 participants; I2=9.4%). No individual studies reported a significant difference between active treatment and control.

Appendix G Figure 4 Risk Ratio for Various Preterm Delivery Outcomes From Treatment of Bacterial Vaginosis Among a General Obstetric Population

* Includes spontaneous late abortion (.16 weeks).

Abbreviations: CI=confidence interval; OC=oral clindamycin; N=number of participants; OM=oral metronidazole; PPROM=preterm premature rupture of membranes; PROM=premature rupture of membranes; PTD=preterm delivery; RE=random effects; VC=intravaginal clindamycin.

Appendix G Figure 4 is titled “Risk Ratio of Various Preterm Delivery Outcomes From Treatment of Bacterial Vaginosis Among a General Obstetric Population.” This figure displays forest plots reporting the risk ratio for preterm delivery (all cause or spontaneous) at less than 32 weeks gestation for three studies, low birth weight (<2,500 g) for five studies, very low birth weight (<1,500 g) for three studies, and preterm premature rupture of membranes or premature rupture of membranes for four studies. Among the three studies assessing preterm delivery at less than 32 weeks gestation, one (Carey, 2000) compared oral metronidazole with control, one (Larsson, 2006) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. One study (Larsson, 2006) was considered fair quality, while the remaining two were considered good quality. The pooled risk ratio comparing active treatment with control was 0.87 (95% CI, 0.54 to 1.42; 5,564 participants, I2=10.6%). No individual studies reported a significant difference between active treatment and control. Among the five studies assessing low birth weight, one (Carey, 2000) compared oral metronidazole with control, three (Guaschino, 2003; Lamont, 2003; McGregor, 1994) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. All five studies were considered good quality. The pooled risk ratio comparing active treatment with control was 1.03 (95% CI, 0.83 to 1.29; 5,377 participants; I2=19.5%). No individual studies reported a significant difference between active treatment and control. Among the three studies assessing very low birth weight, one (Carey, 2000) compared oral metronidazole with control, one (Lamont, 2003) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. All three studies were considered good quality. The pooled risk ratio comparing active treatment with control was 1.05 (95% CI, 0.50 to 2.18; 5,149 participants; I2=48.5%). No individual studies reported a significant difference between active treatment and control. Among the four studies assessing preterm premature rupture of membranes with premature rupture of membranes, one (McDonald, 1997) compared oral metronidazole with control, two (McGregor, 1994; Guaschino, 2003) compared intravaginal clindamycin with control, and one (Subtil, 2018) compared oral clindamycin with control. All four studies were considered good quality. The pooled risk ratio comparing active treatment with control was 1.11 (95% CI, 0.72 to 1.72; 3,568 participants; I2=0%). No individual studies reported a significant difference between active treatment and control.

Appendix G Figure 5 Funnel Plot of Pooled Estimate of Treatment Effect (Absolute Risk Difference) on Preterm Delivery Unstratified by Outcome in General Obstetric Population

Appendix G Figure 5 is titled “Funnel Plot of Pooled Estimate of Treatment Effect (Absolute Risk Difference) on Preterm Delivery at Unstratified by Outcome in General Obstetric Population.” This figure displays a funnel plot of 10 studies reporting preterm delivery. Each study is represented by a dot, plotted against an x-axis that represents the absolute risk difference reported by the study and a y-axis that represents its standard error. Eight of the study dots are within the funnel, while the remaining two fall just on either side of the funnel. This funnel plot does not suggest publication bias.