# Appendix F Additional Results For Diagnostic Test Accuracy (Key Question 2)

Appendix F Figure 1 Summary Receiver Operating Characteristics Curve for Diagnostic Test Accuracy of the BD Affirm VPIII Test

Figure Notes: The 95 percent confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for sensitivity and specificity is similar. The 95 percent prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present. In this example, the prediction region covers nearly one third of the SROC space and is about three times larger relative to the confidence region, suggesting at least moderate heterogeneity beyond what we would expect from chance alone. However, the prediction region is symmetric, suggesting inconsistency in both the sensitivity and specificity estimates.

Abbreviations: AUC=area under the curve; HSROC=hierarchical summary receiver operating characteristic; Sn=sensitivity; Sp=specificity.

Appendix F Figure 1 is titled “Summary Receiver Operating Characteristics Curve for Diagnostic Test Accuracy of the BD Affirm VP III Test.” This figure displays a summary receiver operating characteristic curve that was generated from five studies comparing BD Affirm with a reference test. The area under the curve was 0.91 (95% CI, 0.87 to 0.94). The 95 percent prediction region covered nearly one third of the space, suggesting moderate heterogeneity in the pooled estimates beyond what would be expected because of chance variation. The pooled sensitivity of BD Affirm based on the five studies (2,936 participants) was 0.87 (95% CI, 0.80 to 0.92) and the pooled specificity was 0.81 (95% CI, 0.73 to 0.88). The pooled positive likelihood ratio was 4.6 (95% CI, 3.1 to 6.8), and the pooled negative likelihood ratio was 0.16 (95% CI, 0.11 to 0.26).

Appendix F Figure 2 Forest Plot of Diagnostic Test Accuracy Studies Evaluating the BD Affirm VPIII Test

Abbreviations: CI=confidence interval; GS=Gram stain; NR=not reported; Symp=symptomatic.

Appendix F Figure 2 is titled “Forest Plot of Diagnostic Test Accuracy Studies Evaluating BD Affirm VP III Test.” This figure displays forest plots reporting the sensitivity and specificity of BD Affirm in five studies. Four studies (Cartwright, 2013; Byun, 2016; Briselden, 1994; Witt, 2002) compared BD Affirm with Gram stain using Nugent criteria, while the fifth (Lowe, 2009) compared BD Affirm with complete Amsel’s clinical criteria. One study (Byun, 2016) was considered good quality; the remaining four were considered fair quality. The pooled sensitivity based on the five studies (2,936 participants) was 0.87 (95% CI, 0.80 to 0.92) and the pooled specificity was 0.81 (95% CI, 0.73 to 0.88).

Appendix F Figure 3 Summary Receiver Operating Characteristics Curve for Complete Amsel’s Clinical Criteria Compared With Gram Stain

Figure Notes: The 95 percent confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, the estimate for specificity is more precise than the estimate for sensitivity as indicated by the region being elongated in the vertical direction relative to the horizontal direction. The 95 percent prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region where we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present. In this example, the prediction region covers over one third of the SROC space and is substantially larger relative to the confidence region, suggesting moderate to substantial heterogeneity beyond what we would expect from chance alone..

Abbreviations: AUC=area under the curve; HSROC=hierarchical summary receiver operating characteristic; Sn=sensitivity; Sp=specificity.

Appendix F Figure 3 is titled “Summary Receiver Operating Characteristics Curve for Complete Amsel’s Clinical Criteria Compared With Gram Stain.” This figure displays a summary receiver operating characteristic curve that was generated from 14 studies comparing complete Amsel’s clinical criteria with Gram stain using Nugent criteria. The area under the curve was 0.93 (95% CI, 0.89 to 0.95). The 95 percent prediction region covered more than one third of the SROC space indicating substantial heterogeneity with respect to the estimate of sensitivity and specificity that cannot be explained by chance variation. The pooled sensitivity based on the 14 studies (5,790 participants) was 0.76 (95% CI, 0.63 to 0.85) and the pooled specificity was 0.95 (95% CI, 0.89 to 0.98). The pooled positive likelihood ratio was 14.1 (95% CI, 6.8 to 29.2) and the pooled negative likelihood ratio was 0.26 (95% CI, 0.17 to 0.39).

Appendix F Figure 4 Forest Plot of Diagnostic Test Accuracy Studies Evaluating Complete Amsel’s Clinical Criteria Compared With Gram Stain

Abbreviations: CI=confidence interval; GS=Gram stain; N=number of participants; NR=not reported; Symp=symptomatic.

Appendix F Figure 4 is titled “Forest Plot of Diagnostic Test Accuracy Studies Evaluating Complete Amsel’s Clinical Criteria Compared With Gram Stain.” This figure displays forest plots reporting the sensitivity and specificity of complete Amsel’s clinical criteria compared to Gram stain using Nugent criteria in 14 studies. Three studies (Gratacos, 1999; Hay, 1992; Platz-Christensen 1995) were considered good quality; the other 11 (Bradshaw, 2005; Chen, 2018; Gallo, 2011; Gutman, 2005; Hilmarsdottir, 2006; Landers, 2004; Myziuk, 2003; Schwebke, 1996; Schwebke, 2018; Sha, 2007; Singh, 2013) were considered fair quality. The pooled sensitivity based on the 14 studies (5,790 participants) was 0.76 (95% CI, 0.63 to 0.85) and the pooled specificity was 0.95 (95% CI, 0.89 to 0.98).

Appendix F Figure 5 Summary Receiver Operating Characteristics Curve for Diagnostic Test Accuracy of Modified Amsel’s Clinical Criteria

Figure Notes: The 95 percent confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for specificity is higher compared with the precision of the estimates for sensitivity. The 95 percent prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present. In this example, the prediction region covers only about one fifth of the SROC space and is only somewhat larger than the confidence region, suggesting no more than a small amount of heterogeneity beyond what we would expect from chance alone. However, the region it spans implies that a future study with high sensitivity/low specificity is equally likely as a study with low sensitivity/high specificity.

Abbreviations: HSROC=hierarchical summary receiver operating characteristic; Sn=sensitivity; Sp=specificity.

Appendix F Figure 5 is titled “Summary Receiver Operating Characteristics Curve for Diagnostic Test Accuracy of Modified Amsel’s Clinical Criteria.” This figure displays a summary receiver operating characteristic curve that was generated from four studies comparing modified Amsel’s clinical criteria with Gram stain using Nugent criteria. The 95 percent prediction region covers about one fifth of the SROC space, but its shape suggests at least moderate heterogeneity. The pooled sensitivity of modified Amsel’s clinical criteria based on the four studies (2,477 participants) was 0.67 (95% CI, 0.54 to 0.78) and the pooled specificity was 0.96 (95% CI, 0.93 to 0.98). The pooled positive likelihood ratio was 17.3 (95% CI, 10.4 to 28.8) and the pooled negative likelihood ratio was 0.34 (95% CI, 0.24 to 0.48).

Appendix F Figure 6 Forest Plot of Diagnostic Test Accuracy Studies Evaluating Modified Amsel’s Clinical Criteria

Abbreviations: CI=confidence interval; GS=Gram stain; N=Number of participants; NR=not reported; Symp=symptomatic.

Appendix F Figure 6 is titled “Forest Plot of Diagnostic Test Accuracy Studies Evaluating Modified Amsel’s Clinical Criteria.” This figure displays forest plots reporting the sensitivity and specificity of modified Amsel’s clinical criteria compared with Gram stain using Nugent criteria in four studies. One study (Gratacos, 1999) was considered good quality; the remaining three (Mastrobattista, 2000; Schwebke, 1996; Schwebke, 2018) were considered fair quality. The pooled sensitivity based on the four studies (2,477 participants) was 0.67 (95% CI, 0.54 to 0.78) and the pooled specificity was 0.96 (95% CI, 0.93 to 0.98).