# Appendix E Assessment of Study Quality

Appendix E Table 1 Study Quality Ratings for Diagnostic Accuracy Studies: Part 1

Study Author (Year) | Overall Study Quality | Comments
Bradshaw et al (2005)^100^ | Fair | Unclear whether consecutive or random sample was enrolled, no information about masking of index and referent tests, exclusion of some participants with intermediate flora from analyses
Briselden et al (1994)^96^ | Fair | No information about whether a consecutive or random sample was enrolled
Byun et al (2016)^90^ | Good | None
Cartwright et al (2013)^95^ | Fair | Some concerns for bias due to selection of patients, spectrum bias (all symptomatic), and lack of information about masking of index and referent tests
Chen et al (2018)^110^ | Fair | No information about whether consecutive or random enrollment used and whether testers were blinded to results of index and reference tests
Gallos et al (2011)^103^ | Fair | Unclear whether enrollment was consecutive or random; also the analysis was done at the visit level (not participant level) with each participant contributing up to 10 visits; thus, the observations are not independent of each other and the authors have not accounted for this in their analysis
Gratacos et al (1999)^88^ | Good | None
Gutman et al (2005)^109^ | Fair | Unclear whether patients were consecutively or randomly enrolled and whether referent test was interpreted without knowledge of index test
Hay et al (1992)^91^ | Good | None
Hellberg et al (2001)^93^ | Good | None
Hillier et al (2011)^101^ | Fair | Unclear method of sample enrollment; no information about masking of index and referent test results
Hilmarsdottir et al (2006)^104^ | Fair | Unclear whether consecutive or random sample used, does not provide information on scoring of index test, only provides information on number analyzed so do not know how many were eligible or enrolled but had missing data
Landers et al (2004)^105^ | Fair | Unclear whether consecutive or random sample enrollment used, masking of test results not reported
Lin et al (2002)^201^ | Poor | In addition to high concerns for bias in patient selection and index test performance, the analysis does not use patients as the unit of analysis; it uses “slides,” each patient contributed two sets of slides (an original and a duplicate) that were read multiple times by technicians and each “read” contributed a data point to the analysis
Lowe et al (2009)^97^ | Fair | Unclear whether consecutive or random sample enrollment used, unclear criteria for positive referent test
Mastrobattista et al (2000)^89^ | Fair | Unclear whether consecutive or random sample enrollment used, no reporting of whether referent and index test results were masked
Myziuk et al (2003)^102^ | Fair | Unclear risk of bias in patient selection, index test, and reference test domains
Platz-Christensen et al (1995)^92^ | Good | Uses Spiegel’s criteria for referent test on Gram stain
Rouse et al (2009)^136^ | Fair (pH and clue cells) Poor (whiff and modified Amsel’s clinical criteria) | Unclear risk of bias in patient selection and reference test domains for pH and clue cells, high level of missing data for “whiff” test and modified Amsel’s clinical criteria resulting in high concern for bias for those two tests
Schmidt et al (1994)^94^ | Good | None
Schwebke et al (1996)^108^ | Fair | Unclear risk of bias in some domains, including patient selection and masking of index test results
Schwebke (2018)^99^; Gaydos (2017)^65^ | Fair | Effect of excluding participants with intermediate Nugent scores from the analysis is unclear
Sha et al (2007)^106^ | Fair | Unclear whether used consecutive or random enrollment; no indication that results of index and referent test were masked; also the analysis was done at the visit level (not participant level) with each participant contributing multiple observations; thus, the observations are not independent of each other and the authors have not accounted for this in their analysis
Singh et al (2013)^107^ | Fair | Unclear risk of bias due to patient selection and reference test (lack of information about masking)
Sonnex et al (1995)^137^ | Fair | No information about method of enrollment and no indication that index and referent tests were masked
Witt et al (2002)^98^ | Fair | Unclear whether consecutive or random sample were enrolled, unclear whether results of index and referent test were masked

Abbreviation: pH=logarithmic scale used to specify the acidity or basicity of an aqueous solution.

Appendix E Table 2 Study Quality Ratings for Diagnostic Accuracy Studies: Part 2

Study Author(s) (Year(s)) | Consider Patients Evaluated (prior testing, presentation, intended use of index test and setting). Is there concern that the included patients do not match the review question? | Consider Index Test. Is there concern that the index test, its conduct, or interpretation differ from the review question? | Consider Reference Test. Is there concern that the target condition as defined by the reference standard does not match the review question?
Bradshaw et al (2005)^100^ | Low | Low | Low
Briselden et al (1994)^96^ | Low | Low | Low
Byun et al (2016)^90^ | Unclear | Low | Low
Cartwright et al (2013)^95^ | Unclear | Low | Low
Chen et al (2018)^110^ | Low | Low | Low
Gallos et al (2011)^103^ | High | Low | Low
Gratacos et al (1999)^88^ | Low | Low | Low
Gutman et al (2005)^109^ | Low | Low | Low
Hay et al (1992)^91^ | Low | Low | Unclear
Hellberg et al (2001)^93^ | Unclear | Unclear | Unclear
Hillier et al (2011)^101^ | Low | Low | Low
Hilmarsdottir et al (2006)^104^ | Unclear | Low | Low
Landers et al (2004)^105^ | Low | Low | Low
Lin et al (2002)^201^ | Unclear | Unclear | Low
Lowe et al (2009)^97^ | Low | Low | Low
Mastrobattista et al (2000)^89^ | Low | Low | Low
Myziuk et al (2003)^102^ | Low | Low | Low
Platz-Christensen et al (1995)^92^ | Low | Low | Low
Rouse et al (2009)^136^ | Low | Low | Low
Schmidt et al (1994)^94^ | Low | Low | Low
Schwebke et al (1996)^108^ | Low | Low | Low
Schwebke (2018)^99^; Gaydos (2017)^65^ | Unclear | Low | Low
Sha et al (2007)^106^ | Unclear | Low | Low
Singh et al (2013)^107^ | Low | Low | Low
Sonnex et al (1995)^137^ | Low | Low | Low
Witt et al (2002)^98^ | Low | Low | Low

Appendix E Table 3 Study Quality Ratings for Diagnostic Accuracy Studies: Part 3

Study Author(s) (Year(s)) | Was a consecutive or random sample of patients enrolled? | Was a case-control design avoided? | Did the study avoid inappropriate exclusions? | Could the selection of patients have introduced bias? | Comments
Bradshaw et al (2005)^100^ | Unclear | Yes | Yes | Unclear | Unclear whether a consecutive or random sample was enrolled
Briselden et al (1994)^96^ | Unclear | Yes | Yes | Unclear | No information about whether a consecutive or random sample was enrolled
Byun et al (2016)^90^ | Unclear | Yes | Yes | Low | None
Cartwright et al (2013)^95^ | Unclear | Yes | Yes | Unclear | Study cites another paper for details of the study population, the other paper describes the study population as deidentified samples. This paper describes study population as women with clinically documented vaginitis, but unclear whether a consecutive or random sample was used
Chen et al (2018)^110^ | Unclear | Yes | Yes | Unclear | Unclear whether a consecutive or random sample of patients was enrolled
Gallos et al (2011)^103^ | Unclear | Yes | Yes | Unclear | Unclear whether a consecutive or random sample of patients was enrolled
Gratacos et al (1999)^88^ | Yes | Yes | Yes | Low | None
Gutman et al (2005)^109^ | Unclear | Yes | Yes | Unclear | Not clear how many patients were eligible and no mention of consecutive or random sample being enrolled
Hay et al (1992)^91^ | Yes | Yes | Yes | Low | None
Hellberg et al (2001)^93^ | Yes | Yes | Unclear | Low | Cites another paper for detailed study enrollment criteria; the cited paper verifies that consecutive enrollment was used
Hillier et al (2011)^101^ | Unclear | Yes | Yes | Unclear | Unclear how sample was enrolled
Hilmarsdottir et al (2006)^104^ | Unclear | Yes | Unclear | Unclear | No information about study inclusion/exclusion criteria or method of recruitment/enrollment
Landers et al (2004)^105^ | Unclear | Yes | Yes | Unclear | Unclear whether consecutive or random enrollment used
Lin et al (2002)^201^ | No | No | Unclear | High | Study used a case-control design with no information about inclusion/exclusion criteria
Lowe et al (2009)^97^ | Unclear | Yes | Yes | Unclear | Unclear whether a consecutive or random sample of women were enrolled
Mastrobattista et al (2000)^89^ | Unclear | Yes | Yes | Unclear | Unclear whether consecutive or random sample enrollment was used
Myziuk et al (2003)^102^ | Unclear | Yes | Unclear | Unclear | Unclear whether a consecutive or random sample of patients were enrolled
Platz-Christensen et al (1995)^92^ | Yes | Yes | Yes | Low | None
Rouse et al (2009)^136^ | Unclear | Yes | Unclear | Unclear | No information about study inclusion/exclusion criteria or how subjects were enrolled (i.e., consecutively or randomly)
Schmidt et al (1994)^94^ | Yes | Yes | Yes | Low | None
Schwebke et al (1996)^108^ | Unclear | Yes | Unclear | Unclear | No information provided regarding how patients were identified for enrollment or study inclusion/exclusion criteria
Schwebke (2018)^99^; Gaydos (2017)^65^ | Yes | Yes | Yes | Low | None
Sha et al (2007)^106^ | Unclear | Yes | Unclear | Unclear | Review of cited study confirms enrollment methods
Singh et al (2013)^107^ | Unclear | Yes | Yes | Unclear | No information about whether participants were consecutively or randomly enrolled
Sonnex et al (1995)^137^ | Unclear | Yes | Unclear | Unclear | No information on whether a consecutive or random sample was enrolled, no information about study inclusion or exclusion criteria
Witt et al (2002)^98^ | Unclear | Yes | Unclear | Unclear | Unclear whether consecutive or random sample was enrolled, very little information about participant inclusion and exclusion criteria

Appendix E Table 4 Study Quality Ratings for Diagnostic Accuracy Studies: Part 4

Study Author(s) (Year(s)) | Were the index test results interpreted without knowledge of the results of the reference standard? | If a threshold was used, was it pre-specified? | Could the conduct or interpretation of the index test have introduced bias? | Comments
Bradshaw et al (2005)^100^ | Unclear | Yes | Unclear | Masking of referent test results NR
Briselden et al (1994)^96^ | Yes | Yes | Low | Although not explicitly stated, it appears that separate personnel performed the index and referent tests
Byun et al (2016)^90^ | Yes | Yes | Low | None
Cartwright et al (2013)^95^ | Unclear | Yes | Unclear | No information as to whether index tests were interpreted without knowledge of referent test
Chen et al (2018)^110^ | Unclear | Yes | Unclear | No information provided
Gallos et al (2011)^103^ | Yes | Yes | Low | Although not explicitly stated that clinicians were masked to results of index tests, slides for Gram stains were shipped to a central laboratory so it would not have been possible for them to have been aware of the results at the time that the clinical assessment of BV was made
Gratacos et al (1999)^88^ | Yes | Yes | Low | None
Gutman et al (2005)^109^ | Yes | Yes | Low | Because reference tests were sent to outside lab for interpretation, the examiners could not have been aware of the results
Hay et al (1992)^91^ | Yes | Yes | Low | The referent tests were all done in a single batch at the end of the study such that the examiners performing the index test could not have been aware of the results
Hellberg et al (2001)^93^ | No | Yes | Low | The index tests here are components of the referent test that was used; thus, it would be impossible to not have knowledge of both test results at the same time, but the index tests would have to have been conducted first before determining the referent test
Hillier et al (2011)^101^ | Unclear | Yes | Unclear | No information about masking of test results
Hilmarsdottir et al (2006)^104^ | Yes | Unclear | Low | Have to assume that they required 3 of 4 Amsel’s clinical criteria to be positive for a positive overall test
Landers et al (2004)^105^ | Unclear | Yes | Unclear | Index text results not reported as masked
Lin et al (2002)^201^ | Unclear | Unclear | High | No information is provided regarding how the index test was performed or interpreted
Lowe et al (2009)^97^ | Yes | Yes | Low | None
Mastrobattista et al (2000)^89^ | Unclear | Yes | Unclear | Unclear whether index tests were masked
Myziuk et al (2003)^102^ | Unclear | Yes | Unclear | No information about whether persons performing Amsel’s clinical criteria were masked to results of Gram stain, but since Gram stains often go to laboratory to be performed after clinic visit, it is unlikely the clinicians would have had those results. It is also not clear where BVBLUE was performed (in clinic vs. laboratory) or whether persons performing BVBLUE were masked to the other index and referent test results
Platz-Christensen et al (1995)^92^ | Yes | Yes | Low | Not explicitly reported that results were masked but can be inferred by the description of who and where test was performed
Rouse et al (2009)^136^ | Yes | Yes | Low | None
Schmidt et al (1994)^94^ | Unclear | Yes | Low | Index test is a component of the referent test and would be performed before the referent test score could be calculated
Schwebke et al (1996)^108^ | Yes | Yes | Low | Not explicitly stated, but since Gram stains were sent to central laboratory it is unlikely clinicians would have access to the results
Schwebke (2018)^99^; Gaydos (2017)^65^ | Yes | Yes | Low | None
Sha et al (2007)^106^ | Unclear | Yes | Unclear | No information about masking of results
Singh et al (2013)^107^ | Yes | Yes | Low | Gram stain sent to off-site laboratory for testing so would not have been available to examining clinician performing the index test
Sonnex et al (1995)^137^ | Unclear | Yes | Unclear | No information about masking of index test results and seems unlikely given only one study author
Witt et al (2002)^98^ | Unclear | Yes | Unclear | Unclear whether results of index test were masked

Abbreviations: BV=bacterial vaginosis; NR=not reported.

Appendix E Table 5 Study Quality Ratings for Diagnostic Accuracy Studies: Part 5

Study Author(s) (Year(s)) | Is the reference standard likely to correctly classify the target condition? | Were the reference standard results interpreted without knowledge of the results of the index test? | Could the reference standard, its conduct, or its interpretation have introduced bias? | Comments
Bradshaw et al (2005)^100^ | Yes | Unclear | Unclear | Masking of index text results NR
Briselden et al (1994)^96^ | Yes | Yes | Low | None
Byun et al (2016)^90^ | Yes | Yes | Low | None
Cartwright et al (2013)^95^ | Yes | Unclear | Unclear | No information as to whether referent tests were interpreted without knowledge of index test; reference standard considers intermediate flora on Nugent’s criteria as positive if also had positive Amsel’s clinical criteria
Chen et al (2018)^110^ | Yes | Unclear | Unclear | No information provided
Gallos et al (2011)^103^ | Yes | Yes | Low | None
Gratacos et al (1999)^88^ | Yes | Yes | Low | None
Gutman et al (2005)^109^ | Yes | Unclear | Unclear | Unclear whether referent test was interpreted without knowledge of index test diagnosis
Hay et al (1992)^91^ | Yes | Yes | Low | Reference standard is Spiegel’s criteria
Hellberg et al (2001)^93^ | Yes | No | Low | The index tests here are components of the referent test that was used; thus, it would be impossible to not have knowledge of both test results, but the index tests would have to have been conducted first before determining the referent test
Hillier et al (2011)^101^ | Yes | Unclear | Unclear | No information about masking of test results
Hilmarsdottir et al (2006)^104^ | Yes | Yes | Low | None
Landers et al (2004)^105^ | Yes | Unclear | Unclear | Referent test results not reported as masked
Lin et al (2002)^201^ | Yes | Unclear | Unclear | Unclear whether technicians who interpreted the Gram stain slides were masked to results of index test
Lowe et al (2009)^97^ | Unclear | Yes | Unclear | The explicit criteria used to make clinical diagnosis are not stated
Mastrobattista et al (2000)^89^ | Yes | Unclear | Unclear | Unclear whether referent tests were masked
Myziuk et al (2003)^102^ | Yes | Unclear | Unclear | No information as to whether laboratory staff were masked to results of either index tests
Platz-Christensen et al (1995)^92^ | Unclear | Yes | Low | Somewhat unclear whether Gram stain based on Spiegel’s criteria is diagnostic for BV
Rouse et al (2009)^136^ | Yes | Unclear | Unclear | Unclear whether microbiology laboratory had results of index test
Schmidt et al (1994)^94^ | Yes | No | Low | Referent test is composed of index test components, so not possible to mask
Schwebke et al (1996)^108^ | Yes | Unclear | Unclear | No explicit mention that the central laboratory was masked to results of index test
Schwebke (2018)^99^; Gaydos (2017)^65^ | Yes | Yes | Low | None
Sha et al (2007)^106^ | Yes | Unclear | Unclear | No information about masking of results
Singh et al (2013)^107^ | Yes | Unclear | Unclear | No information about whether off-site laboratory personnel were masked to results of the index tests
Sonnex et al (1995)^137^ | Yes | Unclear | Unclear | No information about masking of referent test results and seems unlikely given only one study author
Witt et al (2002)^98^ | Yes | Unclear | Unclear | Unclear whether results of index test were masked

Abbreviations: BV=bacterial vaginosis; NR=not reported.

Appendix E Table 6 Study Quality Ratings for Diagnostic Accuracy Studies: Part 6

Study Author(s) (Year(s)) | Describe any patients who did not receive the index test(s) and/or reference standard or who were excluded | Describe the time interval and any interventions between index test(s) and reference standard | Was there an appropriate interval between index test(s) and reference standard? | Did all patients receive a reference standard? | Did patients receive the same reference standard? | Were nearly all patients (>80%) included in the analysis? | Could the patient flow have introduced bias? | Comments
Bradshaw et al (2005)^100^ | Study reports data for all 288, although unclear how many were eligible and enrolled but did not have available data. Participants with intermediate flora were excluded from some analyses. | Concurrent collection | Yes | Yes | Yes | Yes | Unclear | Effect of excluding participants with intermediate flora from some analysis unknown
Briselden et al (1994)^96^ | Appears that all women who enrolled had data available for the BV analysis. | Concurrent collection | Yes | Yes | Yes | Unclear | Low | None
Byun et al (2016)^90^ | 5 patients were excluded because of inadequate sample quality. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Cartwright et al (2013)^95^ | 18/323 (5.6%) were excluded for missing data (1) or indeterminate results on the BV-PCR (17), which is not a test of interest to this review. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Chen et al (2018)^110^ | None mentioned. | Concurrent collection | Yes | Yes | Yes | Unclear | Low | No information about eligible sample and sample analyzed
Gallos et al (2011)^103^ | Data were available for 1283/1310 (97.9%) of participants that were enrolled. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Gratacos et al (1999)^88^ | NR | Concurrent collection | Yes | Yes | Yes | Unclear | Low | The number of potentially eligible but not enrolled participants is NR
Gutman et al (2005)^109^ | NR | Concurrent collection | Yes | Yes | Yes | Yes | Low | The number of potential eligible but not enrolled participants is NR
Hay et al (1992)^91^ | 4 patients were excluded after enrollment because of heavy bleeding. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Hellberg et al (2001)^93^ | 55 (5.4%) of patients were excluded for missing records. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Hillier et al (2011)^101^ | None | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Hilmarsdottir et al (2006)^104^ | NR | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Landers et al (2004)^105^ | 50 participants were excluded from analysis for reasons not reported. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Lin et al (2002)^201^ | NR | Unclear timing, presumably concurrent collection. | Yes | Yes | Yes | Unclear | Low | None
Lowe et al (2009)^97^ | 12 women were excluded for incomplete data. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Mastrobattista et al (2000)^89^ | 2 patients were excluded for poor-quality specimens. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Myziuk et al (2003)^102^ | NR | Concurrent collection | Yes | Yes | Yes | Unclear | Low | Study does not report the number eligible, for which data were missing or not available. It only reports number analyzed
Platz-Christensen et al (1995)^92^ | None were reported as excluded, although unclear how many were eligible and tested but were not included in analysis. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Rouse et al (2009)^136^ | Missing Gram stain samples for 27/220 (12.2%) participants overall, missing pH test for 4/193 participants with Gram stain, missing whiff test for 83/193 (57%) participants with Gram stain | Concurrent collection | Yes | Yes | Yes for pH and clue cells alone, no for whiff test and modified Amsel’s clinical criteria | Yes | Low for pH and clue cells, high for whiff test and modified Amsel’s | High level of missing data for whiff test and modified Amsel’s clinical criteria
Schmidt et al (1994)^94^ | 8 excluded for missing data. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Schwebke et al (1996)^108^ | NR | Concurrent collection | Yes | Yes | Yes | Unclear | Low | The number of enrolled women without data to analyze is not presented, so unclear whether the number analyzed is similar to the number enrolled
Schwebke (2018)^99^; Gaydos (2017)^65^ | Out of 1,740 eligible participants, 63 were removed due to specimens without evaluable results, 126 were removed due to not compliant reference test or not compliant/indeterminate/failed BD Max test, and 213 were removed due to intermediate reference test (Gram stain score 4 to 6). | Concurrent | Yes | Yes | Yes | Yes | Unclear | 189 (10.9%) participants were excluded from all analyses because they had an intermediate reference test (Gram stain) or not compliant/indeterminate/failed index test (BD Max)
Sha et al (2007)^106^ | Women who seroconverted during the study (N=16) were excluded from the analysis; the analysis was done at the visit level, not patient level. | Concurrent collection | Yes | Yes | Yes | Unclear | Unclear | Because analysis is at the visit level, unclear whether nearly all patients are included over time and patients can contribute more than one visit to the data
Singh et al (2013)^107^ | Three participants excluded for missing data. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None
Sonnex et al (1995)^137^ | No information | Concurrent collection | Yes | Yes | Yes | Unclear | Low | Unclear whether study had any women enrolled who were not analyzed
Witt et al (2002)^98^ | The study authors excluded the participants with intermediate flora from their analysis. Data were provided and we are able to calculate the sensitivity and specificity with these participants included. | Concurrent collection | Yes | Yes | Yes | Yes | Low | None

Abbreviations: BV=bacterial vaginosis; NA=not applicable; NR=not reported; PCR=polymerase chain reaction; pH=logarithmic scale used to specify the acidity or basicity of an aqueous solution.

Appendix E Table 7 Study Quality Ratings for Randomized, Controlled Trials: Part 1

Study Author (Year) | Overall Study Quality Rating | Overall Rationale for Study Quality Rating
Cary et al (2000)^111^ | Good | None
Guaschino et al (2003)^112^ | Good | None
Hauth et al (1995)^121^ | Fair | Using data from a subgroup analysis that was not prespecified
Kekki et al (2001)^113^ | Good | None
Kiss et al (2004)^114^ | Fair | Some concerns for bias because of the lack of participant and caregiver masking to treatment assignment and because the subgroup analysis of women with BV was not prespecified
Lamont et al (2003)^115^ | Good | None
Larsson et al (2006)^116^ | Fair | Some concerns for bias over lack of information regarding allocation concealment; also participants and caregivers in treatment group were not masked to treatment allocation
McDonald et al (1997)^117^ | Good | None
McGregor et al (1994)^118^ | Fair | Some concerns for bias because of lack of information about allocation concealment and no data to assess baseline characteristics to ensure adequate randomization
Morales et al (1994)^122^ | Fair | Some concerns for bias because did not use intent to treat analysis; 6 patients were excluded for failure to complete assigned treatment, and three patients were excluded for receiving antibiotic treatment for other conditions
Subtil et al (2018)^119^ | Good | None
Ugwumadu et al (2003)^120^ | Good | Low for the main study results among women with both intermediate flora and bacterial vaginosis; some concerns for the findings in the subgroup of participants with BV
Vermeulen et al (1999)^123^ | Good | None

Abbreviations: BV=bacterial vaginosis.

Appendix E Table 8 Study Quality Ratings for Randomized, Controlled Trials: Part 2

Study Author (Year) | Was the allocation sequence random? | Was allocation sequence concealed until participants were recruited and assigned to interventions? | Were there baseline imbalances that suggest a problem with the randomization process? | Bias arising from randomization or selection? | Comments
Cary et al (2000)^111^ | Yes | No information | No | Some concerns | No information on method of randomization and no information about allocation concealment
Guaschino et al (2003)^112^ | Probably yes | Yes | Probably no | Low | None
Hauth et al (1995)^121^ | Yes | Yes | No | Low | None
Kekki et al (2001)^113^ | Probably yes | Yes | No information | Low | None
Kiss et al (2004)^114^ | Yes | Probably yes | No | Low | Participants not selected based on BV status, but similar proportion of patients with BV in both the intervention and control groups
Lamont et al (2003)^115^ | Yes | Yes | No | Low | None
Larsson et al (2006)^116^ | Yes | No information | No | Some concerns | No information about allocation concealment
McDonald et al (1997)^117^ | Yes | Yes | Probably no | Low | The placebo group contained 14% of study population younger than age 20 years compared with only 6% in intervention group
McGregor et al (1994)^118^ | Probably yes | No information | No information | Some concerns | Some concerns for bias, as no information about allocation concealment and no data on baseline characteristics to assess balance between groups
Morales et al (1994)^122^ | Yes | Probably yes | Probably no | Low | Higher proportion of patients with more than 1 prior PTD in metronidazole group (22/44 [50%] vs. 14/36 [38%]) although this difference was reported as NS
Subtil et al (2018)^119^ | Yes | Yes | No | Low | None
Ugwumadu et al (2003)^120^ | Yes | Yes | No | Low | None
Vermeulen et al (1999)^123^ | Probably yes | Probably yes | No | Low | The article does say that randomization (which was for women with prior PTD) was stratified by center and by BV status. No further details are given, but this suggests that the subgroup analysis by BV status was preplanned.

Abbreviations: BV=bacterial vaginosis; PTD=preterm delivery; NS=not sufficient.

Appendix E Table 9 Study Quality Ratings for Randomized, Controlled Trials: Part 3

Study Author(s) (Year) | Were the participants aware of their assigned intervention? | Were carers and trial personnel aware of participants’ assigned intervention? | Were there deviations from the intended intervention beyond what would be expected in usual practice? | Were these deviations unbalanced between groups and likely to have affected the outcome? | Were any participants analyzed in a group different from the one they were assigned? | Was there potential for a substantial impact of analyzing participants in the wrong group? | Bias arising from deviations from intended interventions? | Comments
Cary et al (2000)^111^ | No | No | NA | NA | No | NA | Low | None
Guaschino et al (2003)^112^ | Yes | No information | No information | NA | No | NA | Low | Treatment was not masked, introducing some concerns for bias because of differential awareness for symptoms or care that occurred as a result of knowing treatment assignment, but this would largely only be applicable to intermediate outcomes and not to delivery or birth weight outcomes.
Hauth et al (1995)^121^ | No | No | NA | NA | No | NA | Low | None
Kekki et al (2001)^113^ | No | No | NA | NA | No | NA | Low | None
Kiss et al (2004)^114^ | Yes | Yes | Probably no | NA | No | NA | Some concerns | Control group was not placebo controlled; only the intervention group was aware of their group assignment.
Lamont et al (2003)^115^ | No | No | NA | NA | No | NA | Low | None
Larsson et al (2006)^116^ | Yes | Yes | Probably no | NA | No | NA | Some concerns | Only participants and clinicians of participants in the treatment group were aware of diagnosis and treatment assignment. Participants in intervention group were not blinded to treatment allocation; control group did not receive placebo.
McDonald et al (1997)^117^ | No | No | NA | NA | No | NA | Low | None
McGregor et al (1994)^118^ | No | No | NA | NA | No | NA | Low | None
Morales et al (1994)^122^ | No | No | NA | NA | No | NA | Low | None
Subtil et al (2018)^119^ | No | No | NA | NA | No | NA | Lo | None
Ugwumadu et al (2003)^120^ | No | No | NA | NA | No | NA | Low | None
Vermeulen et al (1999)^123^ | No | No | NA | NA | No | NA | Low | None

Abbreviations: NA=not applicable.

Appendix E Table 10 Study Quality Ratings for Randomized, Controlled Trials: Part 4

Study Author(s) (Year) | Were outcome data available for all, or nearly all, participants randomized? | Are the proportions of missing outcome data and reasons for missing outcome data similar across intervention groups? | Is there evidence that results were robust to the presence of missing outcome data? | Bias arising from missing outcome data? | Comments
Cary et al (2000)^111^ | Yes | NA | NA | Low | 1,757/1,953 (90.0%) returned for followup visit and 1,919/1,953 (98.2%) had outcome data available
Guaschino et al (2003)^112^ | Yes | NA | NA | Low | No treatment group: Data for followup 51/57 (89.5%) Clindamycin group: Data for followup 49/55 (89.1%)
Hauth et al (1995)^121^ | Yes | NA | NA | Low | 616/624 (98.7%) had followup data
Kekki et al (2001)^113^ | Yes | NA | NA | Low | BV clearance outcome G1: 90.4% followup G2: 90.9% followup Preterm delivery G1: 100% G2: 100%
Kiss et al (2004)^114^ | Yes | NA | NA | Low | 4,155/4,492 (93.8%) completed the study
Lamont et al (2003)^115^ | Yes | NA | NA | Low | Pregnancy outcomes: Placebo: 201/201 (100%) Clindamycin: 208/208 (100%) Visit 2 followup for repeat Gram stain Placebo: 190/201 (95%) Clindamycin: 178/208 (86%)
Larsson et al (2006)^116^ | Yes | NA | NA | Low | 8,791/9,025 (97.4%)
McDonald et al (1997)^117^ | Yes | NA | NA | Low | 429/439 (97.7%) in treatment group; 428/440 (97.2%) in placebo group
McGregor et al (1994)^118^ | Yes | NA | NA | Low | Overall followup available for 129/142 (90.8%) of participants. Data by group not provided to assess differential attrition
Morales et al (1994)^122^ | No | Unclear | No | Some concerns | Data available for 80/94 (85%) of participants who were enrolled. Five participants were lost to followup. However, authors also excluded 6 participants who did not complete treatment and 3 participants who received antibiotics for other reasons, and authors do not report to which group these participants were allocated, thus violating the intent to treat principle.
Subtil et al (2018)^119^ | Yes | NA | NA | Low | 941/943 (99.8%) in treatment group; 963/968 (99.5%) in placebo group
Ugwumadu et al (2003)^120^ | Yes | NA | NA | Low | 244/249 (98%) in the treatment group and 241/245 (98%) in the placebo group
Vermeulen et al (1999)^123^ | Yes | NA | NA | Low | Data for all enrolled participants in both groups were available

Abbreviations: BV=bacterial vaginosis; G=group; NA=not applicable.

Appendix E Table 11 Study Quality Ratings for Randomized, Controlled Trials: Part 5

Study Author(s) (Year(s)) | Were outcome assessors aware of the intervention received by study participants? | Was the assessment of the outcome likely to be influenced by knowledge of intervention received? | Were the outcomes measured in the same manner for all individuals (equal), in a way that accurately reflects the outcome (valid), and in reproducible manner (reliable)? | Bias arising from measurement of the outcome? | Comments
Cary et al (2000)^111^ | No information | Probably no | Yes | Low | None
Guaschino et al (2003)^112^ | No information | No | Yes | Low | None
Hauth et al (1995)^121^ | No | NA | Yes | Low | None
Kekki et al (2001)^113^ | Probably no | NA | Yes | Low | Outcome assessors for BV clearance were masked, but it is unclear whether outcome assessors for preterm delivery were masked
Kiss et al (2004)^114^ | No information | Probably no | Yes | Low | None
Lamont et al (2003)^115^ | No information | No | Yes | Low | None
Larsson et al (2006)^116^ | No information | Probably no | Yes | Low | None
McDonald et al (1997)^117^ | No | NA | Yes | Low | None
McGregor et al (1994)^118^ | No information | No | Yes | Low | None
Morales et al (1994)^122^ | NI | Probably no | Yes | Low | None
Subtil et al (2018)^119^ | No | NA | Yes | Low | None.
Ugwumadu et al (2003)^120^ | NI | No | Yes | Low | None
Vermeulen et al (1999)^123^ | NI | Probably no | Probably yes | Low | None

Abbreviations: BV=bacterial vaginosis; NA=not applicable; NI=no information.

Appendix E Table 12 Study Quality Ratings for Randomized, Controlled Trials: Part 6

Study Author(s) (Year(s)) | Are the reported outcome data likely to have been selected on the basis of results from multiple outcome measurements within the outcome domain? | Are the reported outcome data likely to have been selected on the basis of results from multiple analyses of the data? | Bias arising from selection of reported results? | Comments
Cary (2000)^111^ | No | No | Low | None
Guaschino (2003)^112^ | No | No | Low | None
Hauth (1995)^121^ | No | Yes | Some concerns | We are using data from a subgroup analysis of results stratified by BV status. This was not a prespecified subgroup, and no information on whether treatment and control groups of women who were BV positive were similar at baseline.
Kekki (2001)^113^ | No | No | Low | None
Kiss (2004)^114^ | No | Yes | Some concerns | We are using data from a subgroup analysis of women with BV; this was not a prespecified subgroup analysis.
Lamont (2003)^115^ | No | No | Low | None
Larsson (2006)^116^ | No | No | Low | None
McDonald (1997)^117^ | No | No | Low | None
McGregor (1994)^118^ | No | No | Low | None
Morales (1994)^122^ | Probably no | No | Low | None
Subtil (2018)^119^ | Probably no | Probably no | Low | The primary outcome was a composite outcome, but our review is more interested in the individual secondary outcomes.
Ugwumadu (2003)^120^ | Probably no | No | Low | The study population included 15.7% of participants with intermediate vaginal flora. However, authors report data in a way that allows us to limit our results to only women with a Nugent score >7; thus, we are technically reporting on a post hoc subgroup analysis.
Vermeulen (1999)^123^ | Probably yes | Probably yes | Low | The authors provide outcomes for the entire enrolled population (intention to treat) and also for completers. We are reporting results from the subgroup analysis in women with BV; randomization was stratified by both center and BV status, suggesting it was preplanned.

Abbreviation: BV=bacterial vaginosis.

Appendix E Table 13 Study Quality Ratings for Controlled Cohort Studies: Part 1

Study Author(s) (Year(s)) | Overall Quality Rating | Overall Rationale for Quality Rating
Diav-Citrin et al (2001)^129^ | Poor | Authors did not address potential confounding, high degree of missing data in both the exposed and control groups
Sorensen et al (1999)^130^ | Fair | Authors did not fully address confounding; some bias from lack of information about how outcome was defined
Thapa et al (1998)^132^ | Fair | Some baseline imbalances between groups and potential for residual confounding

Appendix E Table 14 Study Quality Ratings for Controlled Cohort Studies: Part 2

Study Author(s) (Year(s)) | Is there potential for con-founding of the effect of interven-tion? | Was the analysis based on splitting participants’ follow up time according to intervention? | Were intervention discon-tinuations or switches likely related to factors prognostic for the outcome? | Did the authors use appropriate analyses method that controlled for all the important con-founding domains? | Were con-founding domains measured validly and reliably by the variables available? | Did the authors control for any post-intervention variables that could have been affected by the intervention? | Did the authors use appropriate analyses that adjusted for all important confounding domains and time varying confounding? | Were con-founding domains adjusted for measured validly and reliably by the variables available? | Overall bias due to con-founding | Comments
Diav-Citrin et al (2001)^129^ | Yes | No | NA | No | NA | No | No | No | High | No adjusted analyses performed, no reporting that confounding variables were measured. Exposure to other teratogens not assessed. Larger percentage of women who had abortions in the exposed group.
Sorensen et al (1999)^130^ | Yes | No | NA | Probably no | NA | No information | Probably no | Probably yes | Some concerns | Adjusted for smoking, birth order, and maternal age; did not assess exposure to other teratogens in either group.
Thapa et al (1998)^132^ | Yes | No | NA | Probably yes | Probably yes | No | No | Probably yes | Some concerns | Analysis adjusted for some demographic variables, but no data presented on carcinogenic exposures between groups; also trimester of enrollment in Medicaid was very different between groups, suggesting differences in access to health care and/or difference in socioeconomic characteristics between groups.

Abbreviation: NA=not applicable.

Appendix E Table 15 Study Quality Ratings for Controlled Cohort Studies: Part 3

Study Author(s) (Year(s)) | Was selection of participants into the study based on participant characteristics observed after the start of intervention? | Were the post-intervention variables that influenced selection likely associated with the intervention? | Were the post-intervention variables that influenced selection likely influenced by the outcome or a cause of the outcome? | Do start of followup and start of intervention coincide for most participants? | Were adjustment techniques used that likely correct for selection biases? | Overall bias in selection of participants into the study | Comments
Diav-Citrin et al (2001)^129^ | No | NA | NA | Yes | NA | Some concerns | Participants had to be callers to the Teratogen Information Service to be enrolled, and these participants may be more aware of “exposures” than participants who do not call into this service.
Sorensen et al (1999)^130^ | No | NA | NA | Yes | NA | Low | Used population-based data sources for selection into the study
Thapa et al (1998)^132^ | No | NA | NA | Yes | NA | Low | Used population-based data sources for selection into the study

Abbreviation: NA=not applicable.

Appendix E Table 16 Study Quality Ratings for Controlled Cohort Studies: Part 4

Study Author(s) (Year(s)) | Were intervention groups clearly defined? | Was the information used to define intervention groups recorded at the start of the intervention? | Could classification of intervention status have been affected by knowledge of the outcome or risk of the outcome? | Overall bias in classification of intervention | Comments
Diav-Citrin et al (2001)^129^ | Yes | Yes | No | Low | None
Sorensen et al (1999)^130^ | Yes | Yes | No | Low | None
Thapa et al (1998)^132^ | Yes | Yes | No | Low | None

Appendix E Table 17 Study Quality Ratings for Controlled Cohort Studies: Part 5

Study Author(s) (Year(s)) | Were there deviations from the intended intervention beyond what would be expected in usual practice? | Were these deviations from intended intervention unbalanced between groups and likely to have affected the outcome? | Overall bias due to deviation from intended intervention | Comments
Diav-Citrin et al (2001)^129^ | No | NA | Low | None
Sorensen et al (1999)^130^ | No information | No information | Low | None
Thapa et al (1998)^132^ | No | NA | Low | None

Abbreviation: NA=not applicable.

Appendix E Table 18 Study Quality Ratings for Controlled Cohort Studies: Part 6

Study Author(s) (Year(s)) | Were outcome data available for all, or nearly all, participants? | Were participants excluded due to missing data on intervention status? | Were participants excluded due to missing data on other variables needed for the analysis? | Are the proportion of participants and reasons for missing data similar across interventions? | Is there evidence that results were robust to the presence of missing data? | Overall bias due to missing data | Comments
Diav-Citrin et al (2001)^129^ | No | No | Yes | No | No information | High | Followup birth outcome data only available for 52.4% of metronidazole-exposed participants and for 37.4% of control participants.
Sorensen et al (1999)^130^ | Probably yes | No | No | No information | No information | Some concerns | Used population-level prescription and birth registry databases, but authors did not have data on malformed fetuses detected at prenatal diagnosis and aborted fetuses.
Thapa et al (1998)^132^ | Yes | No | No | No information | No information | Uncertain because no information | 94.2% of potentially eligible women were able to be linked to a child. Authors discuss the implications of migration on findings in the discussion.

Appendix E Table 19 Study Quality Ratings for Controlled Cohort Studies: Part 7

Study Author(s) (Year(s)) | Could the outcome measure have been influenced by knowledge of the intervention received? | Were outcome assessors aware of the intervention received by study participants? | Were the methods of outcome assessment comparable across intervention groups? | Were any systematic errors in measurement of the outcome related to intervention received? | Overall bias in measurement of outcomes | Comments
Diav-Citrin et al (2001)^129^ | Probably no | No information | Yes | Probably no | Low | Because the outcome was major malformations, it is unlikely that knowledge of the exposure would have influenced the measurement of this outcome.
Sorensen et al (1999)^130^ | No | No information | Yes | No information | Some concerns | Outcome definition for malformations not provided by study authors; thus, it is not clear how this was measured using birth registry data.
Thapa et al (1998)^132^ | No | No information | Yes | Probably no | Low | Because the outcome was incidence of cancer, it is unlikely that knowledge of the exposure would have influenced the measurement of this outcome.

Appendix E Table 20 Study Quality Ratings for Controlled Cohort Studies: Part 8

Study Author(s) (Year(s)) | Is the reported effect estimate likely to be selected, on the basis of the results, from multiple outcome measurements within the outcome domain? | Is the reported effect estimate likely to be selected, on the basis of the results, from multiple analyses of the intervention outcome relationship? | Is the reported effect estimate likely to be selected, on the basis of the results, from different subgroups? | Overall bias in selection of the reported result | Comments
Diav-Citrin et al (2001)^129^ | No | No | No | Low | None
Sorensen et al (1999)^130^ | No | No | No | Low | None
Thapa et al (1998)^132^ | No | No | No | Low | None

Appendix E Table 21 Study Quality Ratings for Case Control Studies: Part 1

Study Author(s) (Year(s)) | Overall Study Quality | Taking into account clinical considerations, your evaluation of the methodology used, and the statistical power of the study, do you think there is clear evidence of an association between exposure and outcome? | Are the results of this study directly applicable to the patient group targeted by this guideline | Notes
Czeizel et al (1998)^131^ | Fair | No | Yes | Differential followup, which might be due to the differential methods for outcome ascertainment used between the exposed and unexposed groups. Also, potential for recall bias, particularly among cases.

Appendix E Table 22 Study Quality Ratings for Case Control Studies: Part 2

Study Author(s) (Year(s)) | The study addresses an appropriate and clearly focused question | Cases and controls taken from comparable populations | The same exclusion criteria are used for both cases and controls | What percentage of each group (cases and controls) participated in the study? | Comparison made between participants and nonparticipants to establish similarities or differences
Czeizel et al (1998)^131^ | Yes | Yes | Can’t say | Cases: 82% Controls: 65% | Yes

Appendix E Table 23 Study Quality Ratings for Case Control Studies: Part 3

Study Author(s) (Year(s)) | Cases are clearly defined and differentiated from control | It is clearly established that controls are noncases | Measures taken to prevent knowledge of primary exposure influencing case ascertainment | Exposure status is measured in a standard, valid and reliable way | Main potential confounders are identified and considered in design and analysis | Confidence intervals are provided
Czeizel et al (1998)^131^ | Yes | Yes | Yes | No | Cannot say | Yes

Appendix E Table 24 Study Quality Ratings for Meta-Analyses: Part 1

Study Author(s) (Year(s)) | Overall Study Quality | Rationale for Study Quality
Burtin et al (1995)^133^ | Fair | No review protocol, no information about how studies were selected and data abstracted, no risk of bias assessment for included studies; this is an older review and methods for conducting and reporting systematic reviews were not as robust as they are now.
Caro-Paton et al (1997)^134^ | Fair | No review protocol, no information about how studies were selected and data abstracted, no risk of bias assessment for included studies; this is an older review and methods for conducting and reporting systematic reviews were not as robust as they are now.

Appendix E Table 25 Study Quality Ratings for Meta-Analyses: Part 2

Study Author(s) (Year(s)) | Did the review adhere to predefined objectives and eligibility criteria? | Were the eligibility criteria appropriate for the review question? | Were eligibility criteria unambiguous? | Were all restrictions in eligibility criteria based on study characteristics appropriate (e.g., date, sample size, study quality, outcomes measured)? | Were any restrictions in eligibility criteria based on sources of information appropriate (e.g. publication status or format, language, availability of data)? | Concerns regarding specification of study eligibility criteria
Burtin et al (1995)^133^ | No information | Yes | Yes | Unclear or some concerns | Very little information to judge | Low
Caro-Paton et al (1997)^134^ | No information | Yes | Yes | Unclear or some concerns | Very little information to judge | Low

Appendix E Table 26 Study Quality Ratings for Meta-Analyses: Part 3

Study Author(s) (Year(s)) | Did the review search an appropriate range of databases/electronic sources for published and unpublished reports? | Were methods additional to database searching used to identify relevant reports? | Were the terms and structure of the search strategy likely to retrieve as many eligible studies as possible? | Were restrictions based on date, publication format, or language appropriate? | Were efforts made to minimize error in selection of studies? | Concerns regarding methods used to identify and/or select studies
Burtin et al (1995)^133^ | Yes | Yes | Probably no | Probably yes | No information | Unclear or some concerns
Caro-Paton et al (1997)^134^ | Yes | Yes | Probably yes | Probably yes | No information | Unclear or some concerns

Appendix E Table 27 Study Quality Ratings for Meta-Analyses: Part 4

Study Author(s) (Year(s)) | Were efforts made to minimize error in data collection? | Were sufficient study characteristics available for both review authors and readers to be able to interpret the results? | Were all relevant study results collected for use in the synthesis? | Was risk of bias (or methodological quality) formally assessed using an appropriate tool? | Were efforts made to minimize error in risk of bias assessment? | Concerns regarding methods used to collect data and appraise studies
Burtin et al (1995)^133^ | No information | Probably yes | No information | No | No information | Unclear or some concerns
Caro-Paton et al (1997)^134^ | No information | Probably yes | No information | No | No information | Unclear or some concerns

Appendix E Table 28 Study Quality Ratings for Meta-Analyses: Part 5

Study Author(s) (Year(s)) | Did the synthesis include all studies that it should? | Were all pre-defined analyses reported or departures explained? | Was the synthesis appropriate given the degree of similarity in the research questions, study designs and outcomes across included studies? | Was between-study variation (heterogeneity) minimal or addressed in the synthesis? | Were the findings robust, e.g. as demonstrated through sensitivity analyses? | Were biases in primary studies minimal or addressed in the synthesis? | Concerns regarding the synthesis
Burtin et al (1995)^133^ | Probably yes | No information | Probably yes | Probably yes | Yes | Yes | Unclear or some concerns
Caro-Paton et al (1997)^134^ | Probably yes | No information | Probably yes | Probably yes | No information | Yes | Unclear or some concerns

Appendix E Table 29 Study Quality Ratings for Meta-Analyses: Part 6

Study Author(s) (Year(s)) | Did the interpretation of findings address all of the concerns identified in all domains? | Was the relevance of identified studies to the review’s research question appropriately considered? | Did the reviewers avoid emphasizing results on the basis of their statistical significance?
Burtin et al (1995)^133^ | No information | Yes | Yes
Caro-Paton et al (1997)^134^ | No information | Yes | Yes