# Appendix D Additional Evidence Tables

Appendix D Table 1 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—pH (KQ 2)

Appendix D Table 2 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—Vaginal Discharge (KQ 2)

Appendix D Table 3 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy–Whiff Test (KQ 2)

Appendix D Table 4 Accuracy of Diagnostic Tests From Studies of Diagnostic Test Accuracy—Clue Cells (KQ 2)

Appendix D Table 5 Additional Study Characteristics of Randomized, Controlled Trials of Treatment of Bacterial Vaginosis to Prevent Preterm Delivery (KQs 4 and 5)

Appendix D Table 6 Intermediate Outcomes of Randomized, Controlled Trials of Treatment of Bacterial Vaginosis to Prevent Preterm Delivery (KQ 4)

Appendix D Table 7 Additional Study Characteristics of Cohort Studies of Harms of In Utero Exposure to Metronidazole (KQ5)

Appendix D Table 8 Detailed Harm Outcomes Reported in Cohort Studies of In Utero Exposure to Metronidazole (KQ5)

Appendix D Table 9 Additional Study Characteristics of Case Control Study of Harms of In Utero Exposure to Metronidazole (KQ5)

Appendix D Table 10 Detailed Harm Outcomes Reported in Case Control Study of In Utero Exposure to Metronidazole (KQ5)

Appendix D Table 11 Additional Study Characteristics of Meta-Analyses of Harms of In Utero Exposure to Metronidazole (KQ5)

Appendix D Table 12 Harm Outcomes Reported in Meta-Analyses of In Utero Exposure to Metronidazole (KQ5)