# Appendix C Excluded Studies

List of Exclusion Codes:

X1 Systematic review for hand search
X2 Ineligible publication type
X3 Ineligible country
X4 Ineligible population
X5 Ineligible intervention
X6 Ineligible comparator
X7 Ineligible outcome
X8 Ineligible study design
X9 Duplicate or superseded
X10 Study protocol or in progress
X11 Abstract only
X12 Non-English full text
X13 Other

1 Screening for bacterial vaginosis in pregnancy: recommendations and rationale. Am J Prev Med. 2001 Apr;20:(3 Suppl):59–61. PMID: 11306233. Exclusion Code: X2.11306233
2 Screening for bacterial vaginosis in pregnancy: recommendations and rationale. Am J Nurs. 2002 Aug;102(8):91–3. PMID: 12394045. Exclusion Code: X2.12394045
3 Screening for bacterial vaginosis in pregnancy to prevent preterm delivery: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008 Feb 5;148(3):214–9. PMID: 19046169. Exclusion Code: X2.18252683
4 Abdali K, Jahed L, Amooee S, . Comparison of the effect of vaginal zataria multiflora cream and oral metronidazole pill on results of treatments for vaginal infections including trichomoniasis and bacterial vaginosis in women of reproductive age. Biomed Res Int. 2015;2015:683640. doi: 10.1155/2015/683640. PMID: 26385347. Exclusion Code: X3.26266260
5 Africa CW. Efficacy of methods used for the diagnosis of bacterial vaginosis. Expert Opin Med Diagn. 2013 Mar;7(2):189–200. doi: 10.1517/17530059.2013.753876. PMID: 23585843. Exclusion Code: X2.23530888
6 Allergan Sales LLC. Safety and tolerability of metronidazole gel 1.3%. March 18, 2015. In ClinicalTrials.gov. [cited December 2, 2018]. Bethesda, MD: National Library of Medicine. 2016. Available from: https://ClinicalTrials.gov/show/NCT02392026. NCT02392026. Exclusion Code: X4.
7 American International. Diagnosing bacterial vaginosis/vaginitis (BV) using the gynecologene test method. September 23, 2015. In ClinicalTrials.gov. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02558179. NCT02558179. Exclusion Code: X10.
8 Anderson B, Zhao Y, Andrews W, . Effect of antibiotic exposure on Nugent score among pregnant women with and without bacterial vaginosis. Obstet Gynecol. 2011;117(4):844–9. doi: 10.1097/AOG.0b013e318209dd57. PMID: CN-00812284. Exclusion Code: X4.21422854
9 Andrews WW, Goldenberg RL. What we have learned from an antibiotic trial in fetal fibronectin positive women. Semin Perinatol. 2003 Jun;27(3):231–8. PMID: 12889590. Exclusion Code: X4.12889590
10 Assistance Publique Hopitaux De Marseille. Identification and impact of vaginal flora anomalies among pregnant woman. June 11, 2007. In ClinicalTrials.gov. [cited December 2, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00484653. NCT00484653. Exclusion Code: X9.
11 Assistance Publique Hopitaux De Marseille. Medico-economic impact of screening atopobium vaginae and gardnerella vaginalis in molecular biology by “point-of-care” during pregnancy. November 11, 2014. In ClinicalTrials.gov. [cited December 2, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02288832. Exclusion Code: X10.
12 August Wolff GmbH & Co, Arzneimittel KG. Safety, tolerability and efficacy of vaginal suppository WO3191 in the post-treatment of bacterial vaginosis. February 22, 2016. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02687789. NCT02687789. Exclusion Code: X4.
13 Balashov SV, Mordechai E, Adelson ME, . Identification, quantification and subtyping of Gardnerella vaginalis in noncultured clinical vaginal samples by quantitative PCR. J Med Microbiol. 2014 Feb;63(Pt 2):162–75. doi: 10.1099/jmm.0.066407-0. PMID: 24200640. Exclusion Code: X7.24200640
14 Balashov SV, Mordechai E, Adelson ME, . Multiplex quantitative polymerase chain reaction assay for the identification and quantitation of major vaginal lactobacilli. Diagn Microbiol Infect Dis. 2014 Apr;78(4):321–7. doi: 10.1016/j.diagmicrobio.2013.08.004. PMID: 24445159. Exclusion Code: X5.24445159
15 Beck D, Foster JA. Machine learning techniques accurately classify microbial communities by bacterial vaginosis characteristics. PLoS One. 2014;9(2):e87830. doi: 10.1371/journal.pone.0087830. PMID: 26023904. Exclusion Code: X5.24498380
16 Belgian Contract Research O. Therapeutic Equivalence (non-inferiority), Randomized, Observer-blind, two Parallel Group, Clinical Trial for Comparing the Efficacy and Tolerability of a Generic Formulation of Vaginal Ovule containing Clindamycin 100 mg/ovule versus Dalacin® 100 mg Vaginal Ovules (Pfizer©) in patients with Bacterial Vaginosis - Therapeutic equivalence trial between two formulations of clindamycin 100mg vaginal ovules. Verisfield (UK) Ltd., Greek branch. Athens Greece: 2017. https://www.clinicaltrialsregister.eu/ctr-search/search?query=eudract_number:2016-004292-41. Exclusion Code: X10.
17 Bharti R, Sainia P, Kapoor G, . Evaluation of vaginal pH as a screening tool for bacterial vaginosis and impact of screening and treating for bacterial vaginosis on preterm births. Indian J Public Health Res Dev. 2017;8(4):214–9. doi: 10.5958/0976-5506.2017.00342.4. PMID: CN-01440663. Exclusion Code: X3.
18 Bitzer EM, Schneider A, Wenzlaff P, . Self-testing of vaginal pH to prevent preterm delivery: a controlled trial. Dtsch Arztebl Int. 2011 Feb;108(6):81–6. doi: 10.3238/arztebl.2011.0081. PMID: 20852454. Exclusion Code: X8.21373274
19 Blankenstein T, Lytton SD, Leidl B, . Point-of-care (POC) diagnosis of bacterial vaginosis (BV) using VGTest ion mobility spectrometry (IMS) in a routine ambulatory care gynecology clinic. Arch Gynecol Obstet. 2015 Aug;292(2):355–62. doi: 10.1007/s00404-014-3613-x. PMID: 26078959. Exclusion Code: X5.25638448
20 Boggess KA, Trevett TN, Madianos PN, . Use of DNA hybridization to detect vaginal pathogens associated with bacterial vaginosis among asymptomatic pregnant women. Am J Obstet Gynecol. 2005 Sep;193(3 Pt 1):752–6. doi: 10.1016/j.ajog.2005.01.068. PMID: 16150270. Exclusion Code: X5.16150270
21 Bothuyne-Queste É, Hannebicque-Montaigne K, Canis F, . Is the bacterial vaginosis risk factor of prematurity? Study of a cohort of 1336 patients in the hospital of Arras. Journal de Gynécologie Obstétrique et Biologie de la Reproduction. 2012 2012/05/01/;41(3):262–70. doi: 10.1016/j.jgyn.2012.01.007. Exclusion Code: X12.
22 Bradshaw C, Pirotta M, Hocking J, . Double-blind randomised placebo controlled trial of oral metronidazole in combination with either vaginal clindamycin or an oestrogen-containing vaginal probiotic for the treatment of bacterial vaginosis. Sex Transm Infect. 2011;87:A80–a1. doi: 10.1136/sextrans-2011-050109.132. PMID: CN-01033602. Exclusion Code: X4.
23 Bravo AB, Miranda LS, Lima OF, . Validation of an immunologic diagnostic kit for infectious vaginitis by Trichomonas vaginalis, Candida spp., and Gardnerella vaginalis. Diagn Microbiol Infect Dis. 2009 Mar;63(3):257–60. doi: 10.1016/j.diagmicrobio.2008.11.010. PMID: 19216938. Exclusion Code: X3.19216938
24 Bretelle F, Fenollar F, Baumstarck K, . Screen-and-treat program by point-of-care of Atopobium vaginae and Gardnerella vaginalis in preventing preterm birth (AuTop trial): study protocol for a randomized controlled trial. Trials. 2015 Oct 19;16:470. doi: 10.1186/s13063-015-1000-y. PMID: 26482128. Exclusion Code: X10.26482128
25 Bretelle F, Rozenberg P, Pascal A, . High Atopobium vaginae and Gardnerella vaginalis vaginal loads are associated with preterm birth. Clin Infect Dis. 2015 Mar 15;60(6):860–7. doi: 10.1093/cid/ciu966. PMID: 25452591. Exclusion Code: X5.25452591
26 Briery CM, Chauhan SP, Magann EF, . Treatment of bacterial vaginosis does not reduce preterm birth among high-risk asymptomatic women in fetal fibronectin positive patients. J Miss State Med Assoc. 2011 Mar;52(3):72–5. PMID: 20012637. Exclusion Code: X6.21476464
27 Brocklehurst P, Gordon A, Heatley E, . Antibiotics for treating bacterial vaginosis in pregnancy. Cochrane Database Syst Rev. 2013(1). doi: 10.1002/14651858.CD000262.pub4. PMID: CD000262. Exclusion Code: X1.
28 Brown HL, Fuller DA, Davis TE, . Evaluation of the Affirm Ambient Temperature Transport System for the detection and identification of Trichomonas vaginalis, Gardnerella vaginalis, and Candida species from vaginal fluid specimens. J Clin Microbiol. 2001 Sep;39(9):3197–9. PMID: 11526150. Exclusion Code: X6.11526150
29 Brown HL, Fuller DD, Jasper LT, . Clinical evaluation of affirm VPIII in the detection and identification of Trichomonas vaginalis, Gardnerella vaginalis, and Candida species in vaginitis/vaginosis. Infect Dis Obstet Gynecol. 2004;12(1):17–21. doi: 10.1080/1064744042000210375. PMID: 15460191. Exclusion Code: X6.15460191
30 Cakiroglu Y, Caliskan S, Doger E, . Do the interactions between coital frequency, cervical length, and urogenital infection affect obstetric outcomes? Turk J Obstet Gynecol. 2015 Jun;12(2):66–70. doi: 10.4274/tjod.89106. PMID: 28913045. Exclusion Code: X3.28913045
31 Carter J, Beck D, Williams H, . GA-based selection of vaginal microbiome features associated with bacterial vaginosis. Genet Evol Comput Conf. 2014;2014:265–8. doi: 10.1145/2576768.2598378. PMID: 25541628. Exclusion Code: X5.25541628
32 Cartwright CP, Lembke BD, Ramachandran K, . Development and validation of a semiquantitative, multitarget PCR assay for diagnosis of bacterial vaginosis. J Clin Microbiol. 2012 Jul;50(7):2321–9. doi: 10.1128/jcm.00506-12. PMID: 23320114. Exclusion Code: X5.22535982
33 Cartwright CP, Pherson AJ, Harris AB, . Multicenter study establishing the clinical validity of a nucleic-acid amplification-based assay for the diagnosis of bacterial vaginosis. Diagn Microbiol Infect Dis. 2018 Nov;92(3):173–8. doi: 10.1016/j.diagmicrobio.2018.05.022. Exclusion Code: X5.29937222
34 Castell S, Krause G, Schmitt M, . Feasibility and acceptance of cervicovaginal self-sampling within the German National Cohort (Pretest 2). Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2014 Nov;57(11):1270–6. doi: 10.1007/s00103-014-2054-9. PMID: 25303829. Exclusion Code: X5.25303829
35 Cauci S, Culhane JF. High sialidase levels increase preterm birth risk among women who are bacterial vaginosis-positive in early gestation. Am J Obstet Gynecol. 2011 Feb;204(2):142.e1–9. doi: 10.1016/j.ajog.2010.08.061. PMID: 21261445. Exclusion Code: X5.21055720
36 CDA Research Group, Inc. GoldenCareTM for the treatment of bacterial vaginosis. January 8, 2013. In ClinicalTrials.gov. [cited December 2, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01762670. NCT01762670. Exclusion Code: X14.
37 CDA Research Group, Inc. LUXSOL(TM) topical cream for the treatment of symptomatic bacterial vaginosis; a proof of concept study. July 22, 2014. In ClinicalTrials.gov. [cited December 2, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02197182. NCT02197182. Exclusion Code: X4.
38 Centers for Disease Control and Prevention. Maternal effects of bacterial vaginosis (BV) treatment in pregnancy. September 12, 2005. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000+. Available from: https://ClinicalTrials.gov/show/NCT00153517. NCT00153517. Exclusion Code: X6.
39 Chaijareenont K, Sirimai K, Boriboonhirunsarn D, . Accuracy of Nugent’s score and each Amsel’s criteria in the diagnosis of bacterial vaginosis. J Med Assoc Thai. 2004 Nov;87(11):1270–4. PMID: 15825698. Exclusion Code: X3.15825698
40 Chaim W, Karpas Z, Lorber A. New technology for diagnosis of bacterial vaginosis. Eur J Obstet Gynecol Reprod Biol. 2003 Nov 10;111(1):83–7. PMID: 14557018. Exclusion Code: X5.14557018
41 Chandiok S, Crawley BA, Oppenheim BA, . Screening for bacterial vaginosis: a novel application of artificial nose technology. J Clin Pathol. 1997 Sep;50(9):790–1. PMID: 9389983. Exclusion Code: X5.9389983
42 Charonis G, Larsson PG. Use of pH/whiff test or QuickVue Advanced pH and Amines test for the diagnosis of bacterial vaginosis and prevention of postabortion pelvic inflammatory disease. Acta Obstet Gynecol Scand. 2006;85(7):837–43. doi: 10.1080/00016340600589776. PMID: 16817083. Exclusion Code: X5.16817083
43 Chaudry AN, Travers PJ, Yuenger J, . Analysis of vaginal acetic acid in patients undergoing treatment for bacterial vaginosis. J Clin Microbiol. 2004 Nov;42(11):5170–5. doi: 10.1128/jcm.42.11.5170-5175.2004. PMID: 15528711. Exclusion Code: X5.15528711
44 Chawla R, Bhalla P, Chadha S, . Comparison of Hay’s criteria with Nugent’s scoring system for diagnosis of bacterial vaginosis. Biomed Res Int. 2013;2013:365194. doi: 10.1155/2013/365194. PMID: 23602465. Exclusion Code: X3.23841066
45 Christiana Care Health Services. Clindamycin to reduce preterm birth in a low resource setting. February 29, 2013. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01800825. NCT01800825. Exclusion Code: X3.
46 Cohrssen A, Anderson M, Merrill A, . Reliability of the whiff test in clinical practice. J Am Board Fam Pract. 2005 Nov–Dec;18(6):561–2. PMID: 16322419. Exclusion Code: X7.16322419
47 Common Sense. Va-sense - bacterial vaginosis once a week screening and treatment to reduce infective complications, abortion and preterm delivery in pregnant women with previous preterm delivery. June 29, 2010. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01152528. NCT01152528. Exclusion Code: X14.
48 Cox C, McKenna JP, Watt AP, . New assay for Gardnerella vaginalis loads correlates with Nugent scores and has potential in the diagnosis of bacterial vaginosis. J Med Microbiol. 2015 Sep;64(9):978–84. doi: 10.1099/jmm.0.000118. PMID: 25316066. Exclusion Code: X5.26296660
49 Crist Jr AE, Bankert D, Mallory RV, . Comparison of the BD affirm VPIII test to primary care and clinical laboratory methods for the diagnosis of bacterial vaginosis and yeast vaginitis. Infectious Diseases in Clinical Practice. 2011;19(4):273–5. doi: 10.1097/IPC.0b013e318210fdc0. Exclusion Code: X6.
50 Cristiano L, Rampello S, Noris C, . Bacterial vaginosis: prevalence in an Italian population of asymptomatic pregnant women and diagnostic aspects. Eur J Epidemiol. 1996 Aug;12(4):383–90. PMID: 8891543. Exclusion Code: X6.8891543
51 Czeizel AE, Puho EH, Kazy Z. The use of data set of the Hungarian case-control surveillance of congenital abnormalities for evaluation of birth outcomes beyond birth defects. Cent Eur J Public Health. 2007 Dec;15(4):147–53. PMID: 18786293. Exclusion Code: X8.18251229
52 Danisco. PreFem: “what happens to the vaginal microbiota when a bv infection is treated with metronidazole?” June 14, 2017. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT03187457. NCT03187457. Exclusion Code: X4.
53 Darwish A, Elnshar E, Hamadeh S, . Treatment options for bacterial vaginosis in patients at high risk of preterm labor and premature rupture of membranes. J Obstet Gynaecol Res. 2007;33(6):781–7. doi: 10.1111/j.1447-0756.2007.00656.x. PMID: CN-00702328. Exclusion Code: X3.18001442
54 Daswani B. Comparison of two topical formulations containing clindamycin and clotrimazole in patients with vaginal infections. September. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2011. Available from: https://ClinicalTrials.gov/show/NCT01697826. NCT01697826. Exclusion Code: X3.
55 Datcu R. Characterization of the vaginal microflora in health and disease. Dan Med J. 2014 Apr;61(4):B4830. PMID: 24814599. Exclusion Code: X1.24814599
56 Datcu R, Gesink D, Mulvad G, . Vaginal microbiome in women from Greenland assessed by microscopy and quantitative PCR. BMC Infect Dis. 2013 Oct 16;13:480. doi: 10.1186/1471-2334-13-480. PMID: 21391758. Exclusion Code: X7.24131550
57 Datcu R, Gesink D, Mulvad G, . Bacterial vaginosis diagnosed by analysis of first-void-urine specimens. J Clin Microbiol. 2014 Jan;52(1):218–25. doi: 10.1128/jcm.02347-13. PMID: 24096128. Exclusion Code: X5.24197876
58 Davis JD, Connor EE, Clark P, . Correlation between cervical cytologic results and Gram stain as diagnostic tests for bacterial vaginosis. Am J Obstet Gynecol. 1997 Sep;177(3):532–5. PMID: 9322619. Exclusion Code: X5.9322619
59 Diaz-Cueto L, Dominguez-Lopez P, Tena-Alavez G, . Effect of clindamycin treatment on vaginal inflammatory markers in pregnant women with bacterial vaginosis and a positive fetal fibronectin test. Int J Gynaecol Obstet. 2009 Nov;107(2):143–6. doi: 10.1016/j.ijgo.2009.06.015. PMID: 21419384. Exclusion Code: X3.19647824
60 Discacciati MG, Simoes JA, Amaral RG, . Presence of 20% or more clue cells: an accurate criterion for the diagnosis of bacterial vaginosis in Papanicolaou cervical smears. Diagn Cytopathol. 2006 Apr;34(4):272–6. doi: 10.1002/dc.20418. PMID: 16756982. Exclusion Code: X3.16544334
61 Donders GG. Microscopy of the bacterial flora on fresh vaginal smears. Infect Dis Obstet Gynecol. 1999;7(4):177–9. doi: 10.1155/s1064744999000290. PMID: 10449264. Exclusion Code: X2.10449264
62 Donders GG. Reducing infection-related preterm birth. BJOG. 2015 Jan;122(2):219. doi: 10.1111/1471-0528.13109. PMID: 25546046. Exclusion Code: X8.25546046
63 Donders GG, Marconi C, Bellen G. Easiness of use and validity testing of VS-SENSE device for detection of abnormal vaginal flora and bacterial vaginosis. Infect Dis Obstet Gynecol. 2010;2010:504972. doi: 10.1155/2010/504972. PMID: 20953405. Exclusion Code: X6.20953405
64 Dongfang Hospital Affiliated to Beijing University of Chinese M, Peking University First H, Beijing Compete Pharmaceutical Co L, . Honghe Fujie lotion for the treatment of bacterial vaginosis. February 26, 2018. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2019. Available from: https://ClinicalTrials.gov/show/NCT03446443. NCT03446443. Exclusion Code: X3.
65 Effik Italia S. p A. A study of the new medical device polybactum® (POLARIS). March. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02863536. NCT02863536. Exclusion Code: X4.
66 Eriksson K, Forsum U, Bjornerem A, . Validation of the use of Pap-stained vaginal smears for diagnosis of bacterial vaginosis. APMIS. 2007 Jul;115(7):809–13. doi: 10.1111/j.1600-0463.2007.apm_607.x. PMID: 17413534. Exclusion Code: X5.17614847
67 Esim Buyukbayrak E, Kars B, Karsidag AY, . Diagnosis of vulvovaginitis: comparison of clinical and microbiological diagnosis. Arch Gynecol Obstet. 2010 Nov;282(5):515–9. doi: 10.1007/s00404-010-1498-x. PMID: 21160139. Exclusion Code: X3.20461391
68 Eunice Kennedy Shriver, National Institute of Child Health and Human Development (NICHD),. Longitudinal study of vaginal flora. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00340275. NCT00340275. Exclusion Code: X4.
69 Farr A, Kiss H, Hagmann M, . Routine use of an antenatal infection screen-and-treat program to prevent preterm birth: long-term experience at a tertiary referral center. Birth. 2015 Jun;42(2):173–80. doi: 10.1111/birt.12154. PMID: 25677078. Exclusion Code: X5.25677078
70 Forsum U, Jakobsson T, Larsson PG, . An international study of the interobserver variation between interpretations of vaginal smear criteria of bacterial vaginosis. APMIS. 2002 Nov;110(11):811–8. PMID: 12596717. Exclusion Code: X7.12596717
71 Fredricks DN, Fiedler TL, Thomas KK, . Targeted PCR for detection of vaginal bacteria associated with bacterial vaginosis. J Clin Microbiol. 2007 Oct;45(10):3270–6. doi: 10.1128/jcm.01272-07. PMID: 17274857. Exclusion Code: X5.17687006
72 Gazi H, Degerli K, Kurt O, . Use of DNA hybridization test for diagnosing bacterial vaginosis in women with symptoms suggestive of infection. APMIS. 2006 Nov;114(11):784–7. doi: 10.1111/j.1600-0463.2006.apm_485.x. PMID: 16544334. Exclusion Code: X3.17078859
73 GenMont Biotech Incorporation. Analysis of ameliorative effects of oral probiotics on bacterial vaginosis. April 17, 2017. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT03116789. NCT03116789. Exclusion Code: X5.
74 Genovese C, Corsello S, Nicolosi D, . Alterations of the vaginal microbiota in the third trimester of pregnancy and pPROM. Eur Rev Med Pharmacol Sci. 2016 Aug;20(16):3336–43. PMID: 27608890. Exclusion Code: X5.27608890
75 Geva A, Bornstein J, Dan M, . The VI-SENSE-vaginal discharge self-test to facilitate management of vaginal symptoms. Am J Obstet Gynecol. 2006 Nov;195(5):1351–6. doi: 10.1016/j.ajog.2006.04.008. PMID: 17625772. Exclusion Code: X7.16769019
76 Giacomini G, Calcinai A, Moretti D, . Accuracy of cervical/vaginal cytology in the diagnosis of bacterial vaginosis. Sex Transm Dis. 1998 Jan;25(1):24–7. PMID: 9437781. Exclusion Code: X6.9437781
77 Giakoumelou S, Wheelhouse N, Cuschieri K, . The role of infection in miscarriage. Hum Reprod Update. 2016 Jan–Feb;22(1):116–33. doi: 10.1093/humupd/dmv041. PMID: 26386469. Exclusion Code: X2.26386469
78 Gillet E, Meys J, Verstraelen H, . Association between bacterial vaginosis and cervical intraepithelial neoplasia: systematic review and meta-analysis (Provisional abstract). In PLoS One Exclusion Code: X4.
79 Gjerdingen D, Fontaine P, Bixby M, . The impact of regular vaginal pH screening on the diagnosis of bacterial vaginosis in pregnancy. J Fam Pract. 2000 Jan;49(1):39–43. PMID: 10678339. Exclusion Code: X6.10678339
80 Goldenberg RL, Mwatha A, Read JS, . The HPTN 024 Study: the efficacy of antibiotics to prevent chorioamnionitis and preterm birth. Am J Obstet Gynecol. 2006 Mar;194(3):650–61. doi: 10.1016/j.ajog.2006.01.004. PMID: 16522393. Exclusion Code: X3.16522393
81 Graceway Pharmaceutical, LLC. Dose ranging study of metronidazole vaginal gel in the treatment of bacterial vaginosis. January 24, 2010. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01055106. NCT01055106. Exclusion Code: X4.
82 Grmek Kosnik I, Dermota U, Golle A. Frequency of detection of Gardnerella vaginalis in vaginal smears in the Upper Carniola region. Acta Dermatovenerol Alp Pannonica Adriat. 2016 Jun;25(2):31–3. PMID: 27348455. Exclusion Code: X6.27348455
83 Guangzhou Yipinhong Pharmaceutical Co, LTD. The efficacy and safety study of clindamycin palmitate hydrochloride dispersible tablet treatment of bacterial vaginosis. March 15, 2017. In ClinicalTrials.gov. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT03080740. NCT03080740. Exclusion Code: X4.
84 Haahr T, Jensen JS, Thomsen L, . Abnormal vaginal microbiota may be associated with poor reproductive outcomes: a prospective study in IVF patients. Hum Reprod. 2016 Apr;31(4):795–803. doi: 10.1093/humrep/dew026. PMID: 26911864. Exclusion Code: X5.26911864
85 HaEmek Medical Center, Israel. Comparison between oral clindamycin vs metronidazole for the treatment of abnormal vaginal flora in high risk pregnancies. November 7, 2012. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01722708. NCT01722708. Exclusion Code: X6.
86 Hakimi S, Farhan F, Farshbaf-Khalili A, . The effect of prebiotic vaginal gel with adjuvant oral metronidazole tablets on treatment and recurrence of bacterial vaginosis: a triple-blind randomized controlled study. Arch Gynecol Obstet. 2018 Jan;297(1):1–8. doi: 10.1007/s00404-017-4555-x. PMID: 28983665. Exclusion Code: X3.29151230
87 Hanson L, VandeVusse L, Jerme M, . Probiotics for treatment and prevention of urogenital infections in women: a systematic review. J Midwifery Womens Health. 2016 May;61(3):339–55. doi: 10.1111/jmwh.12472. PMID: 27218592. Exclusion Code: X5.27218592
88 Hardy L, Jespers V, Dahchour N, . Unravelling the bacterial vaginosis-associated biofilm: a multiplex gardnerella vaginalis and atopobium vaginae fluorescence in situ hybridization assay using peptide nucleic acid probes. PLoS One. 2015;10(8):e0136658. doi: 10.1371/journal.pone.0136658. PMID: 25291946. Exclusion Code: X5.26305575
89 Haudongchun Co., Ltd. Clinical study to evaluate the efficacy of HUDC_VT in patients with bacterial vaginosis. November 30, 2017. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT03357666. NCT03357666. Exclusion Code: X5.
90 Hauth JC, Macpherson C, Carey JC, . Early pregnancy threshold vaginal pH and Gram stain scores predictive of subsequent preterm birth in asymptomatic women. Am J Obstet Gynecol. 2003 Mar;188(3):831–5. PMID: 12634666. Exclusion Code: X6.12634666
91 Hay P, Tummon A, Ogunfile M, . Evaluation of a novel diagnostic test for bacterial vaginosis: ‘the electronic nose’. Int J STD AIDS. 2003 Feb;14(2):114–8. doi: 10.1258/095646203321156881. PMID: 12662390. Exclusion Code: X5.12662390
92 Hemalatha R, Mastromarino P, Ramalaxmi BA, . Effectiveness of vaginal tablets containing lactobacilli versus pH tablets on vaginal health and inflammatory cytokines: a randomized, double-blind study. Eur J Clin Microbiol Infect Dis. 2012 Nov;31(11):3097–105. doi: 10.1007/s10096-012-1671-1. PMID: 22777592. Exclusion Code: X5.22777592
93 Hemalatha R, Ramalaxmi BA, Swetha E, . Evaluation of vaginal pH for detection of bacterial vaginosis. Indian J Med Res. 2013 Sep;138(3):354–9. PMID: 23221767. Exclusion Code: X3.24135180
94 Hemmerling A, Harrison W, Schroeder A, . Phase 2a study assessing colonization efficiency, safety, and acceptability of Lactobacillus crispatus CTV-05 in women with bacterial vaginosis. Sex Transm Dis. 2010;37(12):745–50. doi: 10.1097/OLQ.0b013e3181e50026. PMID: CN-00781557. Exclusion Code: X5.20644497
95 Hendler I, Andrews WW, Carey CJ, . The relationship between resolution of asymptomatic bacterial vaginosis and spontaneous preterm birth in fetal fibronectin-positive women. Am J Obstet Gynecol. 2007 Nov;197(5):488.e1–5. doi: 10.1016/j.ajog.2007.03.073. PMID: 17652029. Exclusion Code: X8.17980184
96 Hilbert DW, Smith WL, Chadwick SG, . Development and validation of a highly accurate quantitative real-time PCR assay for diagnosis of bacterial vaginosis. J Clin Microbiol. 2016 Apr;54(4):1017–24. doi: 10.1128/jcm.03104-15. PMID: 26818677. Exclusion Code: X5.26818677
97 Hilbert DW, Smith WL, Chadwick SG, . Correction for Hilbert et al., Development and validation of a highly accurate quantitative real-time PCR assay for diagnosis of bacterial vaginosis. J Clin Microbiol. 2016 Jul;54(7):1930. doi: 10.1128/jcm.00831-16. PMID: 27343296. Exclusion Code: X2.27343296
98 Hillier SL, Krohn MA, Nugent RP, . Characteristics of three vaginal flora patterns assessed by gram stain among pregnant women. Vaginal Infections and Prematurity Study Group. Am J Obstet Gynecol. 1992 Mar;166(3):938–44. PMID: 1372474. Exclusion Code: X7.1372474
99 Hills RL. Cytolytic vaginosis and lactobacillosis. Consider these conditions with all vaginosis symptoms. Adv Nurse Pract. 2007 Feb;15(2):45–8. PMID: 16527508. Exclusion Code: X2.16527508
100 Hitti J, Nugent R, Boutain D, . Racial disparity in risk of preterm birth associated with lower genital tract infection. Paediatr Perinat Epidemiol. 2007 Jul;21(4):330–7. doi: 10.1111/j.1365-3016.2007.00807.x. PMID: 16648432. Exclusion Code: X5.17564589
101 Hoffman MK, Bellad MB, Charantimath US, . A comparison of colorimetric assessment of vaginal pH with Nugent score for the detection of bacterial vaginosis. Infect Dis Obstet Gynecol. 2017;2017:1040984. doi: 10.1155/2017/1040984. PMID: 28293099. Exclusion Code: X3.28293099
102 Hogan VK, Culhane JF, Hitti J, . Relative performance of three methods for diagnosing bacterial vaginosis during pregnancy. Matern Child Health J. 2007 Nov;11(6):532–9. doi: 10.1007/s10995-007-0205-4. PMID: 17644631. Exclusion Code: X5.17874288
103 Homayouni A, Bastani P, Ziyadi S, . Effects of probiotics on the recurrence of bacterial vaginosis: a review. J Low Genit Tract Dis. 2014 Jan;18(1):79–86. doi: 10.1097/LGT.0b013e31829156ec. PMID: 27784549. Exclusion Code: X5.24299970
104 Honda H, Yokoyama T, Akimoto Y, . The frequent shift to intermediate flora in preterm delivery cases after abnormal vaginal flora screening. Sci Rep. 2014 Apr 25;4:4799. doi: 10.1038/srep04799. PMID: 24762852. Exclusion Code: X8.24762852
105 Honest H, Bachmann LM, Knox EM, . The accuracy of various tests for bacterial vaginosis in predicting preterm birth: a systematic review (Provisional abstract). BJOG. 2004;111(5):409–22. PMID: DARE-12004001037. Exclusion Code: X7.15104603
106 Honest H, Bachmann LM, Knox EM, . The accuracy of various tests for bacterial vaginosis in predicting preterm birth: a systematic review. BJOG. 2004 May;111(5):409–22. doi: 10.1111/j.1471-0528.2004.00124.x. PMID: 15104603. Exclusion Code: X7.15104603
107 Hoyme UB. Rationale and rational therapy of bacterial vaginosis. Geburtshilfe Frauenheilkd. 2007;67(3):290–2. doi: 10.1055/s-2007-965195. Exclusion Code: X12.
108 Hoyme UB, Huebner J. Prevention of preterm birth is possible by vaginal pH screening, early diagnosis of bacterial vaginosis or abnormal vaginal flora and treatment. Gynecol Obstet Invest. 2010;70(4):286–90. doi: 10.1159/000314019. PMID: 21654113. Exclusion Code: X8.21051849
109 Hu CY, Li FL, Hua XG, . Longitudinal trajectory of vulvovaginal candidiasis, trichomoniasis, and bacterial vaginosis during pregnancy as well as the impact on pregnancy outcome: a preliminary study. J Matern Fetal Neonatal Med. 2018 Apr 23:1–121. doi: 10.1080/14767058.2018.1469125. PMID: 29685081. Exclusion Code: X3.29685081
110 Huppert JS, Hesse EA, Bernard MC, . Accuracy and trust of self-testing for bacterial vaginosis. J Adolesc Health. 2012 Oct;51(4):400–5. doi: 10.1016/j.jadohealth.2012.01.017. PMID: 23543384. Exclusion Code: X6.22999842
111 Ibss Biomed SA. Supplementation of standard antibiotic therapy with oral probiotics for bacterial vaginosis. November 25, 2013. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01993524. NCT01993524. Exclusion Code: X4.
112 Indiana University School of Medicine. Recurrent bacterial vaginosis and vaginal acidifying gel trial. October 17, 2007. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00545181. NCT00545181. Exclusion Code: X4.
113 Ishaque S, Yakoob MY, Imdad A, . Effectiveness of interventions to screen and manage infections during pregnancy on reducing stillbirths: a review. BMC Public Health. 2011 Apr 13;11 Suppl 3:S3. doi: 10.1186/1471-2458-11-s3-s3. PMID: 21501448. Exclusion Code: X1.21501448
114 Isik G, Demirezen S, Donmez HG, . Bacterial vaginosis in association with spontaneous abortion and recurrent pregnancy losses. J Cytol. 2016 Jul–Sep;33(3):135–40. doi: 10.4103/0970-9371.188050. PMID: 27756985. Exclusion Code: X5.27756985
115 Ison CA, Hay PE. Validation of a simplified grading of Gram stained vaginal smears for use in genitourinary medicine clinics. Sex Transm Infect. 2002;78(6):413–5. doi: 10.1136/sti.78.6.413. Exclusion Code: X5.12473800
116 Jafarnezhad F, Mask MK, Rakhshandeh H, . Comparison of the percentage of medical success for phytovagex vaginal suppository and metronidazole oral tablet in women with bacterial vaginosis. Iranian Journal of Obstetrics, Gynecology and Infertility. 2017;20(3):29–39. doi: 10.22038/ijogi.2017.8870. Exclusion Code: X12.
117 Jakovljevic A, Bogavac M, Nikolic A, . The influence of bacterial vaginosis on gestational week of the completion of delivery and biochemical markers of inflammation in the serum. Vojnosanit Pregl. 2014 Oct;71(10):931–5. PMID: 25526757. Exclusion Code: X3.25518272
118 Janssen-Cila SA. A study to compare efficacy and safety of an ovule containing terconazole, clindamycin and fluocinolone versus an ovule containing metronidazole, nystatin and fluocinolone in the treatment of secondary vulvar/ or vaginal symptoms of infectious vaginitis/ and infectious vaginosis. June 3, 2013. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01867164. NCT01867164. Exclusion Code: X4.
119 Jesse DE, Swanson MS, Newton ER, . Racial disparities in biopsychosocial factors and spontaneous preterm birth among rural low-income women. J Midwifery Womens Health. 2009 Jan–Feb;54(1):35–42. doi: 10.1016/j.jmwh.2008.08.009. PMID: 19114237. Exclusion Code: X5.19114237
120 Joesoef MR, Schmid GP. Bacterial vaginosis: review of treatment options and potential clinical indications for therapy (Structured abstract). Clin Infect Dis. 1995;20(Supplement 1):S72–s9. PMID: DARE-11995000850. Exclusion Code: X2.7795111
121 Johnson HL, Ghanem KG, Zenilman JM, . Sexually transmitted infections and adverse pregnancy outcomes among women attending inner city public sexually transmitted diseases clinics. Sex Transm Dis. 2011 Mar;38(3):167–71. doi: 10.1097/OLQ.0b013e3181f2e85f. PMID: 21275914. Exclusion Code: X5.20852454
122 Jones HE, Harris KA, Azizia M, . Differing prevalence and diversity of bacterial species in fetal membranes from very preterm and term labor. PLoS One. 2009 Dec 8;4(12):e8205. doi: 10.1371/journal.pone.0008205. PMID: 19997613. Exclusion Code: X5.19997613
123 Jones NM, Holzman C, Friderici KH, . Interplay of cytokine polymorphisms and bacterial vaginosis in the etiology of preterm delivery. J Reprod Immunol. 2010 Dec;87(1–2):82–9. doi: 10.1016/j.jri.2010.06.158. PMID: 20573348. Exclusion Code: X5.20965572
124 Kaiser Permanente. A pilot study of oral tinidazole for women with recurrent bacterial vaginosis. May 10, 2006. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00324142. NCT00324142. Exclusion Code: X4.
125 Kampan NC, Suffian SS, Ithnin NS, . Evaluation of BV((R)) Blue Test Kit for the diagnosis of bacterial vaginosis. Sex Reprod Healthc. 2011 Jan;2(1):1–5. doi: 10.1016/j.srhc.2010.11.002. PMID: 22133886. Exclusion Code: X3.21147452
126 Kiss H, Petricevic L, Martina S, . Reducing the rate of preterm birth through a simple antenatal screen-and-treat programme: a retrospective cohort study. Eur J Obstet Gynecol Reprod Biol. 2010 Nov;153(1):38–42. doi: 10.1016/j.ejogrb.2010.06.020. PMID: 21668769. Exclusion Code: X8.20675037
127 Koumans EH, Lane SD, Aubry R, . Evaluation of Syracuse Healthy Start’s program for abnormal flora management to reduce preterm birth among pregnant women. Matern Child Health J. 2011 Oct;15(7):1020–8. doi: 10.1007/s10995-010-0661-0. PMID: 19795485. Exclusion Code: X8.20824320
128 Kumar S, Suri V, Sharma M. Bacterial vaginosis in preterm labor. Int J Gynaecol Obstet. 2006 Oct;95(1):40–1. doi: 10.1016/j.ijgo.2006.05.022. PMID: 16828770. Exclusion Code: X3.16828770
129 Kusters JG, Reuland EA, Bouter S, . A multiplex real-time PCR assay for routine diagnosis of bacterial vaginosis. Eur J Clin Microbiol Infect Dis. 2015 Sep;34(9):1779–85. doi: 10.1007/s10096-015-2412-z. PMID: 26117968. Exclusion Code: X5.26143346
130 Lambert JA, Kalra A, Dodge CT, . Novel PCR-based methods enhance characterization of vaginal microbiota in a bacterial vaginosis patient before and after treatment. Appl Environ Microbiol. 2013 Jul;79(13):4181–5. doi: 10.1128/aem.01160-13. PMID: 23624483. Exclusion Code: X7.23624483
131 Lamont RF, Hudson EA, Hay PE, . A comparison of the use of Papanicolaou-stained cervical cytological smears with Gram-stained vaginal smears for the diagnosis of bacterial vaginosis in early pregnancy. Int J STD AIDS. 1999 Feb;10(2):93–7. PMID: 10215113. Exclusion Code: X6.10215113
132 Lamont RF, Nhan-Chang CL, Sobel JD, . Treatment of abnormal vaginal flora in early pregnancy with clindamycin for the prevention of spontaneous preterm birth: a systematic review and metaanalysis. Am J Obstet Gynecol. 2011 Sep;205(3):177–90. doi: 10.1016/j.ajog.2011.03.047. PMID: 22071048. Exclusion Code: X1.22071048
133 Larsson P, Poutakidis G, Adolfsson A, . Treatment of bacterial vaginosis in early pregnancy and its effect on spontaneous preterm delivery and preterm premature rupture of membranes. Clin Microbiol. 2016;5(259):2. Exclusion Code: X8.
134 Larsson PG, Fahraeus L, Carlsson B, . Predisposing factors for bacterial vaginosis, treatment efficacy and pregnancy outcome among term deliveries; results from a preterm delivery study. BMC Womens Health. 2007 Oct 22;7:20. doi: 10.1186/1472-6874-7-20. PMID: 17510259. Exclusion Code: X8.17953762
135 Larsson PG, Forsum U. Bacterial vaginosis-a disturbed bacterial flora and treatment enigma. APMIS. 2005 May;113(5):305–16. doi: 10.1111/j.1600-0463.2005.apm_01.x. PMID: 16011656. Exclusion Code: X2.16011656
136 Leitich H, Brunbauer M, Bodner-Adler B, . Antibiotic treatment of bacterial vaginosis in pregnancy: a meta-analysis (structured abstract). Am J Obstet Gynecol. 2003;188(3):752–8. PMID: DARE-12003009527. Exclusion Code: X1.12634652
137 Levi AW, Harigopal M, Hui P, . Comparison of Affirm VPIII and Papanicolaou tests in the detection of infectious vaginitis. Am J Clin Pathol. 2011 Mar;135(3):442–7. doi: 10.1309/ajcp7tbn5vzuglzu. PMID: 20711427. Exclusion Code: X6.21350100
138 Libman MD, Kramer M, Platt R. Comparison of Gram and Kopeloff stains in the diagnosis of bacterial vaginosis in pregnancy. Diagn Microbiol Infect Dis. 2006 Mar;54(3):197–201. doi: 10.1016/j.diagmicrobio.2005.09.017. PMID: 17522586. Exclusion Code: X6.16427240
139 Lin DP, Pan BJ, Fuh JC, . Improving Gram-stained reproducible result by further adding clue cells in diagnosing bacterial vaginosis. Kaohsiung J Med Sci. 2002 Apr;18(4):164–70. PMID: 12164009. Exclusion Code: 13.12164009
140 London School of Hygiene. The effect of norethisterone enanthate on recurrent bacterial vaginosis. April 26, 2006. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02905890. NCT02905890. Exclusion Code: X3.
141 Lowe NK, Ryan-Wenger NA. A clinical test of women’s self-diagnosis of genitourinary infections. Clin Nurs Res. 2000 May;9(2):144–60. doi: 10.1177/105477380000900204. PMID: 12162239. Exclusion Code: X5.12162239
142 Loyprasert-Thananimit S, Kuasuwan P, Nittayaboon K, . Validity evaluation of in-house preparation kit, vaginal pH paper test combined amine tube test, for the simple diagnosis of bacterial vaginosis. J Med Assoc Thai. 2012 Jun;95(6):747–51. PMID: 23472099. Exclusion Code: X3.22774616
143 Luong ML, Libman M, Dahhou M, . Vaginal douching, bacterial vaginosis, and spontaneous preterm birth. J Obstet Gynaecol Can. 2010 Apr;32(4):313–20. doi: 10.1016/s1701-2163(16)34474-7. PMID: 21325838. Exclusion Code: X5.20500937
144 Machado A, Castro J, Cereija T, . Diagnosis of bacterial vaginosis by a new multiplex peptide nucleic acid fluorescence in situ hybridization method. PeerJ. 2015;3:e780. doi: 10.7717/peerj.780. PMID: 25737820. Exclusion Code: X5.25737820
145 Machado A, Cerca N. Multiplex peptide nucleic acid fluorescence in situ hybridization (PNA-FISH) for diagnosis of bacterial vaginosis. Methods Mol Biol. 2017;1616:209–19. doi: 10.1007/978-1-4939-7037-7_13. PMID: 28600771. Exclusion Code: X5.28600771
146 Makarova LN, Kravtsov EG, Vasil’eva EA, . Modern methods for diagnosis of Gardnerella infection. Bull Exp Biol Med. 2000 Aug;130(8):780–2. PMID: 11177243. Exclusion Code: X3.11177243
147 Malaguti N, Bahls LD, Uchimura NS, . Sensitive detection of thirteen bacterial vaginosis-associated agents using multiplex polymerase chain reaction. Biomed Res Int. 2015;2015:645853. doi: 10.1155/2015/645853. PMID: 24722380. Exclusion Code: X3.26078959
148 Mancuso MS, Figueroa D, Szychowski JM, . Midtrimester bacterial vaginosis and cervical length in women at risk for preterm birth. Am J Obstet Gynecol. 2011;204(4):342.e1–5. doi: 10.1016/j.ajog.2010.11.003. PMID: 21183154. Exclusion Code: X5.21183154
149 Marjan Industria e Comercio ltda. Efficacy and safety study of metronidazole, nystatin and dexamethasone combination therapy in bacterial and fungal vaginal infections. July 10, 2014. In ClinicalTrials.gov: . [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02186145. NCT02186145. Exclusion Code: X3.
150 Mastrobattista JM, Klebanoff MA, Carey JC, . The effect of body mass index on therapeutic response to bacterial vaginosis in pregnancy. Am J Perinatol. 2008 Apr;25(4):233–7. doi: 10.1055/s-2008-1066875. PMID: 18548397. Exclusion Code: X7.18548397
151 Mastromarino P, Vitali B, Mosca L. Bacterial vaginosis: a review on clinical trials with probiotics. New Microbiol. 2013;36(3):229–38. Exclusion Code: X5.23912864
152 Matijevic R, Grgic O, Knezevic M. Vaginal pH versus cervical length in the mid-trimester as screening predictors of preterm labor in a low-risk population. Int J Gynaecol Obstet. 2010 Oct;111(1):41–4. doi: 10.1016/j.ijgo.2010.05.011. PMID: 23496149. Exclusion Code: X5.20615503
153 McDonald HM, Brocklehurst P, Gordon A. Antibiotics for treating bacterial vaginosis in pregnancy. Cochrane Database Syst Rev. 2007;1(1). Exclusion Code: X1.
154 McNamee KM, Dawood F, Farquharson RG. Mid-trimester pregnancy loss. Obstet Gynecol Clin North Am. 2014 Mar;41(1):87–102. doi: 10.1016/j.ogc.2013.10.007. PMID: 24491985. Exclusion Code: X2.24491985
155 Medical University of South Carolina. Inflammation and treatment of bacterial vaginosis near term. July 22, 2008. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00720291. NCT00720291. Exclusion Code: X7.
156 Medicis Global Service Corporation. Safety and efficacy study to treat bacterial vaginosis. June 18, 2012. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01621399. NCT01621399. Exclusion Code: X4.
157 Medinova AG. Comparative study of efficacy of 10 mg dequalinium chloride (fluomizin) in the local treatment of bacterial vaginosis. May 18, 2010. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2008. Available from: https://ClinicalTrials.gov/show/NCT01125410. NCT01125410. Exclusion Code: X4.
158 Meis PJ, Goldenberg RL, Mercer B, . The preterm prediction study: significance of vaginal infections. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. 1995 Oct;173(4):1231–5. PMID: 7485327. Exclusion Code: X5.7485327
159 Menard JP, Fenollar F, Henry M, . Molecular quantification of Gardnerella vaginalis and Atopobium vaginae loads to predict bacterial vaginosis. Clin Infect Dis. 2008 Jul 1;47(1):33–43. doi: 10.1086/588661. PMID: 19920869. Exclusion Code: X5.18513147
160 Menard JP, Fenollar F, Raoult D, . Self-collected vaginal swabs for the quantitative real-time polymerase chain reaction assay of Atopobium vaginae and Gardnerella vaginalis and the diagnosis of bacterial vaginosis. Eur J Clin Microbiol Infect Dis. 2012 Apr;31(4):513–8. doi: 10.1007/s10096-011-1341-8. PMID: 22520996. Exclusion Code: X5.21789604
161 Menard JP, Mazouni C, Fenollar F, . Diagnostic accuracy of quantitative real-time PCR assay versus clinical and Gram stain identification of bacterial vaginosis. Eur J Clin Microbiol Infect Dis. 2010 Dec;29(12):1547–52. doi: 10.1007/s10096-010-1039-3. PMID: 21051846. Exclusion Code: X5.20814710
162 Menard JP, Mazouni C, Salem-Cherif I, . High vaginal concentrations of Atopobium vaginae and Gardnerella vaginalis in women undergoing preterm labor. Obstet Gynecol. 2010 Jan;115(1):134–40. doi: 10.1097/AOG.0b013e3181c391d7. PMID: 22082725. Exclusion Code: X5.20027045
163 Mendonca K, Costa C, Ricci V, . Enzymatic assay to test diamines produced by vaginal bacteria. New Microbiol. 2015 Apr;38(2):267–70. PMID: 25107710. Exclusion Code: X6.25938752
164 Minozzi M, Gerli S, Di Renzo GC, . The efficacy and safety of a single dose of polyhexamethylene biguanide gynaecologic solution versus a seven-dose regimen of vaginal clindamycin cream in patients with bacterial vaginosis. Eur Rev Med Pharmacol Sci. 2008 Jan–Feb;12(1):59–65. PMID: 18775597. Exclusion Code: X6.18401974
165 Mission Pharmacal. Treatment of bacterial vaginosis with oral tinidazole. September 29, 2005. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00229216. NCT00229216. Exclusion Code: X4.
166 Mitchell CM, Hitti JE, Agnew KJ, . Comparison of oral and vaginal metronidazole for treatment of bacterial vaginosis in pregnancy: impact on fastidious bacteria. BMC Infect Dis. 2009 Jun 10;9:89. doi: 10.1186/1471-2334-9-89. PMID: 19897689. Exclusion Code: X7.19515236
167 Miyoshi J, Ohba T, Ohkuma M, . Efficacy of a prospective community-based intervention to prevent preterm birth. J Perinat Med. 2017 Jan 1;45(1):113–9. doi: 10.1515/jpm-2015-0408. PMID: 27089398. Exclusion Code: X8.27089398
168 Mohammadzadeh F, Dolatian M, Jorjani M, . Diagnostic value of Amsel’s clinical criteria for diagnosis of bacterial vaginosis. Glob J Health Sci. 2014 Oct 29;7(3):8–14. doi: 10.5539/gjhs.v7n3p8. PMID: 26204200. Exclusion Code: X3.26204200
169 Moniri R, Behrashi M. Effects of metronidazole therapy on preterm labor in women with bacterial vaginosis. Acta Med Iran. 2009;47(3):181–4. Exclusion Code: X3.
170 Montse Palacio. Bacterial vaginosis in pregnancy: detection by weekly vaginal pH testing. December 1, 2008. In ClinicalTrials.gov: . [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00799500. NCT00799500. Exclusion Code: X14.
171 Morton AN, Bradshaw CS, Fairley CK. Changes in the diagnosis and management of bacterial vaginosis following clinical research. Sex Health. 2006 Sep;3(3):183–5. PMID: 17470593. Exclusion Code: X5.17044224
172 Mulhem E, Boyanton BL, Jr., Robinson-Dunn B, . Performance of the Affirm VP-III using residual vaginal discharge collected from the speculum to characterize vaginitis in symptomatic women. J Low Genit Tract Dis. 2014 Oct;18(4):344–6. doi: 10.1097/lgt.0000000000000025. PMID: 24832170. Exclusion Code: X6.24832170
173 Nadeau HC, Subramaniam A, Andrews WW. Infection and preterm birth. Semin Fetal Neonatal Med. 2016 Apr;21(2):100–5. doi: 10.1016/j.siny.2015.12.008. PMID: 26778525. Exclusion Code: X2.26778525
174 Nailor MD, Sobel JD. Tinidazole for bacterial vaginosis. Expert Rev Anti Infect Ther. 2007 Jun;5(3):343–8. doi: 10.1586/14787210.5.3.343. PMID: 17202272. Exclusion Code: X9.17547500
175 Nailor MD, Sobel JD. Tinidazole for the treatment of vaginal infections. Expert Opin Investig Drugs. 2007 May;16(5):743–51. doi: 10.1517/13543784.16.5.743. PMID: 16307744. Exclusion Code: X5.16307744
176 Nath K, Sarosy JW, Stylianou SP. Suitability of a unique 16S rRNA gene PCR product as an indicator of Gardnerella vaginalis. Biotechniques. 2000 Feb;28(2):222–4, 6. PMID: 10683728. Exclusion Code: X7.10683728
177 National Institute of Allergy and Infectious Diseases. Safety and efficacy of 5% monolaurin vaginal gel administered intravaginally for the treatment of bacterial vaginosis. March 15, 2016. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2017. Available from: https://ClinicalTrials.gov/show/NCT02709005. NCT02709005. Exclusion Code: X4.
178 Nelson DB. Treatment and management of bacterial vaginosis in pregnancy: current and future perspectives. Womens Health (Lond). 2006 Mar;2(2):267–77. doi: 10.2217/17455057.2.2.267. PMID: 16490998. Exclusion Code: X2.19803898
179 Nelson DB, Bellamy S, Clothier BA, . Characteristics and pregnancy outcomes of pregnant women asymptomatic for bacterial vaginosis. Matern Child Health J. 2008 Mar;12(2):216–22. doi: 10.1007/s10995-007-0239-7. PMID: 19750853. Exclusion Code: X8.17546484
180 Nelson DB, Bellamy S, Gray TS, . Self-collected versus provider-collected vaginal swabs for the diagnosis of bacterial vaginosis: an assessment of validity and reliability. J Clin Epidemiol. 2003 Sep;56(9):862–6. PMID: 14505771. Exclusion Code: X5.14505771
181 Nelson DB, Bellamy S, Nachamkin I, . First trimester bacterial vaginosis, individual microorganism levels, and risk of second trimester pregnancy loss among urban women. Fertil Steril. 2007 Nov;88(5):1396–403. doi: 10.1016/j.fertnstert.2007.01.035. PMID: 18844645. Exclusion Code: X5.17434499
182 Nelson DB, Bellamy S, Odibo A, . Vaginal symptoms and bacterial vaginosis (BV): how useful is self-report? Development of a screening tool for predicting BV status. Epidemiol Infect. 2007 Nov;135(8):1369–75. doi: 10.1017/s095026880700787x. PMID: 17532736. Exclusion Code: X5.17274857
183 Nelson DB, Hanlon A, Hassan S, . Preterm labor and bacterial vaginosis-associated bacteria among urban women. J Perinat Med. 2009;37(2):130–4. doi: 10.1515/jpm.2009.026. PMID: 18591634. Exclusion Code: X5.18999913
184 Nelson DB, Hanlon A, Nachamkin I, . Early pregnancy changes in bacterial vaginosis-associated bacteria and preterm delivery. Paediatr Perinat Epidemiol. 2014 Mar;28(2):88–96. doi: 10.1111/ppe.12106. PMID: 25518272. Exclusion Code: X5.24405280
185 Nelson DB, Hanlon AL, Wu G, . First trimester levels of BV-associated bacteria and risk of miscarriage among women early in pregnancy. Matern Child Health J. 2015 Dec;19(12):2682–7. doi: 10.1007/s10995-015-1790-2. PMID: 26156825. Exclusion Code: X7.26156825
186 Nelson DB, Komaroff E, Nachamkin I, . Relationship of selected bacterial vaginosis-associated bacteria to Nugent score bacterial vaginosis among urban women early in pregnancy. Sex Transm Dis. 2013 Sep;40(9):721–3. doi: 10.1097/olq.0000000000000001. PMID: 22535982. Exclusion Code: X5.23945426
187 Nenadic DB, Pavlovic MD. Cervical fluid cytokines in pregnant women: relation to vaginal wet mount findings and polymorphonuclear leukocyte counts. Eur J Obstet Gynecol Reprod Biol. 2008 Oct;140(2):165–70. doi: 10.1016/j.ejogrb.2008.02.020. PMID: 18406509. Exclusion Code: X5.18406509
188 Nenadic DB, Pavlovic MD, Motrenko T. A novel microscopic method for analyzing Gram-stained vaginal smears in the diagnosis of disorders of vaginal microflora. Vojnosanit Pregl. 2015 Aug;72(8):670–6. PMID: 24521723. Exclusion Code: X6.26495692
189 Nigro G, Mazzocco M, Mattia E, . Role of the infections in recurrent spontaneous abortion. J Matern Fetal Neonatal Med. 2011 Aug;24(8):983–9. doi: 10.3109/14767058.2010.547963. PMID: 21397086. Exclusion Code: X7.21261443
190 Novakov Mikic A, Stojic S. Study results on the use of different therapies for the treatment of vaginitis in hospitalised pregnant women. Arch Gynecol Obstet. 2015 Aug;292(2):371–6. doi: 10.1007/s00404-015-3638-9. PMID: 25651828. Exclusion Code: X5.25651828
191 Nunns D, Mandal D, Farrand RJ, . A comparison of acridine orange, wet microscopy and Gram staining in the diagnosis of bacterial vaginosis. J Infect. 1997 May;34(3):211–3. PMID: 9200027. Exclusion Code: X6.9200027
192 Nwankwo TO, Aniebue UU, Umeh UA. Syndromic diagnosis in evaluation of women with symptoms of vaginitis. Curr Infect Dis Rep. 2017 Jan;19(1):3. doi: 10.1007/s11908-017-0558-9. PMID: 28210940. Exclusion Code: X5.28210940
193 Nygren P, Fu R, Freeman M, . Evidence on the benefits and harms of screening and treating pregnant women who are asymptomatic for bacterial vaginosis: an update review for the U.S. Preventive Services Task Force. Ann Intern Med. 2008 Feb 5;148(3):220–33. doi: 10.7326/0003-4819-148-3-200802050-00008. PMID: 18758800. Exclusion Code: X1.18252684
194 Nyirjesy P, McIntosh M, Steinmetz J, . The effects of intravaginal clindamycin and metronidazole therapy on vaginal mobiluncus morphotypes in patients with bacterial vaginosis. Sex Transm Dis. 2007;34(4):197–202. doi: 10.1097/01.olq.0000235152.98601.d7. PMID: CN-00577377. Exclusion Code: X4.17179772
195 Nyirjesy P, McIntosh MJ, Gattermeir DJ, . The effects of intravaginal clindamycin and metronidazole therapy on vaginal lactobacilli in patients with bacterial vaginosis. Am J Obstet Gynecol. 2006 May;194(5):1277–82. doi: 10.1016/j.ajog.2005.11.006. PMID: 17010117. Exclusion Code: X4.16647910
196 Obata-Yasuoka M, Ba-Thein W, Hamada H, . A multiplex polymerase chain reaction-based diagnostic method for bacterial vaginosis. Obstet Gynecol. 2002 Oct;100(4):759–64. PMID: 12383546. Exclusion Code: X5.12383546
197 Obiero J, Rulisa S, Ogongo P, . Nifuratel-Nystatin combination for the treatment of mixed infections of bacterial vaginosis, vulvovaginal candidiasis, and trichomonal vaginitis. Cochrane Database Syst Rev. 2018;2018(4). doi: 10.1002/14651858.CD013012. Exclusion Code: X5.
198 O’Brien RF. Bacterial vaginosis: many questions-any answers? Curr Opin Pediatr. 2005 Aug;17(4):473–9. PMID: 16012258. Exclusion Code: X2.16012258
199 O’Dowd TC, West RR, Winterburn PJ, . Evaluation of a rapid diagnostic test for bacterial vaginosis. Br J Obstet Gynaecol. 1996 Apr;103(4):366–70. PMID: 8605135. Exclusion Code: X7.8605135
200 Oduyebo OO, Anorlu RI, Ogunsola FT. The effects of antimicrobial therapy on bacterial vaginosis in non-pregnant women. Cochrane Database Syst Rev. 2009 Jul 8(3):CD006055. doi: 10.1002/14651858.CD006055.pub2. PMID: 19588379. Exclusion Code: X4.19588379
201 Okun N, Gronau KA, Hannah ME. Antibiotics for bacterial vaginosis or Trichomonas vaginalis in pregnancy: a systematic review (structured abstract). Obstet Gynecol. 2005;105(4):857–68. PMID: DARE-12005009900. Exclusion Code: X1.15802417
202 Okwoli RN, Adinma JL, Nnaeze CN. Laboratory diagnosis of Gardnerella vaginalis vaginosis. West Afr J Med. 2002 Jul–Sep;21(3):244–7. PMID: 12744579. Exclusion Code: X3.12744579
203 Oliver RS, Lamont RF. Infection and antibiotics in the aetiology, prediction and prevention of preterm birth. J Obstet Gynaecol. 2013 Nov;33(8):768–75. doi: 10.3109/01443615.2013.842963. PMID: 24219711. Exclusion Code: X2.24219711
204 Oswaldo Cruz Foundation. Probiotics for the prevention of premature birth and neonatal related morbidity. March 15, 2006. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2009. Available from: https://ClinicalTrials.gov/show/NCT00303082. NCT00303082. Exclusion Code: X3.
205 Othman M, Alfirevic Z, Neilson JP. Probiotics for preventing preterm labour. In Cochrane Database Syst Rev Exclusion Code: X5.
206 Peking University Shenzhen Hospital. Oral metronidazole with lactobacillus vaginal suppositories to prevent recurrence of bacterial vaginosis. April 4, 2017. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT03099408. NCT03099408. Exclusion Code: X4.
207 Perlamutrov Y, Gomberg M, Chernova N, . A comparative efficacy of nifuratel and metronidazole in therapy of bacterial vaginosis associated with atopobium vaginae. In Sex Transm Infect Exclusion Code: X4.
208 Perote-Pedroso J, Castro V. Regular vaginal ph screening in the diagnosis of bacterial vaginosis in pregnancy and its impact on the incidence of preterm deliveries. Int J Gynaecol Obstet. 2015;131:E550–e1. PMID: CN-01106611. Exclusion Code: X3.
209 Petersen CS, Danielsen AG, Renneberg J. Direct or referral microscopy of vaginal wet smear for bacterial vaginosis: experience from an STD clinic. Acta Derm Venereol. 1999 Nov;79(6):473–4. PMID: 10598765. Exclusion Code: X6.10598765
210 Petrikkos GL, Hadjisoteriou M, Daikos GL. PCR versus culture in the detection of vaginal Ureaplasma urealyticum and Mycoplasma hominis. Int J Gynaecol Obstet. 2007 Jun;97(3):202–3. doi: 10.1016/j.ijgo.2006.12.014. PMID: 17822329. Exclusion Code: X5.17368648
211 Plummer EL, Garland SM, Bradshaw CS, . Molecular diagnosis of bacterial vaginosis: does adjustment for total bacterial load or human cellular content improve diagnostic performance? J Microbiol Methods. 2017 Feb;133:66–8. doi: 10.1016/j.mimet.2016.12.024. PMID: 28042056. Exclusion Code: X7.28042056
212 Plummer EL, Vodstrcil LA, Danielewski JA, . Combined oral and topical antimicrobial therapy for male partners of women with bacterial vaginosis: acceptability, tolerability and impact on the genital microbiota of couples - a pilot study. PLoS One. 2018;13(1). doi: 10.1371/journal.pone.0190199. Exclusion Code: X4.
213 Potter B, Jhorden L, Porter M. Clinical inquiries. Should we screen for bacterial vaginosis in asymptomatic patients at risk for preterm labor? J Fam Pract. 2004 Oct;53(10):827–31. PMID: 15469780. Exclusion Code: X2.
214 Powell AM, Nyirjesy P. Recurrent vulvovaginitis. Best Pract Res Clin Obstet Gynaecol. 2014 Oct;28(7):967–76. doi: 10.1016/j.bpobgyn.2014.07.006. PMID: 25220102. Exclusion Code: X2.25220102
215 Pratiksha G, Neha A, Anju H, . Significance of bacterial vaginosis and periodontal infection as predictors of preterm labor. Bangladesh J Med Science. 2016;15(3):441–9. doi: 10.3329/bjms.v15i3.14888. PMID: CN-01248237. Exclusion Code: X3.
216 Pretorius C, Jagatt A, Lamont RF. The relationship between periodontal disease, bacterial vaginosis, and preterm birth. J Perinat Med. 2007;35(2):93–9. doi: 10.1515/jpm.2007.039. PMID: 16643824. Exclusion Code: X2.17343541
217 Prey M. Routine Pap smears for the diagnosis of bacterial vaginosis. Diagn Cytopathol. 1999 Jul;21(1):10–3. PMID: 10405800. Exclusion Code: X5.10405800
218 Pruski P, MacIntyre DA, Lewis HV, . Medical swab analysis using desorption electrospray ionization mass spectrometry: a noninvasive approach for mucosal diagnostics. Anal Chem. 2017 Feb 7;89(3):1540–50. doi: 10.1021/acs.analchem.6b03405. PMID: 28208268. Exclusion Code: X5.28208268
219 Quan M. Vaginitis: diagnosis and management. Postgrad Med. 2010 Nov;122(6):117–27. doi: 10.3810/pgm.2010.11.2229. PMID: 21350100. Exclusion Code: X2.21084788
220 Raja I, Basavareddy A, Mukherjee D, . Randomized, double-blind, comparative study of oral metronidazole and tinidazole in treatment of bacterial vaginosis. Indian J Pharmacol. 2016;48(6):654–8. doi: 10.4103/0253-7613.194843. PMID: CN-01289976. Exclusion Code: X3.28066102
221 Redelinghuys MJ, Ehlers MM, Dreyer AW, . Normal flora and bacterial vaginosis in pregnancy: an overview. Crit Rev Microbiol. 2016;42(3):352–63. Exclusion Code: X2.25834920
222 Regionshospitalet Viborg, Skive. PNA FISH, PCR and gram staining for detection of bacterial vaginosis - a comparative clinical study in a Danish IVF setting. January 22, 2014. In ClinicalTrials.gov: . [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02042352. NCT02042352. Exclusion Code: X4.
223 Reid F, Oakeshott P, Kerry SR, . Chlamydia related bacteria (Chlamydiales) in early pregnancy: community-based cohort study. Clin Microbiol Infect. 2017 Feb;23(2):119.e9–.e14. doi: 10.1016/j.cmi.2016.10.011. PMID: 27773758. Exclusion Code: X5.27773758
224 Reid G, Burton J, Hammond JA, . Nucleic acid-based diagnosis of bacterial vaginosis and improved management using probiotic lactobacilli. J Med Food. 2004 Summer;7(2):223–8. doi: 10.1089/1096620041224166. PMID: 15298771. Exclusion Code: X5.15298771
225 Rein MF, Shih LM, Miller JR, . Use of a lactoferrin assay in the differential diagnosis of female genital tract infections and implications for the pathophysiology of bacterial vaginosis. Sex Transm Dis. 1996 Nov–Dec;23(6):517–21. PMID: 8946639. Exclusion Code: X5.8946639
226 Rittenschober-Bohm J, Waldhoer T, Schulz SM, . First trimester vaginal ureaplasma biovar colonization and preterm birth: results of a prospective multicenter study. Neonatology. 2018;113(1):1–6. doi: 10.1159/000480065. PMID: 28934751. Exclusion Code: X5.28934751
227 Rodrigues FS, Peixoto S, Adami F, . Proposal of a new cutoff for Nugent criteria in the diagnosis of bacterial vaginosis. J Microbiol Methods. 2015 Aug;115:144–6. doi: 10.1016/j.mimet.2015.05.006. PMID: 26001874. Exclusion Code: X3.25957514
228 Roeters AM, Boon ME, van Haaften M, . Inflammatory events as detected in cervical smears and squamous intraepithelial lesions. Diagn Cytopathol. 2010 Feb;38(2):85–93. doi: 10.1002/dc.21169. PMID: 21384783. Exclusion Code: X4.19795485
229 Rossi A, Rossi T, Bertini M, . The use of Lactobacillus rhamnosus in the therapy of bacterial vaginosis. Evaluation of clinical efficacy in a population of 40 women treated for 24 months. Arch Gynecol Obstet. 2010 Jun;281(6):1065–9. doi: 10.1007/s00404-009-1287-6. PMID: 20644497. Exclusion Code: X5.20012637
230 Rumyantseva TA, Bellen G, Romanuk TN, . Utility of microscopic techniques and quantitative real-time polymerase chain reaction for the diagnosis of vaginal microflora alterations. J Low Genit Tract Dis. 2015 Apr;19(2):124–8. doi: 10.1097/lgt.0000000000000060. PMID: 25023332. Exclusion Code: X3.25023332
231 Ryan-Wenger NA, Neal JL, Jones AS, . Accuracy of vaginal symptom self-diagnosis algorithms for deployed military women. Nurs Res. 2010 Jan–Feb;59(1):2–10. doi: 10.1097/NNR.0b013e3181c3b9dd. PMID: 20461391. Exclusion Code: X6.20010039
232 Sagawa T, Negishi H, Kishida T, . Vaginal and cervical pH in bacterial vaginosis and cervicitis during pregnancy. Hokkaido Igaku Zasshi. 1995 Nov;70(6):839–46. PMID: 8582707. Exclusion Code: X7.8582707
233 Saharan SP, Surve C, Raut V, . Diagnosis and prevalence of bacterial vaginosis. J Postgrad Med. 1993 Apr–Jun;39(2):72–3. PMID: 8169866. Exclusion Code: X3.8169866
234 Sangkomkamhang US, Lumbiganon P, Prasertcharoensuk W, . Antenatal lower genital tract infection screening and treatment programs for preventing preterm delivery. Cochrane Database Syst Rev. 2015(2). doi: 10.1002/14651858.CD006178.pub3. PMID: CD006178. Exclusion Code: X1.
235 Sanu O, Lamont RF. Periodontal disease and bacterial vaginosis as genetic and environmental markers for the risk of spontaneous preterm labor and preterm birth. J Matern Fetal Neonatal Med. 2011 Dec;24(12):1476–85. doi: 10.3109/14767058.2010.545930. PMID: 21944221. Exclusion Code: X5.21261445
236 Schellenberg J, Blake Ball T, Lane M, . Flow cytometric quantification of bacteria in vaginal swab samples self-collected by adolescents attending a gynecology clinic. J Microbiol Methods. 2008 Jun;73(3):216–26. doi: 10.1016/j.mimet.2008.03.004. PMID: 18423913. Exclusion Code: X5.18423913
237 Schmidt H, Hansen JG. Diagnosis of bacterial vaginosis by wet mount identification of bacterial morphotypes in vaginal fluid. Int J STD AIDS. 2000 Mar;11(3):150–5. doi: 10.1258/0956462001915589. PMID: 10726936. Exclusion Code: X5.10726936
238 Schmidt H, Hansen JG. Validity of wet-mount bacterial morphotype identification of vaginal fluid by phase-contrast microscopy for diagnosis of bacterial vaginosis in family practice. APMIS. 2001 Sep;109(9):589–94. PMID: 11878711. Exclusion Code: X5.11878711
239 Schmitt M, Depuydt C, Stalpaert M, . Bead-based multiplex sexually transmitted infection profiling. J Infect. 2014 Aug;69(2):123–33. doi: 10.1016/j.jinf.2014.04.006. PMID: 24814157. Exclusion Code: X5.24814157
240 Schwebke, Jr., Desmond R. Tinidazole vs metronidazole for the treatment of bacterial vaginosis. In Am J Obstet Gynecol Exclusion Code: X6.
241 Schwebke, Jr., Marrazzo J, Beelen A, . A Phase 3, Multicenter, Randomized, Double-Blind, Vehicle-Controlled Study Evaluating the Safety and Efficacy of Metronidazole Vaginal Gel 1.3% in the Treatment of Bacterial Vaginosis. Sex Transm Dis. 2015;42(7):376–81. doi: 10.1097/OLQ.0000000000000300. PMID: CN-01162024. Exclusion Code: X4.26222750
242 Schwebke J. The Women’s Health II Medical Education Network _Part 1: Understanding bacterial vaginosis: diagnosis, treatment, and improved outcomes. J Fam Pract. 2007 Sep;56(9 Suppl Women):S1–6; quiz S7-8. PMID: 16543864. Exclusion Code: X2.16543864
243 Schwebke JR. Diagnostic methods for bacterial vaginosis. Int J Gynaecol Obstet. 1999 Nov;67: Suppl 1:S21–3. PMID: 10661732. Exclusion Code: X2.10661732
244 Schwebke JR, Lee JY, Lensing S, . Home screening for bacterial vaginosis to prevent sexually transmitted diseases. Clin Infect Dis. 2016 Mar 01;62(5):531–6. doi: 10.1093/cid/civ975. PMID: 26611782. Exclusion Code: X4.26611782
245 Schwiertz A, Taras D, Rusch K, . Throwing the dice for the diagnosis of vaginal complaints? Ann Clin Microbiol Antimicrob. 2006 Feb 17;5:4. doi: 10.1186/1476-0711-5-4. PMID: 17687006. Exclusion Code: X6.16503990
246 Secor M, Coughlin G. Bacterial vaginosis update. Adv NPs PAs. 2013 Aug;4(8):23–6. PMID: 24120172. Exclusion Code: X2.24120172
247 Selim SA, El Alfy SM, Aziz MH, . Effective of metronidazole to bacterial flora in vagina and the impact of microbes on live birth rate during intracytoplasmic sperm injection (ICSI). Arch Gynecol Obstet. 2011 Dec;284(6):1449–53. doi: 10.1007/s00404-011-1857-2. PMID: 20221621. Exclusion Code: X3.21331540
248 Shaaban O, Fetih G, Abdellah N, . Pilot randomized trial for treatment of bacterial vaginosis using in situ forming metronidazole vaginal gel. J Obstet Gynaecol Res. 2011;37(7):874–81. doi: 10.1111/j.1447-0756.2010.01457.x. PMID: CN-00812330. Exclusion Code: X3.21410839
249 Sheehy O, Santos F, Ferreira E, . The use of metronidazole during pregnancy: a review of evidence. Curr Drug Saf. 2015;10(2):170–9. PMID: 26544959. Exclusion Code: X1.25986038
250 Sheiness D, Dix K, Watanabe S, . High levels of Gardnerella vaginalis detected with an oligonucleotide probe combined with elevated pH as a diagnostic indicator of bacterial vaginosis. J Clin Microbiol. 1992 Mar;30(3):642–8. PMID: 1372621. Exclusion Code: X5.1372621
251 Shennan A, Crawshaw S, Briley A, . A randomised controlled trial of metronidazole for the prevention of preterm birth in women positive for cervicovaginal fetal fibronectin: the PREMET Study. BJOG. 2006 Jan;113(1):65–74. doi: 10.1111/j.1471-0528.2005.00788.x. Exclusion Code: X7.16398774
252 Shipitsyna E, Roos A, Datcu R, . Composition of the vaginal microbiota in women of reproductive age-sensitive and specific molecular diagnosis of bacterial vaginosis is possible? PLoS One. 2013;8(4):e60670. doi: 10.1371/journal.pone.0060670. PMID: 22774616. Exclusion Code: X5.23585843
253 Shujatullah F, Khan HM, Khatoon R, . An evaluation of OSOM BV blue test in the diagnosis of bacterial vaginosis. Asian Pac J Trop Med. 2010;3(7):574–6. doi: 10.1016/S1995-7645(10)60139-3. Exclusion Code: X3.
254 Simcox R, Sin WT, Seed PT, . Prophylactic antibiotics for the prevention of preterm birth in women at risk: a meta-analysis. Aust N Z J Obstet Gynaecol. 2007 Oct;47(5):368–77. doi: 10.1111/j.1479-828X.2007.00759.x. PMID: 17877593. Exclusion Code: X1.17877593
255 Simoes JA, Discacciati MG, Brolazo EM, . Clinical diagnosis of bacterial vaginosis. Int J Gynaecol Obstet. 2006 Jul;94(1):28–32. doi: 10.1016/j.ijgo.2006.04.013. PMID: 16817083. Exclusion Code: X3.16756982
256 Skaraborg Hospital. Treatment of bacterial vaginosis in early pregnancy in skaraborg and the effect on spontaneous preterm delivery. January 28, 2015. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02348463. NCT02348463. Exclusion Code: X9.
257 Skaraborg Hospital. Treatment of bacterial vaginosis combined with human lactobacilli. November 22, 2010. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01245322. NCT01245322. Exclusion Code: X4.
258 Skaraborg Hospital. Will vaginal colonization of lactobacillus increase cure rate after treatment of bacterial vaginosis and chronic vulvovaginal candida. November 20, 2014. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02295579. NCT02295579. Exclusion Code: X4.
259 Smayevsky J, Canigia LF, Lanza A, . Vaginal microflora associated with bacterial vaginosis in nonpregnant women: reliability of sialidase detection. Infect Dis Obstet Gynecol. 2001;9(1):17–22. doi: 10.1155/s1064744901000047. PMID: 11368254. Exclusion Code: X6.11368254
260 Sobel JD. Antibiotic consideration in bacterial vaginosis. Curr Infect Dis Rep. 2009 Nov;11(6):471–5. PMID: 19743911. Exclusion Code: X2.19857387
261 Sobel JD, Ferris D, Schwebke J, . Suppressive antibacterial therapy with 0.75% metronidazole vaginal gel to prevent recurrent bacterial vaginosis. Am J Obstet Gynecol. 2006 May;194(5):1283–9. doi: 10.1016/j.ajog.2005.11.041. PMID: 16517914. Exclusion Code: X4.16647911
262 Sobel JD, Hay P. Diagnostic techniques for bacterial vaginosis and vulvovaginal candidiasis - requirement for a simple differential test. Expert Opin Med Diagn. 2010 Jul;4(4):333–41. doi: 10.1517/17530059.2010.488688. PMID: 20027045. Exclusion Code: X2.23496149
263 Sobel JD, Karpas Z, Lorber A. Diagnosing vaginal infections through measurement of biogenic amines by ion mobility spectrometry. Eur J Obstet Gynecol Reprod Biol. 2012 Jul;163(1):81–4. doi: 10.1016/j.ejogrb.2012.03.022. PMID: 23745304. Exclusion Code: X5.22520996
264 Sobel JD, Nyirjesy P, Kessary H, . Use of the VS-sense swab in diagnosing vulvovaginitis. J Womens Health (Larchmt). 2009 Sep;18(9):1467–70. doi: 10.1089/jwh.2008.1305. PMID: 18226677. Exclusion Code: X7.19743911
265 Sobel R, Sobel JD. Metronidazole for the treatment of vaginal infections. Expert Opin Pharmacother. 2015 May;16(7):1109–15. doi: 10.1517/14656566.2015.1035255. PMID: 25887246. Exclusion Code: X2.25887246
266 Sodhani P, Garg S, Bhalla P, . Prevalence of bacterial vaginosis in a community setting and role of the pap smear in its detection. Acta Cytol. 2005 Nov–Dec;49(6):634–8. doi: 10.1159/000326251. PMID: 16450903. Exclusion Code: X3.16450903
267 Song Y, He L, Zhou F, . Segmentation, splitting, and classification of overlapping bacteria in microscope images for automatic bacterial vaginosis diagnosis. IEEE J Biomed Health Inform. 2017 Jul;21(4):1095–104. doi: 10.1109/jbhi.2016.2594239. PMID: 27479982. Exclusion Code: X5.27479982
268 Starpharma Pty Ltd. A phase 3 study of SPL7013 gel (VivaGel) for the treatment of bacterial vaginosis. April 16, 2012. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01577537. NCT01577537. Exclusion Code: X5.
269 Storti-Filho A, Estivalet Svidizinski TI, da Silva Souza RJ, . Oncotic colpocytology stained with Harris-Shorr in the observation of vaginal microorganisms. Diagn Cytopathol. 2008 Jun;36(6):358–62. doi: 10.1002/dc.20820. PMID: 19857387. Exclusion Code: X3.18478612
270 Sturm PD, Moodley P, Nzimande G, . Diagnosis of bacterial vaginosis on self-collected vaginal tampon specimens. Int J STD AIDS. 2002 Aug;13(8):559–63. doi: 10.1258/095646202760159693. PMID: 12194740. Exclusion Code: X3.12194740
271 Subtil D, Brabant G, Tilloy E, . Early clindamycin for bacterial vaginosis in low-risk pregnancy: the PREMEVA1 randomized, multicenter, double-blind, placebo-controlled trial. Am J Obstet Gynecol. 2014;210(1 suppl. 1):S3. doi: 10.1016/j.ajog.2013.10.036. PMID: CN-01062100. Exclusion Code: X9.
272 Sungkar A, Purwosunu Y, Aziz M, . Influence of early self-diagnosis and treatment of bacterial vaginosis on preterm birth rate. Int J Gynaecol Obstet. 2012;117(3):264–7. doi: 10.1016/j.ijgo.2012.01.007. PMID: CN-00880779. Exclusion Code: X3.22445423
273 Swadpanich U, Lumbiganon P, Prasertcharoensook W, . Antenatal lower genital tract infection screening and treatment programs for preventing preterm delivery. Cochrane Database Syst Rev. 2008 Apr 16(2):Cd006178. doi: 10.1002/14651858.CD006178.pub2. PMID: 18425940. Exclusion Code: X1.18425940
274 Symbiomix Therapeutics. Open-label study to evaluate the safety of a single dose of SYM-1219, a granule formulation containing 2 grams of secnidazole. May 25, 2015. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02452866. NCT02452866. Exclusion Code: X4.
275 Symbiomix Therapeutics. A phase 3 study of SYM-1219 treatment of women and post-menarchal adolescent girls with bacterial vaginosis. April 16, 2015. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2015. Available from: https://ClinicalTrials.gov/show/NCT02418845. NCT02418845. Exclusion Code: X4.
276 Taha T, Kumwenda N, Kafulafula G, . Intermittent intravaginal antibiotic treatment of bacterial vaginosis in HIV-uninfected and -infected women: a randomized clinical trial. PLoS Clin Trials. 2007;2(2):e10TN: NCT00140764/ClinicalTrials.gov. doi: 10.1371/journal.pctr.0020010. PMID: CN-00641463. Exclusion Code: X3.17318258
277 Taj U, Javeria M, Hanif A. Comparison of intravaginal versus oral metronidazole in the treatment of bacterial vaginosis in obstetrical patients. Pakistan J Med Health Sciences. 2017;11(2):519–22. PMID: CN-01403512. Exclusion Code: X3.
278 Tam MT, Yungbluth M, Myles T. Gram stain method shows better sensitivity than clinical criteria for detection of bacterial vaginosis in surveillance of pregnant, low-income women in a clinical setting. Infect Dis Obstet Gynecol. 1998;6(5):204–8. doi: 10.1155/s1064744998000416. PMID: 9894174. Exclusion Code: X6.9894174
279 Tan H, Fu Y, Yang C, . Effects of metronidazole combined probiotics over metronidazole alone for the treatment of bacterial vaginosis: a meta-analysis of randomized clinical trials. Arch Gynecol Obstet. 2017 Jun;295(6):1331–9. doi: 10.1007/s00404-017-4366-0. PMID: 28386675. Exclusion Code: X4.28386675
280 Taylor-Robinson D, Morgan DJ, Sheehan M, . Relation between Gram-stain and clinical criteria for diagnosing bacterial vaginosis with special reference to Gram grade II evaluation. Int J STD AIDS. 2003;14(1):6. Exclusion Code: X6.
281 Teva Pharmaceuticals USA. Bioequivalence of metronidazole gel, 0.75% in the treatment of bacterial vaginosis. November 25, 2009. In ClinicalTrials.gov. [cited December 3, 2018]. Bethesda, MD: National Library of Medicine. 2003. Available from: https://ClinicalTrials.gov/show/NCT01020396. NCT01020396. Exclusion Code: X4.
282 Thinkhamrop J, Hofmeyr GJ, Adetoro O, . Antibiotic prophylaxis during the second and third trimester to reduce adverse pregnancy outcomes and morbidity. Cochrane Database Syst Rev. 2015 Jun 20(6):Cd002250. doi: 10.1002/14651858.CD002250.pub3. PMID: 26092137. Exclusion Code: X1.26092137
283 Thomason JL, Anderson RJ, Gelbart SM, . Simplified gram stain interpretive method for diagnosis of bacterial vaginosis. Am J Obstet Gynecol. 1992 Jul;167(1):16–9. PMID: 1279973. Exclusion Code: X5.1279973
284 Thompson C, McCabe K. An audit of the value of microscopy of gram-stained and wet film preparations for the diagnosis of bacterial vaginosis in a department of genitourinary medicine. Int J STD AIDS. 1994 Jan–Feb;5(1):69–70. PMID: 8142535. Exclusion Code: X6.8142535
285 Thulkar J, Kriplani A, Agarwal N. Utility of pH test & Whiff test in syndromic approach of abnormal vaginal discharge. Indian J Med Res. 2010;131(3):445–8. Exclusion Code: X320418561
286 Tokyol C, Aktepe OC, Cevrioglu AS, . Bacterial vaginosis: comparison of Pap smear and microbiological test results. Mod Pathol. 2004 Jul;17(7):857–60. doi: 10.1038/modpathol.3800132. PMID: 15073605. Exclusion Code: X3.15073605
287 Tosun I, Aydin F, Kaklikkaya N, . Frequency of bacterial vaginosis among women attending for intrauterine device insertion at an inner-city family planning clinic. Eur J Contracept Reprod Health Care. 2003 Sep;8(3):135–8. PMID: 14667323. Exclusion Code: X3.14667323
288 Udayalaxm, Bhat G, Kotigadde S, . Comparison of the methods of diagnosis of bacterial vaginosis. Journal of Clinical and Diagnostic Research. 2011;5(3):498–501. Exclusion Code: X3
289 Ugwumadu A. Role of antibiotic therapy for bacterial vaginosis and intermediate flora in pregnancy. Best Pract Res Clin Obstet Gynaecol. 2007 Jun;21(3):391–402. doi: 10.1016/j.bpobgyn.2007.01.001. PMID: 16492583. Exclusion Code: X2.17512255
290 Ugwumadu A, Reid F, Hay P, . Oral clindamycin and histologic chorioamnionitis in women with abnormal vaginal flora. Obstet Gynecol. 2006 Apr;107(4):863–8. doi: 10.1097/01.Aog.0000202399.13074.98. PMID: 16517046. Exclusion Code: X7.16582124
291 University Hospital, Lille. Prevention of very preterm delivery by testing for and treatment of bacterial vaginosis. March 25, 2008. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00642980. NCT00642980. Exclusion Code: X9.
292 University of Alabama at Birmingham. Treatment of bacterial vaginosis. May 11, 2006. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00324818. NCT00324818. Exclusion Code: X4.
293 University of Alabama at Birmingham. Treatment of bacterial vaginosis (BV) with tinidazole. June 23, 2011. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00334633. NCT00334633. Exclusion Code: X4.
294 University of Alabama at Birmingham. Randomized controlled trial of treatment of male partners of women with BV. August 6, 2014. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02209519. NCT02209519. Exclusion Code: X4.
295 University of British Columbia. BASIC (Boric Acid, Alternate Solution for Intravaginal Colonization) Study. November 27, 2008. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00799214. NCT00799214. Exclusion Code: X4.
296 University of Pittsburgh. Comparing NAAT testing to standard methods for the diagnosis of vaginitis. July 30, 2014. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02203942. NCT02203942. Exclusion Code: X14.
297 University of Washington. Bacterial vaginosis; a randomized trial to reduce recurrence. October 10, 2007. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00542074. NCT00542074. Exclusion Code: X3.
298 van Belkum A, Koeken A, Vandamme P, . Development of a species-specific polymerase chain reaction assay for Gardnerella vaginalis. Mol Cell Probes. 1995 Jun;9(3):167–74. doi: 10.1006/mcpr.1995.0024. PMID: 7477009. Exclusion Code: X5.7477009
299 van der Veer C, van Houdt R, van Dam A, . Accuracy of a commercial multiplex PCR for the diagnosis of bacterial vaginosis. J Med Microbiol. 2018 Sep;67(9):1265–70. doi: 10.1099/jmm.0.000792. Epub 2018 Jul 9. PMID: 29648469. Exclusion Code: X5.29985123
300 Vardar E, Maral I, Inal M, . Comparison of Gram stain and Pap smear procedures in the diagnosis of bacterial vaginosis. Infect Dis Obstet Gynecol. 2002;10(4):203–7. doi: 10.1155/s1064744902000236. PMID: 12648314. Exclusion Code: X3.12648314
301 Varma R, Gupta JK. Antibiotic treatment of bacterial vaginosis in pregnancy: multiple meta-analyses and dilemmas in interpretation. Eur J Obstet Gynecol Reprod Biol. 2006 Jan 1;124(1):10–4. doi: 10.1016/j.ejogrb.2005.07.015. PMID: 19803898. Exclusion Code: X1.16129546
302 Varma R, Gupta JK, James DK, . Do screening-preventative interventions in asymptomatic pregnancies reduce the risk of preterm delivery-a critical appraisal of the literature. Eur J Obstet Gynecol Reprod Biol. 2006 Aug;127(2):145–59. doi: 10.1016/j.ejogrb.2006.02.001. PMID: 16769019. Exclusion Code: X1.16517046
303 Verstraelen H, Verhelst R. Bacterial vaginosis: an update on diagnosis and treatment. Expert Rev Anti Infect Ther. 2009;7(9):1109–24. Exclusion Code: X2.19883331
304 Vidaeff AC, Ramin SM. From concept to practice: the recent history of preterm delivery prevention. Part II: Subclinical infection and hormonal effects. Am J Perinatol. 2006 Feb;23(2):75–84. doi: 10.1055/s-2006-931803. PMID: 16506112. Exclusion Code: X2.16506112
305 Wang KD, Su JR. Quantification of Atopobium vaginae loads may be a new method for the diagnosis of bacterial vaginosis. Clin Lab. 2014;60(9):1501–8. PMID: 26482128. Exclusion Code: X3.25291946
306 Wayne State University. Validation of a novel diagnostic, prognostic assay for bacterial vaginosis. July 9, 2014. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT02185456. NCT02185456. Exclusion Code: X9.
307 Weissenbacher ER, Donders G, Unzeitig V, . A comparison of dequalinium chloride vaginal tablets (Fluomizin(R)) and clindamycin vaginal cream in the treatment of bacterial vaginosis: a single-blind, randomized clinical trial of efficacy and safety. Gynecol Obstet Invest. 2012;73(1):8–15. doi: 10.1159/000332398. PMID: 23934099. Exclusion Code: X4.22205034
308 Western Galilee Hospital-Nahariya. Bacterial vaginosis screening and treatment to reduce infective complications, abortion and preterm delivery. June 26, 2007. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00491270. NCT00491270. Exclusion Code: X14.
309 Wiggins R, Crowley T, Horner PJ, . Use of 5-bromo-4-chloro-3-indolyl-alpha-D-N-acetylneuraminic acid in a novel spot test to identify sialidase activity in vaginal swabs from women with bacterial vaginosis. J Clin Microbiol. 2000 Aug;38(8):3096–7. PMID: 10921986. Exclusion Code: X5.10921986
310 Wolrath H, Boren H, Hallen A, . Trimethylamine content in vaginal secretion and its relation to bacterial vaginosis. APMIS. 2002 Nov;110(11):819–24. PMID: 12588422. Exclusion Code: X5.12588422
311 Youngkin EQ, Lester PB. Promoting self-care and secondary prevention in women’s health: a study to test the accuracy of a home self-test system for bacterial vaginosis. Appl Nurs Res. 2010 Feb;23(1):2–10. doi: 10.1016/j.apnr.2008.02.002. PMID: 20207066. Exclusion Code: X6.20122505
312 Yudin MH. Bacterial vaginosis in pregnancy: diagnosis, screening, and management. Clin Perinatol. 2005 Sep;32(3):617–27. doi: 10.1016/j.clp.2005.05.007. PMID: 16085023. Exclusion Code: X2.16085023
313 Yudin MH, Landers DV, Meyn L, . Clinical and cervical cytokine response to treatment with oral or vaginal metronidazole for bacterial vaginosis during pregnancy: a randomized trial. Obstet Gynecol. 2003 Sep;102(3):527–34. PMID: 12962937. Exclusion Code: X6.12962937
314 Yudin MH, Money DM. Screening and management of bacterial vaginosis in pregnancy. J Obstet Gynaecol Can. 2008 Aug;30(8):702–16. PMID: 18786293. Exclusion Code: X2.18786293
315 Yudin MH, Money DM. No. 211-screening and management of bacterial vaginosis in pregnancy. J Obstet Gynaecol Can. 2017 Aug;39(8):e184–e91. doi: 10.1016/j.jogc.2017.04.018. PMID: 28729110. Exclusion Code: X2.28729110
316 Zagazig University. Vaginal clindamycin cream plus vaginal probiotic for bacterial vaginosis. July 31, 2017. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT03234517. NCT03234517. Exclusion Code: X3.
317 Zarshenas M, Jahed L, Abdali K. A comparison of therapeutic effects of the zataria multiflora vaginal cream and oral metronidazole tablet on the treatment of trichomonas vaginalis and bacterial vaginosis in reproductive aged women. Int J Gynaecol Obstet. 2015;131:E469. PMID: CN-01136195. Exclusion Code: X3.
318 Zhao TF, Zhong L, Luo D. Living preparation of lactobacillus versus metronidazole for bacterial vaginosis in pregnancy: a systematic review. Chinese Journal of Evidence-Based Medicine. 2010;10(11):1338–44. Exclusion Code: X12.
319 Zodiac Produtos Farmaceuticos S. A. Evaluate efficacy, tolerability & safety of combination of clindamycin and ketoconazole for the treatment of mixed-type vaginosis, bacterial vaginosis and candidiasis. April 28, 2009. In ClinicalTrials.gov. [cited December 4, 2018]. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00889356. NCT00889356. Exclusion Code: X3.
320 Zozaya-Hinchliffe M, Lillis R, Martin DH, . Quantitative PCR assessments of bacterial species in women with and without bacterial vaginosis. J Clin Microbiol. 2010 May;48(5):1812–9. doi: 10.1128/jcm.00851-09. PMID: 20495228. Exclusion Code: X7.20305015