# Appendix B Additional Methods Information

## Appendix B1 Detailed Search Strategy

### PubMed Search Strategy

Combined KQs PubMed (January 1, 2006 through May 29, 2019)

| Terms | Results
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((Vaginosis, Bacterial[MeSH Terms]) OR Vaginosis, Bacterial[Title/Abstract]) OR “intermediate flora”[Title/Abstract Sort by: Best Match | 5311 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((((((Mass Screening[MeSH Terms]) OR Sensitivity[MeSH Terms]) OR Specificity[MeSH Terms]) OR Sensitivity[Title/Abstract]) OR specificity[Title/Abstract]) OR diagnosis[Title/Abstract]) OR diagnosis[MeSH Terms]) OR screening[Title/Abstract])) OR ((((((“Diagnostic Test Approval”[Mesh]) OR “Clinical Laboratory Techniques”[Mesh]) OR “Vaginal Smears”[Mesh]) OR “Reproducibility of Results”[Mesh]) OR “Point-of-Care Testing”[Mesh]) OR “Vaginosis, Bacterial/diagnosis”[Mesh]) Sort by: Best Match | 9861252 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #6) Sort by: Best Match | 2782 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“News” [Publication Type]) OR “Editorial” [Publication Type] OR (((case reports[Publication Type]) OR letter[Publication Type]) OR patient education handout[Publication Type]) Sort by: Best Match | 3535965 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Africa”[Mesh]) OR “India”[Mesh] OR “Developing Countries”[Mesh])) Sort by: Best Match | 393336 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 OR #9) Sort by: Best Match | 3883500 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #10) Sort by: Best Match | 2397 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #10) Sort by: Best Match Filters: English | 2077 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #10) Sort by: Best Match Filters: Publication date from 2006/01/01; English | 1097 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((Pregnancy Outcome[MeSH Terms]) OR Pregnancy[MeSH Terms])) OR (((“Embryonic Structures”[Mesh]) OR “Pregnancy Complications”[Mesh]))) OR pregnan* Sort by: Best Match | 1261898 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #14) Sort by: Best Match | 1861 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Mutagenesis”[Mesh]) OR “Carcinogenesis”[Mesh] OR ((“adverse effects” [Subheading]) OR “Patient Harm”[Mesh]) OR “Congenital Abnormalities”[Mesh] OR harm[tw] OR defect[tw] OR malform[tw] Sort by: Best Match | 3076028 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Clindamycin”[Mesh]) OR “Metronidazole”[Mesh]) OR “secnidazole” [Supplementary Concept] OR secnidazole[tw] OR Metronidazole[tw] OR clindamycin[tw] Sort by: Best Match | 29131 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #16 AND #17) Sort by: Best Match | 323 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #18) Sort by: Best Match | 44 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Anti-Bacterial Agents”[Mesh] OR “Anti-Bacterial Agents” [Pharmacological Action]) OR “Bacterial Infections”[Mesh] Sort by: Best Match | 1355452 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #20) Sort by: Best Match | 3729 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #16 AND #21) Sort by: Best Match | 121 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 OR #19 OR #22) Sort by: Best Match | 1861 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 OR #19 OR #22) Sort by: Best Match Filters: English | 1624 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 OR #19 OR #22) Sort by: Best Match Filters: Publication date from 2006/01/01; English | 828 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 OR #25) Sort by: Best Match Filters: Publication date from 2006/01/01; English | 1550 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)

### Other Data Sources

Cochrane=199 total; 123 unique

- Cochrane Reviews =9 total; 7 unique
- DARE=11 total; 8 unique
- Cochrane Controlled Clinical Trials Registry=184 total; 108 unique

Embase =313 total; 121 unique

ClinicalTrials.gov=141 total;139 unique

Health Services Research Projects in Process (HSRProj) =5 total; 4 unique

World Health Organization International Clinical Trials Registry Platform=30 total; 7 unique

KQ 2 Gap Search PubMed (Inception through December 31, 2005)

| Terms | Results
#71 | Search Vaginosis, Bacterial[MeSH Terms] OR Vaginosis, Bacterial[Title] Sort by: PublicationDate | 2747
#73 | Search (Gram Stain[Title/Abstract] OR Nugent[Title/Abstract]) | 5593
#77 | Search ((BV Blue[Title/Abstract] OR BD Max[Title/Abstract] OR BD Affirm[Title/Abstract] OR VS-Sense Pro[Title/Abstract] OR Amsel[Title/Abstract])) | 252
#82 | Search ((#73) OR (#77)) AND (#71) | 514
#83 | Search Mass Screening[MeSH Terms] OR Sensitivity[MeSH Terms] OR Specificity[MeSH Terms] OR Sensitivity[Title/Abstract] OR specificity[Title/Abstract] OR diagnosis[Title/Abstract] OR diagnosis[MeSH Terms] OR screening[Title] OR “Diagnostic Test Approval”[Mesh] OR “Clinical Laboratory Techniques”[Mesh] OR “Vaginal Smears”[Mesh] OR “Reproducibility of Results”[Mesh] OR “Point-of-Care Testing”[Mesh] OR “Vaginosis, Bacterial/diagnosis”[Mesh] Sort by: PublicationDate | 9301603
#84 | Search (#83) AND (#71) | 1595
#87 | Search (HIV[MeSH Terms] OR HIV Infections[MeSH Terms] OR HIV Seronegativity[MeSH Terms]) Sort by: PublicationDate | 295552
#88 | Search Case Reports[Publication Type] OR Editorial[Publication Type] OR Letter[Publication Type] OR Patient Education Handout[Publication Type] OR News[Publication Type] Sort by: PublicationDate | 3324702
#90 | Search (#87) OR (#88) | 3562041
#91 | Search (#84) NOT (#90) | 1508
#92 | Search (#91) Filters: English | 1292
#99 | Search meta-analysis[Publication Type] OR systematic review[Title/Abstract] Sort by: PublicationDate | 169048
#100 | Search (#92) AND (#99) | 7
#93 | Search (#92) Filters: Publication date from 1966/01/01 to 2005/12/31; English | 613
#102 | Search Treatment Outcome[MeSH Terms] Filters: Publication date from 1966/01/01 to 2005/12/31; English | 227133
#103 | Search (#93) NOT (#102) Filters: Publication date from 1966/01/01 to 2005/12/31; English Sort | 548

## Appendix B2 Study Selection Criteria

| Include | Exclude
Population | KQs 1, 3: Asymptomatic pregnant adolescents and women; studies that include mixed populations of symptomatic and asymptomatic participants will be included if the results for asymptomatic participants are reported separately or if less than 20% of the study population is characterized as symptomatic for bacterial vaginosis; KQ 2: Reproductive-age adolescents and women, including pregnant or nonpregnant study participants; KQs 4, 5: Pregnant adolescents and women diagnosed with bacterial vaginosis | KQs 1, 3, 4, 5: Nonpregnant adolescents and women; KQs 1, 3: Adolescents and women with symptomatic bacterial vaginosis
Intervention | KQ 1, 3: Routine screening for bacterial vaginosis using Gram stain (Nugent’s criteria) or any tests listed under KQ 2.; KQ 2: Screening interventions:; - Clinical assessment using complete or partial Amsel’s clinical criteria; - BD MAX™ Vaginal Panel; - BD Affirm™ VPIII Microbial Identification Test; - Colorimetric assessment of pH; - VS-SENSE PRO™ (pH indicator vaginal swab); - OSOM® BVBLUE® (detects sialidase activity); - Other tests^*^; KQs 4, 5: Treatment interventions (oral or vaginal):; - Metronidazole; - Clindamycin | KQ 1: Screening for multiple organisms or infections if the impact of screening specifically for bacterial vaginosis cannot be isolated.; KQ 2: Screening interventions: Tests for diagnosis of bacterial vaginosis that are obsolete or no longer being marketed; KQs 4, 5: Treatment interventions: Treatments not evaluated in pregnant women; Interventions that are not FDA approved for treatment of BV:; - Rifamixin; - Dequalinium chloride; - Oral or vaginal probiotics; - Topical antiseptics; - Treatment of partner (as sole strategy)
Comparison | KQ 1: No screening, usual care; KQ 2: Screening reference standards:; - Gram stain (based on Nugent’s criteria); - Clinical assessment using complete Amsel’s clinical criteria; KQs 4, 5: Treatment interventions:; - Placebo, delayed treatment, or no treatment | KQ 1: Studies with an active comparator group; KQ 2: Screening interventions that do not use an included reference standard; KQs 4, 5: Studies with an active comparator group (i.e., pharmacologic or nonpharmacologic treatment)
Outcomes | KQs 1, 4:; Health Outcomes; - All-cause preterm delivery (spontaneous and indicated deliveries prior to 37 weeks gestation); - Spontaneous preterm delivery; - Indicated preterm delivery; - Low birth weight; - Preterm labor; - Preterm premature rupture of membranes; - 2nd trimester fetal loss; - Spontaneous abortion; - Intrauterine fetal demise; - Neonatal sepsis; - Neonatal death; Intermediate Outcome; - Clearing of bacterial vaginosis after treatment; KQ 2: Sensitivity, specificity, positive likelihood ratio, negative likelihood ratio, normalized frequencies (e.g., x of y tests are true positives or false positives); KQ 3: Anxiety, distress; KQ 5: Harms related to fetal exposure to medication:; - Teratogenesis (e.g., congenital anomalies); - Carcinogenesis; - Maternal AEs, such as:; - Tolerability; - Vaginal candidiasis; - Serious AEs (e.g., those resulting in the need for medical attention) | KQs 1, 2, 4: Outcomes not specifically listed as included
Timing | Intervention timing: Treatment provided after diagnosis; Outcome timing:; KQs 1, 3, 4, 5: Outcomes measured during current pregnancy at any point after screening or treatment, up to 30 days postdelivery; for outcomes related to harms of fetal exposure, outcomes measured at any time point will be included; KQ 2: Screening test and reference standard assessed at same encounter | Outcome timing:; KQs 1, 3, 4, 5: Outcomes not measured during current pregnancy or within 30 days of delivery, except for harms related to fetal exposure; KQ 2: Screening test and reference standard not assessed at same encounter
Setting | Any clinical care settings providing prenatal care, including general obstetrics practices, family medicine practices, and public health clinics; Studies conducted in countries categorized as “very high” on the Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries not categorized as “very high” on the Human Development Index
Study design | KQs 1, 4: RCTs, controlled trials, or systematic reviews of RCTs or controlled trials that use study selection criteria similar to this review^†^; KQ 2: Diagnostic test accuracy studies or systematic reviews of diagnostic test accuracy that use study selection criteria similar to this review^†^; KQs 3, 5: RCTs, controlled trials, cohort studies, case-control studies, or systematic reviews that use study selection criteria similar to this review^†^ | Editorials, narrative reviews, letters to the editor, and study designs not listed as specifically included (e.g., case reports, case series, studies without a comparison group); publications not reporting original research
Language | English language | Languages other than English
Study quality | Good- and fair-quality studies | Poor-quality studies will be excluded from the main analyses but will be synthesized in sensitivity analyses if no good- or fair-quality studies are available for a KQ.

* Other diagnostic tests will be included if the following criteria are met: 1) test is feasible for use in primary care settings, 2) test is evaluated in a separate cohort from the one in which the test was initially developed and validated, and 3) test is evaluated with a priori defined test thresholds.

† Only the most recent systematic review will be included if there are multiple reviews from the same group of investigators using the same review protocol. When there are several systematic reviews on the same topic and similar included primary studies, the review with a low risk of bias and the latest cutoff date for the literature search will be selected.

Abbreviations: BV=bacterial vaginosis; FDA=Food and Drug Administration; KQ=key question; pH=logarithmic scale used to specify the acidity or basicity of an aqueous solution; RCT=randomized, controlled trial.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor:: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor:: Has a fatal flaw, such as using inappropriate reference standard, improperly administering screening test, using biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VI

https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

Harris et al, 2001^200^