# Appendix A Additional Background Information

## Contextual Questions

Contextual questions (CQs) 1, 2, and 3 were designed to provide the USPSTF with additional information about the relationship between bacterial vaginosis, intermediate flora, and preterm delivery. CQ 1 sought information about the epidemiologic association between these conditions and preterm delivery outcomes, while CQ 2 was focused specifically on whether treatment of intermediate flora reduces preterm delivery. Lastly, CQ 3 was focused on the association between bacterial vaginosis and other known risks for preterm delivery, since the mechanisms underlying preterm delivery are complex and challenging to measure and understand in observational studies. CQ 4 was designed to provide information about existing practice patterns related to the diagnosis of bacterial vaginosis in clinical practice and CQ 5 was designed to provide information about adverse events of treatment with metronidazole and clindamycin in nonpregnant women.

### CQ 1 What is the association between bacterial vaginosis, intermediate flora, or abnormal vaginal flora and preterm delivery in U.S. populations, or in similar populations if no U.S. data is available or is limited?

An association between the diagnosis of bacterial vaginosis or intermediate flora and a risk of preterm birth has been reported for over two decades. A 2007 metanalysis^50^ of English-language studies published through 2005 pooled 24 cohort studies or control groups from randomized, controlled trials (RCTs), representing 24,190 patients. The vast majority of the studies were conducted in very highly developed countries (Europe, United States, and Canada). In these studies, bacterial vaginosis was diagnosed with either Amsel’s clinical criteria, Gram stain interpreted with Nugent’s criteria, or both. Asymptomatic women diagnosed with bacterial vaginosis had a pooled odds ratio (OR) of delivery at less than 37 weeks of 2.16 (95% CI, 1.56 to 3.00) compared with women who either did not have bacterial vaginosis or had intermediate flora. In this analysis, the odds of early delivery were similarly elevated for women with and without a history of preterm delivery (OR, 2.63 and 2.22, respectively). The elevated risk was not significantly higher for delivery at less than 34 weeks (4 studies; OR, 1.29 [95% CI, 0.92 to 1.82]) or for delivery at less than 32 weeks (4 studies; OR, 1.34 [95% CI, 0.59 to 3.06]). Second trimester miscarriage had the highest association with diagnosis of bacterial vaginosis during pregnancy (OR, 6.32 [95% CI, 3.65 to 10.94]). The association of bacterial vaginosis with preterm birth was somewhat higher when diagnosed before 16 weeks (RR, 2.97 [95% CI, 1.48 to 5.98]) compared with diagnosis at 20 weeks or greater (RR, 1.89 [95% CI, 1.27 to 2.83]), but these findings were not very precise, suggesting that early diagnosis of bacterial vaginosis in pregnancy is not riskier than later diagnosis. The same review calculated the risk of preterm delivery for pregnant women who had intermediate flora compared with those who had normal flora in five studies representing 1,653 participants. Asymptomatic women with intermediate flora did not have a significantly increased risk of preterm birth compared with those with normal flora (pooled OR for preterm birth at less than 37 weeks, 2.41 [95% CI, 0.63 to 9.20]).

Despite the strong association between bacterial vaginosis and preterm birth in the 2007 meta-analysis, among U.S. populations studied since 2005, bacterial vaginosis has not been associated with a higher risk of preterm delivery in the following populations: asymptomatic pregnant women at high risk for preterm birth diagnosed in the first trimester (p=0.36),^139^ asymptomatic pregnant women at average risk for preterm delivery diagnosed in the second trimester (OR, 1.1 to 1.8; P≥0.35),^140–143^ and symptomatic pregnant women diagnosed in the first trimester who were treated for bacterial vaginosis (adjusted OR, 1.07 [95% CI, 0.64 to 1.79]).^144^ In some small subgroups of women at high risk of preterm birth, high levels of specific bacterial species detected through polymerase chain reaction tests were associated with preterm delivery, including Gardnerella vaginalis, Leptotrichia/Sneathia, Mobiluncus, and BVAB1.^143,^ ^145^ Low levels of Lactobacillus crispatus were also associated with preterm birth in one study.^145^ It is possible that previously described associations between bacterial vaginosis and preterm labor are due to some other underlying factor that predisposes women to both bacterial vaginosis and preterm labor. This might include sociodemographic variables that cannot be sufficiently accounted for in the analysis or varying levels of immune function within the population.^142,^ ^146^

### CQ 2 Is treatment of abnormal vaginal flora and intermediate flora associated with reduced preterm delivery?

Some have argued that intermediate flora, indicated by a Nugent score of 4 to 6 on Gram stain, should be treated as a distinct entity in its own right for the following reasons.^7,^ ^147–149^ The microbial profile of intermediate flora can vary substantially and may or may not include Lactobacillus strains or anaerobic bacteria.^63,^ ^150,^ ^151^ Intermediate flora may be more accurately described as a transitional state between normal flora and a variety of abnormal flora, including but not limited to bacterial vaginosis.^151^ Intermediate flora may not respond to treatment similarly as bacterial vaginosis. Two studies conducted in the United Kingdom among pregnant women with either bacterial vaginosis or intermediate flora treated with clindamycin found higher rates of reversion to normal flora among those with bacterial vaginosis than among those with intermediate flora (91% vs. 53%).^149,^ ^151^

The 2013 Cochrane Review of antibiotics for treating bacterial vaginosis in pregnancy identified two trials out of 21 that included pregnant women with either bacterial vaginosis or intermediate flora. The review did not find a reduction in preterm birth before 37 weeks when pooling results from all eligible trials (RR, 0.88 [95% CI, 0.71 to 1.09]; 13 trials; 6,491 women).^152^ On the other hand, when limited to the two trials that included women with bacterial vaginosis or intermediate flora, treatment did reduce the risk of preterm birth before 37 weeks (pooled RR, 0.53 [95% CI, 0.34 to 0.84]; 2 trials; 894 women).^115,^ ^120^ However, this benefit is unlikely to be explained by the inclusion of women with intermediate flora because in both trials, a larger benefit of treatment was seen among women with a higher Nugent score (i.e., bacterial vaginosis). Both trials were multicenter trials conducted in the United Kingdom evaluating asymptomatic, average-risk pregnant women in the early second trimester; they are included in the systematic review update portion of our report. In one study, women who screened positive (Nugent score of 4 or more) were treated with oral clindamycin. Overall, 15 percent (37/244) in the clindamycin group and 16 percent (38/241) in the placebo group had intermediate flora (Nugent score of 4 to 6).^120^ The study found an overall benefit of treatment. Though not powered to assess treatment by Nugent score, it noted a benefit across all scores but a maximal benefit in those with a Nugent score of 10 (rate of spontaneous preterm delivery was 5.4% in the treatment group compared with 35.7% in the placebo group). The second trial randomized women who screened positive (Nugent score of 4 or greater) to vaginal clindamycin or placebo with a second course of treatment for those with persistently abnormal Nugent score.^115^ For all participants, preterm birth was decreased (adjusted OR, 0.38 [95% CI, 0.16 to 0.90]). In a subgroup analysis of this data, the treatment tended to be more effective at preventing preterm birth in the group with a Nugent score of 7 or more compared to a Nugent score of 4 to 6.^149^

A subgroup of a study included in the systematic review portion of our report screened low-risk asymptomatic women for bacterial vaginosis at their first prenatal visit using Spiegel’s Gram stain criteria. Among those diagnosed with intermediate flora (N=106), 22 were randomized to vaginal clindamycin or placebo. There were two preterm deliveries; one occurred in the treatment group and one in the placebo group.^126^ In a nonrandomized cohort study from Japan, asymptomatic women were screened in the early second trimester and women with a Nugent score of 4 or greater were treated with vaginal metronidazole. The authors found no reduction in preterm birth or gestational age at delivery (preterm birth rate 3.48% in the intervention group compared with 4.31% in an unscreened comparison group).^153^

In summary, we found little evidence suggesting that treatment of intermediate flora leads to a benefit in preterm birth prevention. However, studies are limited in number and characterized by small sample sizes. It is possible that given the diversity of intermediate flora states, future research will identify specific categories of intermediate flora for which treatment may be beneficial.

### CQ 3 What is the association between bacterial vaginosis and other known risk factors for preterm delivery?

#### Demographic Characteristics

During pregnancy, the presence of bacterial vaginosis and intermediate flora is more prevalent among African American women compared with non-Hispanic white and Hispanic women, with RRs ranging from 1.5 to 2.^141,^ ^154–157^ This association has remained strong even after controlling for differences in socioeconomic status, sexual practices, and other demographic variables.^155^ Young age, nulliparity, current tobacco use, low educational attainment, and lower income have also been consistently associated with bacterial vaginosis (RR, 1.3 to 2.60).^141,^ ^157–161^ These characteristics are also all known risk factors for spontaneous preterm birth.^162,^ ^163^

#### Clinical Characteristics

Many different and varied clinical characteristics have been identified as being associated with preterm birth. The extent to which these clinical characteristics are also associated with bacterial vaginosis varies. Untreated genitourinary infections other than bacterial vaginosis may be associated with preterm birth and bacterial vaginosis tends to be associated with a higher risk of concurrent genitourinary infections.^162^ In a study of nonpregnant reproductive age women in the U.S. military, for every additional episode of bacterial vaginosis, the risk of acquiring chlamydia was 13 percent higher and the risk of acquiring gonorrhea was 27 percent higher.^164^ However, in a second study of nonpregnant women at high risk for sexually transmitted infections, bacterial vaginosis was associated with prevalent (RR, 2.83 [95% CI, 1.81 to 4.42]) but not incident chlamydial infection (RR, 1.52 [95% CI, 0.74 to 3.13]).^165^ In some populations, the risk of preterm birth appears to be higher if two or more vaginal infections, including bacterial vaginosis, chlamydia, and trichomonas, are present concurrently. This suggests that the association between bacterial vaginosis and other vaginal infections may not be causative. It may instead be associated with shared risk factors such as sexual behaviors and concurrent genital tract infections.

The risk of bacterial vaginosis has not been consistently associated with periodontal disease^166,^ ^167^ or vaginal douching.^155,^ ^157,^ ^168^ Systematic reviews of reproductive age women have shown an association between bacterial vaginosis and herpes simplex, human immunodeficiency, and human papilloma viruses.^169–171^ Altered levels of immune function such as TNFα polymorphisms,^142^ level of defensins (human neutrophil peptides) in vaginal fluid,^146^ and vaginal cytokine concentrations^172^ have been associated with bacterial vaginosis and preterm delivery. An association between bacterial vaginosis and short cervix has not been shown.

### CQ 4 What is the uptake or use of various diagnostic tests for bacterial vaginosis in clinical practice?

Few studies have investigated the use of specific diagnostic tests for bacterial vaginosis among pregnant women in clinical practice. A handful of studies investigate practices among U.S. outpatient clinics. In a chart review of 150 visits from 52 patients referred to a specialty referral clinic for vulvovaginal disorders, from 1995 to 1997, the number of pregnant patients was not reported. Microscopy of vaginal fluid was performed at 94 (63%) visits, pH measurement at four (3%) visits, and whiff test at five (3%) visits. Bacterial vaginosis was diagnosed at 13 (17%) visits.^173^ Among American College of Obstetricians and Gynecologists fellows surveyed in 1998, 93 percent used clue cells, 78 percent used an amine test, 59 percent used milky discharge, 48 percent used pH, and 18 percent used G. vaginalis culture to diagnose bacterial vaginosis in pregnant patients. Out of around 570 respondents, 57 percent test only those who are symptomatic and 11 percent did not test for bacterial vaginosis at all in pregnant patients.^174^

Wiesbord et al conducted a survey of Georgia-licensed obstetrician/gynecologists, family practitioners, and nurse-midwives in 1998. Among 565 respondents who provided prenatal care, 257 (46%) used clue cells alone, 152 (27%) used Gram stain alone, and most others used a combination of an amine test and a wet mount to diagnose bacterial vaginosis in pregnant patients. Four hundred and seventy seven (84%) respondents tested symptomatic pregnant women and 165 (29%) respondents tested high-risk pregnant patients for bacterial vaginosis.^175^ In a survey of 208 physicians providing gynecology or obstetric care in San Diego, California in 1999, wet mount was the most commonly used test in nonpregnant and pregnant patients (73% and 66%) followed by vaginal culture (18% and 20%), Gram stain (4% and 3%), and rapid test (1% and 1%). Respondents who believed bacterial vaginosis causes preterm delivery were more likely to use wet mount to test for bacterial vaginosis in symptomatic pregnant patients than those who did not (74% vs. 42%). Eight percent always performed wet mount and 19 percent sometimes performed wet mount to diagnose bacterial vaginosis in asymptomatic pregnant patients. Notably these data were all published before the availability of some newer generation tests. It is not understood how frequently such tests are used compared with Amsel’s clinical criteria.

### CQ 5 What are the adverse drug events related to metronidazole or clindamycin when used to treat bacterial vaginosis in nonpregnant adolescents and women?

#### Metronidazole-Related Adverse Events

Metronidazole, a nitroimidazole antimicrobial agent, is commonly used in the treatment of bacterial vaginosis, among other indications. Adverse events attributed to metronidazole use include metallic taste, nausea, vomiting, diarrhea, candida infections, itching, and hypersensitivity.^176–179^ A Cochrane Review conducted in 2009 reported on the effects of antimicrobial therapy on bacterial vaginosis in nonpregnant women. The review included RCTs conducted since 1981 among nonpregnant women with bacterial vaginosis diagnosed by Amsel’s clinical criteria or Gram stain who received any antimicrobial agent. Among included studies, adverse events reported included metallic taste, nausea, vomiting, diarrhea, hypersensitivity, pseudomembranous colitis, any unknown adverse event that the participant or clinicians considered serious, and any event that led to discontinuation of therapy.^180^

A 2011 RCT on the efficacy of tinidazole compared with oral metronidazole 500 mg twice a day for 7 days found that among the metronidazole group, incidences of yeast infection (29.3%) and nausea/vomiting (20.2%) were the most common. Other adverse events included headache (14.7%), bad taste (11.0%), diarrhea (3.7%), and anorexia (0.8%).^181^ A more recent RCT conducted in 2015 on the safety and efficacy of 1.3 percent single-dose metronidazole vaginal gel for bacterial vaginosis treatment (N=581) found that the incidence of adverse events was similar between treatment and placebo gel groups (19% vs. 16.1%, respectively).^182^ The most frequently reported adverse events were vulvovaginal candida infection (5.6%) and headaches (2.2%).^182^ Other reported adverse events in the metronidazole vaginal gel group were diarrhea (1.2%), nausea (1.6%), dysmenorrhea (1.2%), and vulvovaginal pruritus (1.6%). While the incidence of adverse events among the single-dose gel is less than the oral metronidazole dose, it is difficult to compare across studies.

Multiple studies that compared route of metronidazole administration suggest that route affects incidence of adverse events. While the Cochrane review does not compare incidence of adverse events between vaginal and oral metronidazole, two randomized controlled studies reported that vaginal metronidazole was associated with fewer gastrointestinal complaints.^176,^ ^183^ An RCT (N=277) comparing the efficacy of vaginal metronidazole (1,000 mg pessary used daily for 2 days) with oral metronidazole (2 g one-time dose) in acute symptomatic bacterial vaginosis reported that three adverse events were experienced significantly more frequently by the group that received oral dosing: nausea (30.4% vs. 10.2%), abdominal pain (31.9% vs. 16.8%), and metallic taste (17.0% vs. 8.8%).^176^ Another RCT (N=112) compared metronidazole vaginal 5 g twice daily for 5 days and oral metronidazole 500 mg twice daily for 7 days and reported that gastrointestinal symptoms were the most common adverse event reported in both groups, but these symptoms were more common and more severe in the oral group (51.8% vs. 32.7%, p=0.04) compared with the vaginal group. The percentage who experienced candidiasis was comparable (16% vaginal vs. 14% oral).^183^

#### Clindamycin-Related Adverse Events

Clindamycin, a lincosamide antibiotic, is another common treatment for bacterial vaginosis. Clindamycin can be administrated in multiple forms, including orally or vaginally as ovules or creams.^177,^ ^178^ The 2009 Cochrane review includes studies comparing clindamycin cream and placebo groups; however, no analyses was conducted on adverse events between these two groups. Included in the Cochrane review is a 1993 placebo-controlled RCT (N=215) of treatment with vaginal 2 percent clindamycin that reported that the most common adverse events were nonbacterial vaginitis/cervicitis (18.5%), diarrhea (7.4%), headache (4.6%), abdominal pain (2.8%), and vaginal irritation following medication insertion (2.8%).^184^ However, the authors reported that the adverse events were similar between the clindamycin and placebo groups except for nonbacterial vaginitis/cervicitis, which was higher among the clindamycin group (18.5% vs. 7.5%, p=0.03).^184^ Other RCTs included in the 2009 Cochrane Review corroborate that common AEs related to clindamycin^185,^ ^186^ include vaginal irritation, candidiasis, nausea, headache, metallic taste, and diarrhea.^185–188^ The Cochrane review did compare overall AEs between clindamycin ovules and cream and found no differences (RR, 1.11 [95% CI, 0.97 to 1.28] based on one study [N=662]). Specifically, rates of candida infection were comparable (RR, 1.69 [95% CI, 0.41 to 7.00], based on one study [N=658]).

#### Comparison of Adverse Events Between Metronidazole and Clindamycin

The 2009 Cochrane Review conducted a pooled analysis of four trials evaluating the adverse events of clindamycin cream and ovules compared with oral metronidazole antimicrobial therapy on bacterial vaginosis in nonpregnant women (N= 927). There was no statistical difference in overall adverse event rates (RR, 0.75 [95% CI, 0.54 to 1.05]).^180^ However, metronidazole was less likely than clindamycin to cause metallic taste (RR, 0.09 [95% CI, 0.01 to 0.68], based on pooled data from two studies [N=204]), and nausea and vomiting (RR, 0.27 [95% CI, 0.11 to 0.69], based on three studies^185–187^ [N=611]). Rates of candidiasis (RR, 1.11 [95% CI, 0.78 to 1.58], based on four studies^186,^ ^187,^ ^189,^ ^190^ [N=986)], diarrhea (RR, 2.99 [95% CI, 0.12 to 72.85], based on one^187^ study [N=407]), and vaginal irritation (RR, 1.59 [95% CI, 0.31 to 8.17], based on two^186,^ ^187^ studies [N=468]) were not significantly different between groups.

Appendix A Table 1 Summary of Reference Tests Available for Diagnosis of Bacterial Vaginosis in the United States

Reference Test | Description
Gram stain of vaginal fluid (“Nugent’s” criteria) | Based on a scoring system from 0 to 10 of Gram-stained vaginal fluid smear under microscope (x1,000 with oil immersion) scored according to the quantitative appearance of various organisms’ morphologies:; - Large Gram-positive rods; ○ 0 score: 4+ morphotypes present; ○ 1 score: 3+ morphotypes present; ○ 2 score: 2+ morphotypes present; ○ 3 score: 1+ morphotypes present; ○ 4 score: 0 morphotypes present; - Small Gram-negative to Gram-variable rods; ○ 0 score: 0 morphotypes present; ○ 1 score: 1+ morphotypes present; ○ 2 score: 2+ morphotypes present; ○ 3 score: 3+ morphotypes present; ○ 4 score: 4+ morphotypes present; - Curved Gram-variable rods; ○ 0 score: 0 morphotypes present; ○ 1 score: 1+ or 2+ morphotypes present; ○ 2 score: 3+ or 4+ morphotypes present; Total score=Gram-positive rods score + small Gram-negative to Gram-variable rods score + curved Gram-variable rods score. Bacterial vaginosis is diagnosed when total score >7.
Gram stain of vaginal fluid (“Spiegel’s” criteria) | Gram-stained vaginal fluid smears are evaluated under microscope (x1,000 with oil immersion):; - Large Gram-positive bacilli morphology are assumed to be Lactobacillus; - Smaller Gram-variable bacilli morphology are assumed to be Gardnerella; - Other organisms are categorized by their respective morphology; - Presence of these organisms’ morphologies are scored as 1+ for <1 per field, 2+ for 1 to 5 per field, 3+ for 6 to 30 per field, and 4+ for >30 per field; - Bacterial vaginosis is diagnosed with 1 to 2+ score for Lactobacillus presence (i.e., few or none seen in the field) and >1 or 2+ presence of other morphotypes
Clinical diagnosis (“Amsel” criteria) | 3 out of 4 of the following:; - Vaginal pH above 4.5; - Presence of thin, homogenous vaginal discharge; - Release of “fishy odor” from vaginal discharge on addition of 10% potassium hydroxide (the “amine” test); - Presence of clue cells (typically at least 20% of vaginal epithelial cells) in the discharge on wet mount

Abbreviations: pH=logarithmic scale used to specify the acidity or basicity of an aqueous solution.

Appendix A Table 2 Summary of Treatments Available in the United States for Bacterial Vaginosis^191^

Medication/Pregnancy Category^*^ | Formulation | Dose, Route, and Frequency | FDA Label | CDC
Clindamycin “B” | Vaginal ovules (100 mg/ovule) | One ovule intravaginally daily, preferably at bedtime, for 3 days | Indication for treatment of bacterial vaginosis in nonpregnant women. | CDC recommends either oral or vaginal preparations of metronidazole or clindamycin in pregnant women.^191^
Clindamycin “B” | Vaginal cream 2% | One applicator (100 mg) intravaginally daily, preferably at bedtime, for 7 days. | Indication for treatment of bacterial vaginosis in nonpregnant women. One manufacturer (Cleocin) has a label indication for treatment of bacterial vaginosis in 2nd trimester of pregnancy. | CDC recommends either oral or vaginal preparations of metronidazole or clindamycin in pregnant women.^191^
Clindamycin “B” | Oral capsules (various doses) | 300 mg orally twice a day for 7 days | No indication for treatment of bacterial vaginosis. | CDC recommends either oral or vaginal preparations of metronidazole or clindamycin in pregnant women.^191^
Metronidazole “B” | Vaginal gel 0.75% | One applicator (37.5 g) intravaginally daily for 5 days | Indication for treatment of bacterial vaginosis in nonpregnant women. | CDC recommends either oral or vaginal preparations of metronidazole or clindamycin in pregnant women.^191^
Metronidazole “B” | Vaginal gel 1.3% | One applicator (65 mg) intravaginally once at bedtime | Indication for treatment of bacterial vaginosis in nonpregnant women. | CDC recommends either oral or vaginal preparations of metronidazole or clindamycin in pregnant women.^191^
Metronidazole “B” | Tablets (various doses) | 500 mg twice a day or 250 mg three times a day for 7 days | No indication for treatment of bacterial vaginosis. | CDC recommends either oral or vaginal preparations of metronidazole or clindamycin in pregnant women.^191^
Metronidazole “B” | Extended-release tablets (750 mg) | One tablet, once a day for 7 days | No indication for treatment of bacterial vaginosis. | CDC recommends either oral or vaginal preparations of metronidazole or clindamycin in pregnant women.^191^
Tinidazole “C” | Tablets (various doses) | 2 g once a day for 2 days or 1 g once a day for 5 days | Indication for treatment of bacterial vaginosis in nonpregnant women. | Not addressed.
Secnidazole NA^*^ | Single-dose oral granules | One 2 g packet of granules orally, preferably sprinkled over food and consumed | Indication for treatment of bacterial vaginosis in adult women. | Not available at time of last CDC guideline update.

* FDA is phasing out the use of the pregnancy categories, so new drugs will not be assigned a category.^192^

Abbreviations: CDC=Centers for Disease Control and Prevention; FDA=Food and Drug Administration.

Appendix A Table 3 Summary of Recommendations for Screening for Bacterial Vaginosis in Pregnant Women

Organization (Year) | Recommendation
American College of Obstetricians and Gynecologists’ (ACOG) Practice Bulletin (2012, reaffirmed 2018)^193^ | “Other specific tests and monitoring modalities, such as fetal fibronectin screening, bacterial vaginosis testing, and home uterine activity monitoring have been proposed to assess a woman’s risk of preterm delivery. However, available interventional studies based on the use of these tests for screening asymptomatic women have not demonstrated improved perinatal outcomes. Thus, these methods are not recommended as screening strategies.”
Society of Obstetricians and Gynecologists of Canada (SOGC) (2017)^194^ | “Asymptomatic women and women without identified risk factors for preterm birth should not undergo routine screening for or treatment of bacterial vaginosis. Women at increased risk for preterm birth may benefit from routine screening for and treatment of bacterial vaginosis.”
CDC’s Sexually Transmitted Disease (STD) Treatment Guidelines (2015)^191^ | “Evidence does not support routine screening for bacterial vaginosis in asymptomatic pregnant women at high risk for preterm delivery. Symptomatic women should be evaluated and treated.”
Association of Reproductive Health Professionals (2013)^195^ | “Screening for BV is not recommended in asymptomatic women, even in pregnancy.”
British Association for Sexual Health and HIV (BASHH) (2012)^196^ | “There is insufficient evidence to recommend routine treatment of asymptomatic pregnant women who attend a genitourinary clinic and are found to have BV. Women with additional risk factors for preterm birth may benefit from treatment before 20 weeks gestation.”
National Institute for Health and Care Excellence (NICE)^*^ (2011)^197^ | “Pregnant women should not be offered routine screening for bacterial vaginosis because the evidence suggests that the identification and treatment of asymptomatic bacterial vaginosis does not lower the risk of preterm delivery and other adverse reproductive outcomes.”
American Academy of Family Physicians (2008)^198^ | Same as current USPSTF recommendation.

* This guideline is undergoing an update, expected to be published in July 2020.^199^

Abbreviations: ACOG=American College of Obstetricians and Gynecologists; BASHH=British Association for Sexual Health and HIVs; BV=bacterial vaginosis; NICE= National Institute of Clinical Excellence; SOGC=Society of Obstetricians and Gynecologists of Canada; STD=sexually transmitted disease; USPSTF = U.S. Preventive Services Task Force.