# References

1 National Institute on Drug A. Commonly abused drugs. National Institutes of Health, U.S. Department of Health and Human Services; 2010.
2 National Institute on Drug A. Commonly abused prescription drugs. National Institutes of Health, U.S. Department of Health and Human Services; 2011.
3 National Institute on Drug Abuse. Misuse of Prescription Drugs. https://www.drugabuse.gov/publications/research-reports/misuse-prescription-drugs/summary.
4 Agency for Healthcare Research and Quality. Final Research Plan for Tobacco and Nicotine Use Prevention in Children and Adolescents: Primary Care Interventions. https://www.uspreventiveservicestaskforce.org/Page/Document/final-research-plan/tobacco-and-nicotine-use-prevention-in-children-and-adolescents-primary-care-interventions.
5 O’Connor EA, Perdue LA, Senger CA, . Screening and Behavioral Counseling Interventions to Reduce Unhealthy Alcohol Use in Adolescents and Adults: An Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD) 2018.
6 O’Connor EA, Perdue LA, Senger CA, . Screening and behavioral counseling interventions to reduce unhealthy alcohol use in adolescents and adults: Updated evidence report and systematic review for the us preventive services task force. JAMA. 2018;320(18):1910–28. 10.1001/jama.2018.12086 30422198
7 Agency for Healthcare Research and Quality. Final Research Plan for Drug Use in Adolescents and Adults, Including Pregnant Women: Screening. https://www.uspreventiveservicestaskforce.org/Page/Document/final-research-plan/drug-use-in-adolescents-and-adults-including-pregnant-women-screening.
8 Miech RAS, J. E.; Johnston, L. D.; Bachman, J. G.; O’Malley, P. M.; Patrick, M. E. National Adolescent Drug Trends in 2018. http://www.monitoringthefuture.org.
9 Substance Abuse and Mental Health Services Administration. Key substance use and mental health indicators in the United States: Results from the 2016 National Survey on Drug Use and Health. In: SAMHSA, editor. Rockville, MD: Center for Behavioral Health Statistics and Quality,; 2017.
10 Pinchevsky GM, Arria AM, Caldeira KM, . Marijuana exposure opportunity and initiation during college: parent and peer influences. Prevention science : the official journal of the Society for Prevention Research. 2012;13(1):43–54. 10.1007/s11121-011-0243-4 21870157
11 Garnier-Dykstra LM, Caldeira KM, Vincent KB, . Nonmedical use of prescription stimulants during college: four-year trends in exposure opportunity, use, motives, and sources. Journal of American college health : J of ACH. 2012;60(3):226–34. 10.1080/07448481.2011.589876
12 Miech RA, Patrick ME, O’Malley PM, . The Influence of College Attendance on Risk for Marijuana Initiation in the United States: 1977 to 2015. American Journal of Public Health. 2017;107(6):996–1002. 10.2105/ajph.2017.303745 28426314
13 Kann L, McManus T, Harris WA, . Youth Risk Behavior Surveillance - United States, 2015. MMWR Surveill Summ. 2016;65(6):1–174. 10.15585/mmwr.ss6506a1
14 Keyes KM, Wall M, Feng T, . Race/ethnicity and marijuana use in the United States: Diminishing differences in the prevalence of use, 2006–2015. Drug and Alcohol Dependence. 2017;179(Supplement C):379–86. 10.1016/j.drugalcdep.2017.07.027 28846954
15 Substance Abuse and Mental Health Services Administration. National Survey on Drug Use and Health, 2015 and 2016. In: SAMHSA, editor. Rockville, MD: Center for Behavioral Health Statistics and Quality, ; 2017.
16 Li DH, Turner BC, Mustanski B, . Sexual orientation disparities in prescription drug misuse among a nationally representative sample of adolescents: Prevalence and correlates. Addict Behav. 2017;77:143–51. 10.1016/j.addbeh.2017.09.021 29017108
17 Kann L, McManus T, Harris WA, . Youth Risk Behavior Surveillance - United States, 2017. MMWR Surveill Summ. 2018;67(8):1–114. 10.15585/mmwr.ss6708a1
18 Hedegaard H, Warner M, Minino AM. Drug Overdose Deaths in the United States, 1999-2015. NCHS Data Brief. 2017(273):1–8.
19 Warner M, Chen LH, Makuc DM, . Drug poisoning deaths in the United States, 1980-2008. NCHS Data Brief. 2011(81):1–8.
20 Gaither JR, Shabanova V, Leventhal JM. Us national trends in pediatric deaths from prescription and illicit opioids, 1999-2016. JAMA Network Open. 2018;1(8):e186558. 10.1001/jamanetworkopen.2018.6558 30646334
21 Scholl L, Seth P, Kariisa M, . Drug and Opioid-Involved Overdose Deaths - United States, 2013-2017. MMWR Morb Mortal Wkly Rep. 2018;67(5152):1419–27. 10.15585/mmwr.mm675152e1 30605448
22 Martin J-L, Gadegbeku B, Wu D, . Cannabis, alcohol and fatal road accidents. PloS one. 2017;12(11):e0187320–e. 10.1371/journal.pone.0187320 29117206
23 Elvik R. Risk of road accident associated with the use of drugs: A systematic review and meta-analysis of evidence from epidemiological studies. Accid Anal Prev. 2013;60:254–67. 10.1016/j.aap.2012.06.017 22785089
24 Cunningham RM, Carter PM, Ranney M, . Violent reinjury and mortality among youth seeking emergency department care for assault-related injury: a 2-year prospective cohort study. JAMA Pediatr. 2015;169(1):63–70. 10.1001/jamapediatrics.2014.1900 25365147
25 Hohl BC, Wiley S, Wiebe DJ, . Association of Drug and Alcohol Use With Adolescent Firearm Homicide at Individual, Family, and Neighborhood LevelsDrug and Alcohol Use and Adolescent Firearm HomicideDrug and Alcohol Use and Adolescent Firearm Homicide. JAMA Internal Medicine. 2017;177(3):317–24. 10.1001/jamainternmed.2016.8180 28055064
26 Nock MK, Green JG, Hwang I, . Prevalence, correlates, and treatment of lifetime suicidal behavior among adolescents: results from the National Comorbidity Survey Replication Adolescent Supplement. JAMA Psychiatry. 2013;70(3):300–10. 10.1001/2013.jamapsychiatry.55 23303463
27 Goldman-Mellor S, Kwan K, Boyajian J, . Predictors of self-harm emergency department visits in adolescents: A statewide longitudinal study. Gen Hosp Psychiatry. 2019;56:28–35. 10.1016/j.genhosppsych.2018.12.004 30553125
28 Heron M. Deaths: Leading Causes for 2016. National vital statistics reports : from the Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System. 2018;67(6):1–77.
29 Substance Abuse and Mental Health Services Administration. Drug Abuse Warning Network, 2011: National Estimates of Drug-Related Emergency Department Visits. Rockville, MD: Substance Abuse and Mental Health Services Administration; 2011.
30 Substance Abuse and Mental Health Services Administration. Drug Abuse Warning Network, 2011: Selected Tables of National Estimates of Drug-Related Emergency Department Visits. In: Center for Behavioral Health Statistics and Quality, editor. Rockville, MD: SAMHSA; 2013.
31 Crane EH. Emergency department visits involving narcotic pain relievers. Substance Abuse and Mental Health Administration; 2015.
32 Substance Abuse and Mental Health Services Administration. Alcohol and Drug Combinations Are More Likely to Have a Serious Outcome Than Alcohol Alone in Emergency Department Visits Involving Underage Drinking. The DAWN report. 2014.
33 Townsend L, Flisher AJ, King G. A systematic review of the relationship between high school dropout and substance use. Clin Child Fam Psychol Rev. 2007;10(4):295–317.17636403
34 Green KM, Doherty EE, Ensminger ME. Long-term consequences of adolescent cannabis use: Examining intermediary processes. The American journal of drug and alcohol abuse. 2017;43(5):567–75. 10.1080/00952990.2016.1258706 27929672
35 Mitchell O, Caudy MS. Race Differences in Drug Offending and Drug Distribution Arrests. Crime & Delinquency. 2017;63(2):91–112. 10.1177/0011128714568427
36 Kirk DS, Sampson RJ. Juvenile Arrest and Collateral Educational Damage in the Transition to Adulthood. Sociology of Education. 2013;86(1):36–62. 10.1177/0038040712448862
37 Nargiso JE, Ballard EL, Skeer MR. A systematic review of risk and protective factors associated with nonmedical use of prescription drugs among youth in the United States: a social ecological perspective. Journal of studies on alcohol and drugs. 2015;76(1):5–20.25486389
38 Arria AM, Garnier-Dykstra LM, Caldeira KM, . Drug use patterns and continuous enrollment in college: results from a longitudinal study. Journal of studies on alcohol and drugs. 2013;74(1):71–83.23200152
39 Hunt J, Eisenberg D, Kilbourne AM. Consequences of receipt of a psychiatric diagnosis for completion of college. Psychiatr Serv. 2010;61(4):399–404. 10.1176/ps.2010.61.4.399 20360280
40 Heitzeg MM, Cope LM, Martz ME, . Brain activation to negative stimuli mediates a relationship between adolescent marijuana use and later emotional functioning. Dev Cogn Neurosci. 2015;16:71–83. 10.1016/j.dcn.2015.09.003 26403581
41 Gage SH, Hickman M, Zammit S. Association Between Cannabis and Psychosis: Epidemiologic Evidence. Biological Psychiatry. 2016;79(7):549–56. 10.1016/j.biopsych.2015.08.001 26386480
42 Di Forti M, Quattrone D, Freeman TP, . The contribution of cannabis use to variation in the incidence of psychotic disorder across Europe (EU-GEI): a multicentre case-control study. Lancet Psychiatry. 2019;6(5):427–36. 10.1016/S2215-0366(19)30048-3 30902669
43 Bourque J, Afzali MH, Conrod PJ. Association of Cannabis Use With Adolescent Psychotic SymptomsAssociation of Cannabis Use With Adolescent Psychotic SymptomsLetters. JAMA Psychiatry. 2018;75(8):864–6. 10.1001/jamapsychiatry.2018.1330 29874357
44 Grant I, Gonzalez R, Carey CL, . Non-acute (residual) neurocognitive effects of cannabis use: a meta-analytic study. Journal of the International Neuropsychological Society : JINS. 2003;9(5):679–89. 10.1017/s1355617703950016 12901774
45 Schreiner AM, Dunn ME. Residual effects of cannabis use on neurocognitive performance after prolonged abstinence: a meta-analysis. Exp Clin Psychopharmacol. 2012;20(5):420–9. 10.1037/a0029117 22731735
46 Hoch E, Bonnetn U, Thomasius R, . Risks associated with the non-medicinal use of cannabis. Dtsch. 2015;112(16):271–8. 10.3238/arztebl.2015.0271
47 Meier MH, Caspi A, Ambler A, . Persistent cannabis users show neuropsychological decline from childhood to midlife. Proc Natl Acad Sci U S A. 2012;109(40):E2657–64. 10.1073/pnas.1206820109 22927402
48 Johnston L, PM O’Malley, RA Miech, . Monitoring the Future national survey results on drug use, 1975-2016: Overview, key findings on adolescent drug use. Ann Arbor: Institute for Social Research, The University of Michigan; 2017.
49 Cerda M, Wall M, Feng T, . Association of State Recreational Marijuana Laws With Adolescent Marijuana Use. JAMA Pediatr. 2017;171(2):142–9. 10.1001/jamapediatrics.2016.3624 28027345
50 Griesler PC, Hu M-C, Wall MM, . Nonmedical Prescription Opioid Use by Parents and Adolescents in the US. Pediatrics. 2019;143(3):e20182354. 10.1542/peds.2018-2354 30804077
51 Mayberry ML, Espelage DL, Koenig B. Multilevel modeling of direct effects and interactions of peers, parents, school, and community influences on adolescent substance use. J Youth Adolesc. 2009;38(8):1038–49.19636769
52 Fletcher A, Bonell C, Hargreaves J. School effects on young people’s drug use: a systematic review of intervention and observational studies. J Adolesc Health. 2008;42(3):209–20.18295128
53 Draucker CB, Mazurczyk J. Relationships between childhood sexual abuse and substance use and sexual risk behaviors during adolescence: An integrative review. Nursing outlook. 2013;61(5):291–310. 10.1016/j.outlook.2012.12.003 23810256
54 Goldbach J, Fisher BW, Dunlap S. Traumatic experiences and drug use by LGB adolescents: A critical review of minority stress. Journal of Social Work Practice in the Addictions. 2015;15(1):90–113. 10.1080/1533256X.2014.996227
55 Peters EN, Nordeck C, Zanetti G, . Relationship of gambling with tobacco, alcohol, and illicit drug use among adolescents in the USA: Review of the literature 2000-2014. Am J Addict. 2015;24(3):206–16. 10.1111/ajad.12214 25864783
56 Russell K, Dryden DM, Liang Y, . Risk factors for methamphetamine use in youth: a systematic review. BMC Pediatr. 2008;8:48. 10.1186/1471-2431-8-48 18957076
57 Fletcher A, Bonell C, Hargreaves J. School effects on young people’s drug use: a systematic review of intervention and observational studies. J Adolesc Health. 2008;42(3):209–20. 10.1016/j.jadohealth.2007.09.020 18295128
58 American Academy of Pediatrics. Bright Futures: Guidelines for Health Supervision of Infants, Children, and Adolescents, 4th edition. 4th ed. Jr JFH, Shaw JS, Duncan PM, editors: The American Academy of Pediatrics; 2017.
59 Hays SP, Hays CE, Mulhall PF. Community risk and protective factors and adolescent substance use. J Prim Prev. 2003;24(4):125–42.
60 Borodovsky JT, Lee DC, Crosier BS, . U.S. cannabis legalization and use of vaping and edible products among youth. Drug Alcohol Depend. 2017;177:299–306. 10.1016/j.drugalcdep.2017.02.017 28662974
61 Van Ryzin MJ, Roseth CJ, Fosco GM, . A component-centered meta-analysis of family-based prevention programs for adolescent substance use. Clinical psychology review. 2016;45:72–80. 10.1016/j.cpr.2016.03.007 27064553
62 Schinke S, Schwinn TM. Computer-Based Prevention and Intervention to Reduce Substance Use in Youth. Curr Addict Rep. 2017;4(4):410–21. 10.1007/s40429-017-0171-x 29354389
63 Office of Disease Prevention and Health Promotion. Healthy People 2020: topics and objectives. https://www.healthypeople.gov/2020/topics-objectives. October 20, 2017.
64 Substance Abuse and Mental Health Services Administration. Screening, brief intervention, and referral to treatment (SBIRT). https://wwwsamhsagov/programs-campaigns/screening-brief-intervention-referral-treatment. 2017.
65 SAMHSA. Screening, Brief Intervention and Referral to Treatment (SBIRT) in behavioral healthcare. 2011. http://www.samhsa.gov/prevention/sbirt/
66 AAP Committee on Substance Use and Prevention. Substance Use Screening, Brief Intervention, and Referral to Treatment. Pediatrics. 2016;138(1). 10.1542/peds.2016-1210
67 Levy SJL, Williams JF, Committee on Substance Use and Prevention. Substance Use Screening, Brief Intervention, and Referral to Treatment [Clinical Report]. Pediatrics. 2016. 10.1542/peds.2016-1211
68 Moyer VA, Force USPST. Primary care behavioral interventions to reduce illicit drug and nonmedical pharmaceutical use in children and adolescents: U.S. Preventive Services Task Force recommendation statement. Annals of Internal Medicine. 2014;160(9):634–9. PMID: 24615535. 10.7326/M14-0334 24615535
69 Agency for Healthcare Research and Quality. Drug Use, Illicit: Screening. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/drug-use-illicit-screening?ds=1&s=drug. .
70 Agency for Healthcare Research and Quality. Unhealthy Alcohol Use in Adolescents and Adults: Screening and Behavioral Counseling Interventions. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/unhealthy-alcohol-use-in-adolescents-and-adults-screening-and-behavioral-counseling-interventions?ds=1&s=alcohol. Accessed.
71 Agency for Healthcare Research and Quality. Tobacco Use in Children and Adolescents: Primary Care Interventions. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/tobacco-use-in-children-and-adolescents-primary-care-interventions?ds=1&s=tobacco.
72 Knight JR, Sherritt L, Gibson EB, . Effect of Computer-Based Substance Use Screening and Brief Behavioral Counseling vs Usual Care for Youths in Pediatric Primary Care: A Pilot Randomized Clinical Trial. JAMA Netw Open. 2019;2(6):e196258. 10.1001/jamanetworkopen.2019.6258 31225897
73 United Nations Development Programme. Human Development Report. New York, NY: United Nations; 2016.
74 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
75 Substance Abuse and Mental Health Services Administration. Mapping Interventions to Different Levels of Risk. https://www.samhsa.gov/capt/sites/default/files/resources/mapping-interventions-different-level-risks.pdf. Accessed: November 8, 2018.
76 Borenstein M, Hedges LV, Higgins JPT, . Introduction to Meta‐Analysis. West Sussex, England, United Kingdom: John Wily & Sons, Ltd; 2009.
77 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. Bmj. 1997;315(7109):629–34. PMID: 9310563.9310563
78 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
79 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
80 Harris SK, Csemy L, Sherritt L, . Computer-facilitated substance use screening and brief advice for teens in primary care: an international trial. Pediatrics. 2012;129(6):1072–82.22566420
81 Baldus C, Thomsen M, Sack PM, . Evaluation of a German version of the Strengthening Families Programme 10-14: a randomised controlled trial. European Journal of Public Health. 2016;26(6):953–9. 10.1093/eurpub/ckw082 27374805
82 Bannink R, Broeren S, Joosten-van Zwanenburg E, . Effectiveness of a Web-based tailored intervention (E-health4Uth) and consultation to promote adolescents’ health: randomized controlled trial. Journal of medical Internet research. 2014;16(5):e143. 10.2196/jmir.3163 24878521
83 Barlow A, Mullany B, Neault N, . Effect of a paraprofessional home-visiting intervention on American Indian teen mothers’ and infants’ behavioral risks: A randomized controlled trial. The American Journal of Psychiatry. 2013;170(1):83–93. 10.1176/appi.ajp.2012.12010121 23409290
84 Barlow A, Mullany B, Neault N, . Paraprofessional-delivered home-visiting intervention for American Indian teen mothers and children: 3-year outcomes from a randomized controlled trial. American Journal of Psychiatry. 2015;172(2):154–62. 10.1176/appi.ajp.2014.14030332 25321149
85 Barlow A, Varipatis-Baker E, Speakman K, . Home-visiting intervention to improve child care among American Indian adolescent mothers: a randomized trial. Arch Pediatr Adolesc Med. 2006;160(11):1101–7. PMID: 17088511. 10.1001/archpedi.160.11.1101 17088511
86 Broning S, Baldus C, Thomsen M, . Children with elevated psychosocial risk load benefit most from a family-based preventive intervention: Exploratory differential analyses from the German “Strengthening Families Program 10-14” adaptation trial. Prevention Science. 2017;18(8):932–42. 10.1007/s11121-017-0797-x 28643133
87 Broning S, Sack PM, Thomsen M, . Implementing and evaluating the German adaptation of the “Strengthening Families Program 10 - 14”- a randomized-controlled multicentre study. BMC public health. 2014;14:83. 10.1186/1471-2458-14-83 24467917
88 Dembo R, Briones-Robinson R, Schmeidler J, . Brief intervention impact on truant youths’ marijuana use: Eighteen-month follow-up. Journal of child & adolescent substance abuse. 2016;25(1):18–32. 10.1080/1067828X.2013.872068
89 Dembo R, Cervenka KA, Hunter B, . Engaging high risk families in community based intervention services. Aggression and Violent Behavior. 1999;4(1):41–58. 10.1016/S1359-1789%2897%2900028-1
90 Estrada Y, Lee TK, Wagstaff R, . eHealth Familias Unidas: Efficacy Trial of an Evidence-Based Intervention Adapted for Use on the Internet with Hispanic Families. Prevention Science. 2018;10:10. 10.1007/s11121-018-0905-6
91 Fang L, Schinke SP. Two-year outcomes of a randomized, family-based substance use prevention trial for Asian American adolescent girls. Psychol Addict Behav. 2013;27(3):788–98.23276322
92 Fang L, Schinke SP, Cole KC. Preventing substance use among early Asian-American adolescent girls: initial evaluation of a web-based, mother-daughter program. Journal of Adolescent Health. 2010;47(5):529–32.20970090
93 Foxcroft DR, Callen H, Davies EL, . Effectiveness of the strengthening families programme 10-14 in Poland: cluster randomized controlled trial. European Journal of Public Health. 2017;27(3):494–500. 10.1093/eurpub/ckw195 28339547
94 Gmel G, Gaume J, Bertholet N, . Effectiveness of a brief integrative multiple substance use intervention among young men with and without booster sessions. Journal of Substance Abuse Treatment. 2013;44(2):231–40. 10.1016/j.jsat.2012.07.005 22885010
95 Jalling C, Bodin M, Romelsjo A, . Parent programs for reducing adolescent’s antisocial behavior and substance use: A randomized controlled trial. Journal of child and family studies. 2016;25(3):811–26. 10.1007/s10826-015-0263-y 26900316
96 Johnson SL, Jones V, Cheng TL. Promoting “healthy futures” to reduce risk behaviors in urban youth: A randomized controlled trial. American Journal of Community Psychology. 2015;56(1-2):36–45. 10.1007/s10464-015-9734-y 26122751
97 Kerr JC, Valois RF, Farber NB, . Effects of Promoting Health Among Teens on Dietary, Physical Activity and Substance Use Knowledge and Behaviors for African American Adolescents. Am J Health Educ. 2013;44(4):191–202.23957017
98 Kim HK, Leve LD. Substance use and delinquency among middle school girls in foster care: a three-year follow-up of a randomized controlled trial. J Consult Clin Psychol. 2011;79(6):740–50. 10.1037/a0025949 22004305
99 Kim HK, Pears KC, Leve LD, . Intervention Effects on Health-Risking Sexual Behavior Among Girls in Foster Care: The Role of Placement Disruption and Tobacco and Marijuana Use. Journal of child & adolescent substance abuse. 2013;22(5):370–87.24043921
100 Lee CM, Neighbors C, Kilmer JR, . A brief, web-based personalized feedback selective intervention for college student marijuana use: a randomized clinical trial. Psychology of Addictive Behaviors. 2010;24(2):265–73. 10.1037/a0018859 20565152
101 Malmberg M, Kleinjan M, Overbeek G, . Substance use outcomes in the Healthy School and Drugs program: results from a latent growth curve approach. Addictive Behaviors. 2015;42:194–202. 10.1016/j.addbeh.2014.11.021 25481454
102 Malmberg M, Kleinjan M, Overbeek G, . Effectiveness of the ‘Healthy School and Drugs’ prevention programme on adolescents’ substance use: a randomized clustered trial. Addiction. 2014;109(6):1031–40. 10.1111/add.12526 24612164
103 Mason M, Light J, Campbell L, . Peer Network Counseling with Urban Adolescents: A Randomized Controlled Trial with Moderate Substance Users. Journal of Substance Abuse Treatment. 2015;58:16–24. PMID: 26234955. 10.1016/j.jsat.2015.06.013 26234955
104 Mullany B, Barlow A, Neault N, . The Family Spirit Trial for American Indian teen mothers and their children: CBPR rationale, design, methods and baseline characteristics. Prevention Science. 2012;13(5):504–18. 10.1007/s11121-012-0277-2 22932743
105 Rhee H, Hollen PJ, Belyea MJ, . Decision-making program for rural adolescents with asthma: a pilot study. Journal of Pediatric Nursing. 2008;23(6):439–50.19026912
106 Sanci L, Chondros P, Sawyer S, . Responding to Young People’s Health Risks in Primary Care: A Cluster Randomised Trial of Training Clinicians in Screening and Motivational Interviewing. PloS one. 2015;10(9):e0137581. 10.1371/journal.pone.0137581 26422235
107 Schinke SP, Fang L, Cole KC. Preventing substance use among adolescent girls: 1-year outcomes of a computerized, mother-daughter program. Addictive Behaviors. 2009;34(12):1060–4.19632053
108 Schinke SP, Fang L, Cole KC. Computer-delivered, parent-involvement intervention to prevent substance use among adolescent girls. Preventive Medicine. 2009;49(5):429–35.19682490
109 Schwinn T, Hopkins J, Schinke SP, . Using Facebook ads with traditional paper mailings to recruit adolescent girls for a clinical trial. Addictive Behaviors. 2017;65:207–13. 10.1016/j.addbeh.2016.10.011 27835860
110 Schwinn TM, Schinke SP, Di NJ. Preventing drug abuse among adolescent girls: outcome data from an internet-based intervention. Prevention science : the official journal of the Society for Prevention Research. 2010;11(1):24–32. 10.1007/s11121-009-0146-9 19728091
111 Schwinn TM, Schinke SP, Hopkins J, . An Online Drug Abuse Prevention Program for Adolescent Girls: Posttest and 1-Year Outcomes. Journal of Youth & Adolescence. 2018;47(3):490–500. PMID: 28755247. 10.1007/s10964-017-0714-4 28755247
112 Schwinn TM, Thom B, Schinke SP, . Preventing drug use among sexual-minority youths: findings from a tailored, web-based intervention. Journal of Adolescent Health. 2015;56(5):571–3. PMID: 25744209. 10.1016/j.jadohealth.2014.12.015 25744209
113 Walkup JT, Barlow A, Mullany BC, . Randomized controlled trial of a paraprofessional-delivered in-home intervention for young reservation-based American Indian mothers. Journal of the American Academy of Child & Adolescent Psychiatry. 2009;48(6):591–601. 10.1097/CHI.0b013e3181a0ab86 19454915
114 Walton MA, Bohnert K, Resko S, . Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: one year outcomes. Drug Alcohol Depend. 2013;132(3):646–53. 10.1016/j.drugalcdep.2013.04.020 23711998
115 Walton MA, Resko S, Barry KL, . A randomized controlled trial testing the efficacy of a brief cannabis universal prevention program among adolescents in primary care. Addiction. 2014;109(5):786–97. PMID: 24372937. 10.1111/add.12469 24372937
116 D’Amico EJ, Parast L, Shadel WG, . Brief motivational interviewing intervention to reduce alcohol and marijuana use for at-risk adolescents in primary care. J Consult Clin Psychol. 2018;86(9):775–86. PMID: 30138016. 10.1037/ccp0000332 30138016
117 Arnaud N, Baldus C, Elgan TH, . Effectiveness of a Web-Based Screening and Fully Automated Brief Motivational Intervention for Adolescent Substance Use: A Randomized Controlled Trial. Journal of medical Internet research. 2016;18(5):e103. PMID: 27220276. 10.2196/jmir.4643 27220276
118 D’Amico EJ, Miles JN, Stern SA, . Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. Journal of Substance Abuse Treatment. 2008;35(1):53–61. 10.1037/ccp0000332 18037603
119 Milburn NG, Iribarren FJ, Rice E, . A family intervention to reduce sexual risk behavior, substance use, and delinquency among newly homeless youth. Journal of Adolescent Health. 2012;50(4):358–64. 10.1016/j.jadohealth.2011.08.009 22443839
120 Oliansky DM, Wildenhaus KJ, Manlove K, . Effectiveness of brief interventions in reducing substance use among at-risk primary care patients in three community-based clinics. Subst Abuse. 1997;18(3):95–103. None
121 Lindenberg CS, Solorzano RM, Bear D, . Reducing substance use and risky sexual behavior among young, low-income, Mexican-American women: comparison of two interventions. Applied nursing research : ANR. 2002;15(3):137–48. PMID: 12173165.12173165
122 Catalano RF, Gainey RR, Fleming CB, . An experimental intervention with families of substance abusers: one-year follow-up of the focus on families project. Addiction. 1999;94(2):241–54. PMID: 10396792.10396792
123 The National Center on Addiction and Substance Abuse. Missed Opportunity: National Survey of Primary Care Physicians and Patients on Substance Abuse. http://www.centeronaddiction.org/addiction-research/reports/national-survey-primary-care-physicians-patients-substance-abuse. Accessed: May 17, 2016.
124 Mewton L, Visontay R, Chapman C, . Universal prevention of alcohol and drug use: An overview of reviews in an Australian context. Drug Alcohol Rev. 2018;37: Suppl 1:S435–S69. 10.1111/dar.12694 29582489
125 Garcia-Huidobro D, Doty JL, Davis L, . For Whom Do Parenting Interventions to Prevent Adolescent Substance Use Work? Prevention Science. 2018;19(4):570–8. 10.1007/s11121-017-0853-6 29150747
126 Vermeulen-Smit E, Verdurmen JE, Engels RC. The Effectiveness of Family Interventions in Preventing Adolescent Illicit Drug Use: A Systematic Review and Meta-analysis of Randomized Controlled Trials. Clinical Child & Family Psychology Review. 2015;18(3):218–39. 10.1007/s10567-015-0185-7 25998971
127 Patnode CD, O’Connor E, Rowland M, . Primary Care Behavioral Interventions to Prevent or Reduce Illicit Drug and Nonmedical Pharmaceutical Use in Children and Adolescents: A Systematic Evidence Review for the U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2014.
128 Hodder RK, Freund M, Wolfenden L, . Systematic review of universal school-based resilience interventions targeting adolescent tobacco, alcohol or illicit drug use: review protocol. BMJ open. 2014;4(5):e004718. 10.1136/bmjopen-2013-004718
129 Familias Unidas. http://familias-unidas.info/.
130 Coatsworth JD, Pantin H, Szapocznik J. Familias Unidas: a family-centered ecodevelopmental intervention to reduce risk for problem behavior among Hispanic adolescents. Clin Child Fam Psychol Rev. 2002;5(2):113–32. PMID: 12093012.12093012
131 Estrada Y, Lee TK, Huang S, . Parent-Centered Prevention of Risky Behaviors Among Hispanic Youths in Florida. Am J Public Health. 2017;107(4):607–13. PMID: 28207330. 10.2105/ajph.2017.303653 28207330
132 Estrada Y, Rosen A, Huang S, . Efficacy of a Brief Intervention to Reduce Substance Use and Human Immunodeficiency Virus Infection Risk Among Latino Youth. Journal of Adolescent Health. 2015. PMID: 26549551. 10.1016/j.jadohealth.2015.07.006 26549551
133 Strengthening Families Program. https://www.strengtheningfamiliesprogram.org/about.html.
134 Spoth RL, Redmond C, Shin C. Randomized trial of brief family interventions for general populations: adolescent substance use outcomes 4 years following baseline. J Consult Clin Psychol. 2001;69(4):627–42. PMID: 11550729.11550729
135 Spoth RL, Trudeau LS, Guyll M, . Benefits of universal intervention effects on a youth protective shield 10 years after baseline. Journal of Adolescent Health. 2012;50(4):414–7. 10.1016/j.jadohealth.2011.06.010 22443848
136 Rulison KL, Feinberg M, Gest SD, . Diffusion of Intervention Effects: The Impact of a Family-Based Substance Use Prevention Program on Friends of Participants. J Adolesc Health. 2015;57(4):433–40. 10.1016/j.jadohealth.2015.06.007 26210856
137 Feinberg ME, Jones DE, Kan ML, . Effects of family foundations on parents and children: 3.5 years after baseline. Journal of family psychology : JFP : journal of the Division of Family Psychology of the American Psychological Association (Division 43). 2010;24(5):532–42. PMID: 20954763. 10.1037/a0020837 20954763
138 Prinz RJ, Sanders MR, Shapiro CJ, . Population-based prevention of child maltreatment: the U.S. Triple p system population trial. Prevention science : the official journal of the Society for Prevention Research. 2009;10(1):1–12. PMID: 19160053. 10.1007/s11121-009-0123-3 19160053
139 Brody GH, Kogan SM, Chen YF, . Long-term effects of the strong African American families program on youths’ conduct problems. J Adolesc Health. 2008;43(5):474–81. PMID: 18848676. 10.1016/j.jadohealth.2008.04.016 18848676
140 Brody GH, Chen YF, Kogan SM, . Family-centered program deters substance use, conduct problems, and depressive symptoms in black adolescents. Pediatrics. 2012;129(1):108–15. PMID: 22157131. 10.1542/peds.2011-0623 22157131
141 Wolchik SA, Sandler IN, Millsap RE, . Six-year follow-up of preventive interventions for children of divorce: a randomized controlled trial. Jama. 2002;288(15):1874–81. PMID: 12377086.12377086
142 Leslie LK, Mehus CJ, Hawkins JD, . Primary Health Care: Potential Home for Family-Focused Preventive Interventions. American Journal of Preventive Medicine. 2016;51(4):S106–S18. 10.1016/j.amepre.2016.05.014 27498167
143 Schmidt S. Shall we Really do it Again? The Powerful Concept of Replication is Neglected in the Social Sciences. Review of General Psychology. 2009;13(2):90–100. 10.1037/a0015108
144 Patnode CD, O’Connor E, Whitlock EP, . Primary care-relevant interventions for tobacco use prevention and cessation in children and adolescents: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;158(4):253–60. 10.7326/0003-4819-158-4-201302190-00580 23229625
145 Melendez-Torres GJ, Dickson K, Fletcher A, . Positive youth development programmes to reduce substance use in young people: Systematic review. The International journal on drug policy. 2016;36:95–103. PMID: 26874990. 10.1016/j.drugpo.2016.01.007 26874990
146 Ciocanel O, Power K, Eriksen A, . Effectiveness of Positive Youth Development Interventions: A Meta-Analysis of Randomized Controlled Trials. J Youth Adolesc. 2017;46(3):483–504. 10.1007/s10964-016-0555-6 27518860
147 Dray J, Bowman J, Campbell E, . Systematic Review of Universal Resilience-Focused Interventions Targeting Child and Adolescent Mental Health in the School Setting. Journal of the American Academy of Child and Adolescent Psychiatry. 2017;56(10):813–24. 10.1016/j.jaac.2017.07.780 28942803
148 Perrin EC, Sheldrick R, McMenamy JM, . Improving parenting skills for families of young children in pediatric settings: A randomized clinical trial. Jama, Pediatr. 2014;168(1):16–24. 10.1001/jamapediatrics.2013.2919 24190691
149 Kitzman HJ, Olds DL, Cole RE, . Enduring effects of prenatal and infancy home visiting by nurses on children: follow-up of a randomized trial among children at age 12 years. Archives of pediatrics & adolescent medicine. 2010;164(5):412–8. 10.1001/archpediatrics.2010.76 20439791
150 Olds D, Henderson CR, Jr., Cole R, . Long-term effects of nurse home visitation on children’s criminal and antisocial behavior: 15-year follow-up of a randomized controlled trial. Jama. 1998;280(14):1238–44.9786373
151 Eckenrode J, Campa M, Luckey DW, . Long-term effects of prenatal and infancy nurse home visitation on the life course of youths: 19-year follow-up of a randomized trial. Arch Pediatr Adolesc Med. 2010;164(1):9–15. 10.1001/archpediatrics.2009.240 20048236
152 Ranney M, Choo E, Spirito A, . Adolescents’ preference for technology-based emergency department behavioral interventions: does it depend on risky behaviors? Pediatric emergency care [serial on the Internet]. 2013 [cited KQ Search 1 - CENTRAL; Bridge search 20190131 - CENTRAL; 29(4): Available from: http://cochranelibrary-wiley.com/o/cochrane/clcentral/articles/713/CN-00907713/frame.html.
153 Levy SJ, Kokotailo PK. Substance use screening, brief intervention, and referral to treatment for pediatricians. Pediatrics. 2011;128(5):e1330–e40.22042818
154 Grant CN, Bélanger RE. Cannabis and Canada’s children and youth. Paediatrics & child health. 2017;22(2):98–102. 10.1093/pch/pxx017 29480902
155 Harm reduction: An approach to reducing risky health behaviours in adolescents. Paediatrics & child health. 2008;13(1):53–60.19119355
156 National Institute for Health and Care Excellence. Drug misuse prevention: targeted interventions [NICE guideline NG64]. London: NICE; 2017.