# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jennifer Lin, MD, MCR, for her leadership in establishing and maintaining quality standards of Kaiser Permanente Research Affiliates EPC reports in general and her input on a draft of this report; Justin Mills, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the National Center for Injury Prevention and Control, the Division of Adolescent and School Health, and the Division of HIV/AIDS Prevention at the Centers for Disease Control and Prevention and the National Institute on Drug Abuse for providing federal partner review of the draft report; Stephen Banspach, PhD, Sharon Levy, MD, MPH, Sheryl A Ryan, MD, Harry Sumnall, PhD, Deborah Klein Walker, EdD, and Michele L. Allen, MD, MS, who provided expert review of the draft report; and Smyth Lai, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.