# Chapter 4 Discussion

## Summary of Evidence

Among the 29 included trials (and 18,353individuals), findings were inconsistent for the primary outcome of illicit and nonmedical drug use, with some trials showing clear benefits, most showing no clear benefit or harm, and two showing increased use of illicit drugs in the intervention groups (see Table 11 for a summary of evidence for each key question, including our strength-of-evidence rating). While some interventions were associated with reduced illicit and nonmedical drug use, they tended to either target a relatively narrow population (e.g., young adolescent females, or 8^th^ grade girls in foster care) with unknown or likely limited generalizability to other populations, or to have not had their results replicated. There is a growing body of evidence on substance use prevention in primary care settings, using electronically-delivered interventions, typically along with a brief one-time motivational interview with a clinician, however these studies generally found benefits only in subgroup analyses and the pattern of results was not consistent across studies.^72,^ ^80,^ ^114-116^ The previous USPSTF review on this topic concluded that there was inadequate evidence to determine whether preventive interventions were effective in reducing the likelihood of illicit drug use, based on six trials, all of which were also included in the current review.^80,^ ^92,^ ^105,^ ^107,^ ^108,^ ^114^ The current review added newly published literature and expanded the scope of this topic to include trials that were deemed feasible for implementation in a health care system even if the study was conducted in the community or other non-health care settings (i.e., clinicians and/or related staff in the primary care setting should have [or could have] the skills necessary to deliver the intervention, or could refer to others in the health system with the necessary skills). Despite this scope expansion and 23 additional included studies, we concluded that the strength of evidence that primary care-relevant interventions to prevent illicit and nonmedical drug use in children, adolescents and young adults reduce substance use was low, due to the inconsistency in effects, the relatively narrow target populations for most of the interventions that showed a benefit, and the overall lack of benefit among studies conducted in U.S. primary care settings, which were primarily limited to low-dose interventions.

Table 11 Summary of Evidence Among All 29 Included Trials (N=18,353) of Interventions to Prevent Illicit and Nonmedical Drug Use in Children, Adolescents, and Young Adults, by Key Question

Key question | No. of Studies, (No. of Observations) | Summary of findings | Consistency/precision | Other limitations | EPC assessment of overall strength of evidence | Applicability
KQ1 (Health and social/legal outcomes) | 19 (9042) | No single health, social, or legal outcome was widely reported. Family functioning was improved in 3 computer-based general prevention trials among middle school-aged females and their mothers; isolated group differences were found for delinquency (in 2 of 5 trials), global functioning (in 1 trial), and consequences of drug use (in 2 of 3 trials) in general prevention trials. Group differences were rarely found for a variety of mental health scales (9 general prevention trials, 3 Family Spirit trials). | Inconsistent, imprecise | Wide variety of instruments used; specific outcomes rarely reported by more than 4 trials; many trials limited to a narrow demographic or risk groups | Low evidence of small to no benefit | 14 conducted in the U.S., 8 limited to females, including 3 that were limited to pregnant American Indians recruited through the Indian Health Service; 4 additional trials conducted in U.S. primary care settings
KQ2 (Behavioral outcomes) | 29 (18,353) | Although some general prevention interventions were effective in reducing nonmedical and illicit drug use and other behavioral outcomes, the effects were very wide ranging and the pooled effect for drug use was not statistically significant (pooled SMD=−0.08 [95% CI, −0.16 to 0.001], k=24 [from 23 studies], n=12,801, I^2^=57.0%). Pooled estimates showed very small beneficial effects on alcohol use (SMD=−0.11 [95% CI, −0.16 to −0.07], k=23 [from 22 studies], n=12,307, I^2^=4.9%) and tobacco use SMD=−0.09 [95% CI, −0.15 to −0.03], k=15, n=8366, I^2^=35.0%). Of the 3 Family Spirit intervention trials among pregnant adolescent Native Americans, only the largest and best-quality trial found reductions in drug use and only at long-term (38-month) followup. | Inconsistent, Imprecise | Heterogeneity in outcomes reported; only 6 were rating as good quality; 10 trials had less than 12 months’ followup, which may be insufficient to find differences younger adolescents with low use levels; many trials limited to narrow demographic or risk groups | Low evidence of small to no benefit | 22 of 29 trials conducted in the U.S., 15 of which included >50% racial or ethnic minority participants; primarily targeting adolescents (vs. young adults); only 12 trials were conducted in or recruited from health care settings, including 3 that were limited to pregnant American Indians recruited through the Indian Health Service
KQ3 (Harms) | Reported:1 (322); Paradoxical findings: 2 (1925) | One Family Spirit trial found no differences in adverse events or serious adverse events, after controlling for contact time. In addition, 2 general prevention trials reported statistically significant increases in drug use outcomes, and others reported statistically nonsignificant increases in drug, alcohol, or tobacco use. | Consistency NA, imprecise | Only directly reported in 1 trial, and raw proportions were not provided, nor details of how they adjusted for contact time. | Insufficient | Trial directly reporting harms limited to pregnant Native Americans; trials showing statistically significant harmful drug outcomes conducted in Sweden and the U.S.

Abbreviations: CI = Confidence interval; EPC = Evidence-based Practice Center; k = number of studies; KQ = Key Question; NA = Not applicable; SMD = Standard mean difference; US = United States.

Among the 26 general prevention trials (i.e., those that did not target pregnant youth), the pooled estimate for illicit and nonmedical drug use was a very small effect and was not statistically significant. Only 9 of these trials were conducted in healthcare settings. Further, despite the wide range of effect sizes, we found no study, population, or intervention characteristics that were clearly associated with effect size. These interventions typically addressed substance use in general (not just illicit and nonmedical drug use) and typically had broader goals as well, such as improving family functioning and adolescent mental health, and reducing behavior problems. Pooled effects showed that these interventions were associated with lower rates of alcohol and, to a lesser extent, tobacco use, but pooled effect sizes were very small. However, small effects may be expected in these trials composed predominantly of youth who had never or only rarely used illicit drugs or other substances. Ten of trials had less than 12 months’ followup, which may be insufficient to find differences younger adolescents with low use levels. Health, social, and legal outcomes such as consequences of illicit and nonmedical drug use, health-related quality of life, depression, and other mental health symptom scales were sparsely reported in the general prevention trials and generally showed mixed results or no beneficial effects, although three trials of a computer-based intervention for young adolescent girls and their mothers consistently improved family communication, closeness, and parental monitoring.

Two initial pilot trials of the Family Spirit intervention showed minimal effects on the outcomes of interest to this review, however the full-scale trial was effective in reducing illicit and nonmedical drug use, depression, and externalizing symptoms, and is a potentially important intervention in this very high-risk, underserved population of pregnant American Indian adolescents and young adults.^83^ For most of these outcomes, benefits were seen only on long-term followup. This study also found potentially important improvements in other outcomes that were not in scope for this review, including parenting knowledge, parenting self-efficacy, home safety attitudes, and externalizing behaviors in their children.

Despite the overall conclusions, some interventions did prove effective. Among the general prevention interventions, these included the computer-based interventions targeting young adolescent females,^92,^ ^107,^ ^108,^ ^110^ the computer-based version of Familias Unidas targeting eighth-graders with behavior problems,^90^ the primary care clinician training and QI intervention,^106^ and the 46-session intervention for eighth-grade girls in foster care and their foster parents.^98^ Effects were generally maintained through 12 months or beyond in these trials. All of these interventions involved nine or more intervention sessions, all but one^110^ included components for parents or caregivers as well as the youth themselves, and all addressed a broad range of skills and topics. Meta-regressions did not show statistically significant associations between effect size and these or any other characteristics across all included general prevention studies; however, computer-based interventions targeting young adolescent females were tested with and without maternal involvement, and those with a maternal component were more consistently effective.

## Findings in Related Existing Systematic Reviews

Our observation that effective intervention tended to be fairly intensive, include parents, and target a wide range of outcomes was supported by existing systematic reviews of family-based interventions to prevent substance use that had no restriction on study setting.^124-126^ A systematic review of reviews concluded that the strongest evidence to support family-based interventions came from those that were designed to have an impact on a wide range of behaviors rather than focusing narrowly on substance use, those that required active participation of parents, and those among younger adolescents.^124^ Another review concluded that the evidence of benefit was strongest in trials that intervened with young adolescents, but it noted that some programs had been effective in preventing or reducing use in older adolescents as well.^125^ A third review also concluded that interventions targeting both parents and children were likely to be effective in preventing the use of cannabis, but noted a lack of impact on other illicit drug use.^126^ A meta-analysis of intervention components in a large review of family-based prevention programs (k=116) further determined that youth-focused content to encourage more positive family relationships and a more positive orientation toward the future were associated with larger effect sizes, suggesting the value of the youth component as well as the parent component.^61^ Many of the studies included in these review were excluded from our review because they were conducted in school settings, and many had school or community components in addition to the family-based components. We found no systematic reviews addressing substance use prevention in health care settings other than the previous USPSTF review.^127^

## Acceptability of the Included Interventions

We found minimal information on the acceptability of the included interventions to youth, parents, or clinicians. Among the included trials, four that were conducted in or recruited from health care settings reported some measure of acceptability among the youth, with generally favorable results.^80,^ ^105,^ ^106,^ ^114^ Among youth with previous-year cannabis use recruited from primary care waiting rooms and randomized to a single motivational interviewing session, 77 percent said they “liked” the intervention or liked it “a lot,” with no difference in ratings between the computer-based and interventionist-delivered versions.^114^ In the New England arm of a primary care-based trial exploring a brief computer-assisted primary care clinician screening and counseling intervention, 77 percent of youth rated the information they received from the clinicians as excellent or very good, and 59 percent said they were very likely to follow the clinician’s advice.^80^ Among youth in the intervention arm of the clinician training and QI study, 89% rated the screening and intervention process as a “good idea,” 11 percent were unsure, and none rated it as a “bad idea.” Youth ratings were very similar between the intervention and usual care groups on trust in the clinician (mean intervention score=74.6 [SD 13.6], usual care=76.7 [SD 12.3]) and likelihood of returning for future visits to discuss a wide range of complaints (intervention=96.7%, usual care=97.2%).^106^ In the study of rural youth with asthma, 100 percent reported finding the CD-ROM program helpful, 87 percent found the role-playing helpful, and 100 percent found the decisionmaking model helpful.^105^ In addition to these health care-based studies, one of the computer-based interventions reported that 83 percent of participants found the intervention messages easy to understand, 60 percent found them credible, and 66 percent found the program easy to use, and the average global rating of the program was 6.7 (SD 1.6) on a scale of 1 (worst rating) to 10 (best rating).^82^

No studies reported on how the clinicians felt about the interventions that were conducted in or recruited from healthcare settings, nor did we find other evidence related to the acceptability of illicit drug prevention interventions to primary care clinicians. Some of the healthcare-based studies provided some information on adherence, which provides insight into the feasibility of the interventions. A study that recruited adolescents from clinic waiting rooms and provided a single motivational session via either computer or in-person reported that 93 percent of participants completed their intervention within two weeks of their appointment, with most completing them the same day.^115^ Another study that recruited adolescents from appointment rosters of primary care clinics reported the 72 percent of the intervention participants received at least part of the 3-session motivational intervention promoting youth development, and 60 percent completed all three.^96^

## Extrapolation of Findings From Interventions in School Settings

Most of the studies of family-based interventions to prevent illicit and nonmedical drug use have been conducted in school classroom or after school settings, and other reviews have found these school-based prevention program to be effective in reducing illicit drug use.^128^ Two interventions that have been primarily studied in schools settings are Familias Unidas and the Strengthening Families Program. Familias Unidas^129^ is a family-based preventive intervention to improve family communication, positive parenting, and parental monitoring to reduce risky substance use and sexual behaviors in Hispanic adolescents. Participants were generally recruited from middle schools, and sessions occurred outside of school hours. The intervention generally included eight group sessions for parents and four family visits that included the adolescents.^130^ The intervention has shown reductions in illicit drug, alcohol, and cigarette use, as well as improvements in family functioning. For example, an RCT among Hispanic eighth graders and their parents (n=746) found that 30-months after baseline, illicit drug use remained stable in the intervention group while it increased in the control group.^131^ Similarly, an RCT in Hispanic ninth-graders (n=160) found that substance use initiation among girls was significantly lower at 24 months in the intervention versus control group (30.4% vs 64.0%, respectively).^132^ The online version of Familias Unidas that was used in the trial we included in this review did not find a statistically significant effect on the proportion with illicit drug use. However, the relative effect was similar in magnitude to this study, but with shorter followup, a smaller sample size, and lower baseline use levels (e.g., any illicit drug use: 7.3% [6/82] in the intervention group vs. 14.3% [14/98] in the control group, OR=0.47 [95% CI 0.09 to 2.46]).^90^ The included trial also reported statistically significant reductions in the number of use occasions over the prior 3 months for cannabis, inhalants, and misuse of prescription medications.

It is unknown whether the effects of the full in-person version of Familias Unidas would be comparable to those found in school settings if it was implemented in a health care setting. The effects of the intervention may be influenced, for example, by the fact that many of the families already know each other at the start of the intervention, the different expectations and capabilities surrounding confidentiality in schools versus primary care settings, and the role that school personnel play in participants’ lives versus that played by health care clinicians. Interestingly, we included two trials that implemented the Strengthening Families Program 10-14 (SFP10-14) and a third that heavily borrowed from the SFP10-14 materials in their intervention, but these interventions did not prove to be effective outside of school settings.^81,^ ^93,^ ^95^ The Strengthening Families Program is a widely studied intervention designed for high-risk families; several versions exist for different age groups (e.g., preschool, elementary, early teens, and high school).^133^ The program consists of 14 sessions and includes training in parenting skills, family life skills, and children’s social skills; can be implemented in various settings (e.g., schools, community centers, drug courts); and has been adapted to be culturally sensitive.^133^ A 10-year followup (n=446 families) of an RCT originally conducted in Iowa in 1993 found long-term reduction in substance use (27.5% of SFP participants had initiated illicit substance use by age 21 versus 38.3 percent control group (β=−.14, P<.001).^134,^ ^135^ There was also evidence that this program could benefit friends of participants: nonparticipants with a higher cumulative proportion of friends who participated in the SFP intervention were less likely than their peers to use drugs after 3 years.^136^ The beneficial effects of this program appear to have emerged between the 18 and 30-month assessments in most studies, and since the SFP studies included in this review followed participants for a maximum of 24 months, the lack of findings could also be due to insufficient followup. Nevertheless, the fact that the success of this program did not clearly translate to the health care setting illustrates the importance of testing the feasibility and effectiveness of prevention programs in health care settings before recommending their full-scale implementation.

## Potential Role of Primary Care in Promoting and Implementing Illicit Drug Prevention Interventions

Despite the successes of Family Spirit, Familias Unidas, SFP (outside of health care settings), and a number of other general parenting preventive interventions in schools and other settings (e.g., Family Foundations,^137^ Triple P System,^138^ Strong African American Families Program,^139,^ ^140^ New Beginnings^141^), these programs have not been widely adopted. Child wellness experts have posited primary care as an ideal home for these programs, once the benefits are established.^142^ Primary care has the potential to substantially expand the reach of these programs and reduce the stigma associated with taking a parenting class if offered routinely through health care systems as childbirth education classes are now, with primary care providers as the point of engagement. Experts have outlined a number of calls for action and research to support broader acceptance and uptake of general parenting classes,^142^ including:

- Creating an adequately funded research foundation to support integration of effective family-focused preventions programs into primary care
- Increasing public awareness of the effectiveness of family-focused prevention programs and change public norms regarding participation
- Increasing awareness, acceptance, and opportunities among primary care providers for the incorporation of preventive parenting into primary care
- Preparing a workforce that can effectively and efficiently deliver proven family-focused prevention programs in primary care settings
- Advocating for a specific focus on health in implementation efforts under the Affordable Care Act.

As valuable as these programs may be, however, such primary care-based early parenting classes may not provide support for a drug prevention counseling recommendation, since very long-term followup would be needed to determine whether these programs affect illicit drug use.

## Limitations of the Literature

Most of the limitations of the literature center on outcomes reporting. First, reporting of health, social, and legal outcomes was sparse and heterogeneous, limiting our conclusions on these important outcomes. Second, drug use outcomes were very heterogeneous. The trials were almost evenly split between reporting dichotomous and continuous outcomes, limiting our confidence in the pooled effect sizes that combined disparate outcomes. In addition, several trials did not report detailed information on the proportion of individuals in each group who used illicit drugs or the mean number of use occasions (with standard deviations) by group at each assessment. Reporting only parameter estimates without group means makes it difficult to impossible to understand the absolute effect sizes, and some trials had to be dropped from the meta-analysis altogether due to insufficient information.

The landscape in the United States is changing with regard to illicit drugs. Notably, cannabis use has been decriminalized in a growing number of states, and the infusion of fentanyl into the supply of illicit opioids has contributed to numerous accidental overdoses. It is difficult to know, for example, how the legalization of cannabis might impact effect sizes or mechanisms of change. Different approaches may be needed in states where cannabis is legally regulated, or in states that have been hit particularly hard by fentanyl and other illicit and nonmedical opioid use.

Another limitation is that almost all of the interventions were studied by the teams who developed the intervention and had not been replicated by independent researchers. This may be an especially important limitation in this field where outcomes are measured by self-report and are subject to socially desirability effects. Replication by independent investigators helps ensure that group differences are due to the intervention, rather than other factors.^143^. The importance of replication in this literature is highlighted by the fact that among the few replications by independent investigators that were included in this review, some did not replicate beneficial results.^93,^ ^95^

The results for the alcohol and tobacco outcomes do not represent all available evidence on these topics, since we only included interventions that included a drug use prevention component. The USPSTF review on tobacco use prevention in children and adolescents,^4^ for example, provides a better estimate of the potential impact of behavioral counseling interventions, with or without concomitant illicit and nonmedical drug use prevention counseling content, on tobacco use. This review found a 19 percent relative reduction in smoking initiation among participants in behavioral counseling interventions to reduce tobacco use compared to controls (risk ratio, 0.81 [95% CI, 0.70 to 0.93]).^144^

We found no evidence that included children younger than age 10, and minimal evidence on preventing illicit and nonmedical drug use in young adults. We also found very limited evidence on young adults. Most of the evidence we found in young adults focused on reduction of use in people who were regular users, hazardous users, or who had a likely substance use disorder, so were excluded from our review. These types of secondary prevention trials will be included in the USPSTF review on screening and interventions for drug misuse.

## Limitations of Our Approach

We did not include trials that did not report a drug use outcome. The literature on the prevention of illicit and nonmedical drug use is a subset of a larger substance abuse prevention literature. Among these are quite few studies that report only composite substance use outcomes, combining tobacco, alcohol, and illicit drug use without providing information specifically about illicit and nonmedical drug use. Like most of the included interventions, they target substance use broadly, usually along with other outcomes such as family functioning, mental health, behavioral problems, and other health behaviors such as risky sexual behavior, diet, and physical activity. However, they lack the specificity to support a recommendation on counseling for illicit and nonmedical drug use.

We excluded interventions that did not explicitly address prevention of illicit and nonmedical drug use in young people, although some broad prevention or resilience interventions may be effective in preventing illicit drug use. For example, some youth development interventions addressed career development, community service, academic achievement, or leadership skills, but had no direct content on illicit drug use prevention, but have been hypothesized to also prevent or reduce involvement with illicit drugs. Most of the positive youth development interventions we found were implemented in school settings, but some appeared to have been implemented in other community settings such as social service agencies. However, existing systematic reviews have not shown them to be clearly associated with illicit drug use prevention.^145,^ ^146^

Similarly, there are a number of school-based universal resilience interventions targeting child and adolescent mental health, which have been effective in reducing outcomes such as depression symptoms, internalizing and externalizing problems, and general psychological distress.^147^ Because we required a drug use outcome, we may have missed a study of a universal resilience intervention with drug-specific content that reported health outcomes but no drug use outcomes. However, in our searches, all of the interventions we found that specifically targeted illicit drug use also reported drug use outcomes.

In a similar vein, we excluded the trials of early prevention approaches in parents of young children that we found because they did not have drug-specific content in the intervention and did not report a drug use outcome; that is, we did not include studies with only intermediate outcomes such as academic achievement or behavior problems that may predict future illicit drug use. For these early childhood studies, 10 or more years of followup would have typically been needed before the children were at an age relevant for collecting illicit drug use outcomes. For example, we excluded an early intervention trial conducted in pediatric offices among families of toddlers who screened positive on a scale predictive of disruptive behavioral disorders.^148^ This study reported improvements in parenting skill (reduced harsh parenting and inconsistent discipline, increased positive parenting) and reduced child behavior problems, likely precursors of substance use during adolescence. We did find studies of an early childhood nurse home visiting intervention with long-term followup; they found a reduction in a composite substance use outcome at age 12 (combining tobacco, alcohol, and illicit drug use) and no reduction in days used drugs for the full sample at ages 15 and 19, but did find improved academic performance at age 12 for the low-SES subgroup of participants, as well as fewer arrests at ages 15 and 19.^149-151^

## Future Research Needs

Studies are needed that replicate, further refine, and broadly implement some of the interventions described in this review that showed reductions in illicit and nonmedical drug use. These include the clinician training and QI intervention,^106^ and the Familias Unidas intervention.^90^ Several of the primary care-based interventions showed a benefit for some outcomes, for some subgroup, suggesting the combination of a clinician interview and an electronic-based intervention holds promise, however the relatively small overall evidence base and inconsistencies across studies indicates a need for further study of these interventions. It would also be valuable to conduct a trial of the full in-person version of the Familias Unidas intervention in a health care setting. In addition, long-term followup for the SFP trials^81,^ ^93,^ ^95^ should be considered, as SFP trials in other settings generally found benefits only at 30 or more months of followup. Pragmatic implementation studies that integrate prevention programs into real-world practice settings are needed. Efforts to implement other proven school-based interventions that are feasible for implementation in healthcare systems would also be valuable.

It would also be valuable to continue to explore the influence of context and mechanisms of change. This information could provide insight into why some of the existing interventions were successful while other similar interventions were not. Relatedly, given the changing context in United States, understanding the impact of the legal status of cannabis on intervention effectiveness would be useful, for example.

Further work developing computer-based interventions, including as tools for primary care clinicians, is also needed. The included computer-based trials that showed a benefit were designed only for young adolescent females, so are unlikely to be helpful for (or at least have not been tested in) most youth. Results of a survey administered in an urban pediatrics department published in 2013 found that 76 percent of adolescents were interested in receiving a behavioral intervention on alcohol or illicit drugs, and 45 percent preferred technology-based (vs. in-person, telephone-based, or paper) interventions, with text messaging and internet-based modalities garnering the most votes.^152^ As use of electronic devices has grown even more ubiquitous since this survey was administered, the proportion preferring technology-based interventions may have grown even higher. Technology-based interventions represent an opportunity for wide reach, yet, according to a recent review of computer-based interventions to reduce substance use, interventions have not been tested that reach youth through games, smartphone apps, social media, and widely accessible web-based interventions, and have included minimal customization to youths’ individual demography, risk factors, and vulnerabilities.^62^ In addition, studies of implementation of those computer-based interventions that have proven to be effective should be tested among families referred from primary care to determine uptake and effectiveness in this setting.

The landscape of illicit drug use is evolving, for example with normative beliefs changing with regard to cannabis use and the rising number of deaths associated with opioid use. Research is needed to determine the extent to which general prevention interventions are effective for different substances (e.g., cannabis and opioids), and to determine when interventions are needed that target specific substance.

Finally, while this was outside the scope of our review, we nevertheless believe it is important to conduct research on current provider behavior and beliefs with regard to prevention of illicit drug use in their patients. For example, it would be useful to understand as how often they discuss illicit drug use with their young patients, how they discuss it, their beliefs on the value of discussing illicit drug use in their patients, and barriers and facilitators to such discussions. This type of formative work may provide a valuable foundation for developing interventions for delivery in healthcare systems and provide a basis for evaluating change in current practice over time.

Illicit drug use prevention outside of school settings is an emerging field. There are a number of relevant trials registered in clinicaltrials.gov (Appendix F), and we are optimistic that further research will clarify the effects of interventions to prevent illicit drug use.

## Conclusions

We found low strength of evidence that behavioral counseling interventions to prevented illicit and nonmedical substance use in young people due to inconsistency and imprecision of findings. Health, social, and legal outcomes were sparsely reported and few showed improvement. Some interventions were associated with reductions in illicit and nonmedical drug use; however, others showed no benefit and two found paradoxical increases in use.