# Chapter 3 Results

## Literature Search

We reviewed 4452abstracts and 351 full-text articles for all KQs (Appendix A Figure 1) and included 29 trials (28 RCTs, 1 CCT^80^), reported in 38 publications.^72,^ ^80-115^ The list of included and excluded studies (with reasons for exclusion) are available in Appendix B and Appendix C, respectively. We included all six trials that were included in the previous review.^80,^ ^92,^ ^105,^ ^107,^ ^108,^ ^114^ In addition, we included six trials that had been excluded by the previous review due to setting and population^83,^ ^85,^ ^98,^ ^100,^ ^110,^ ^113^ as well as 17 newly published studies. The most common reasons for exclusion were due to the intervention (included elements that are not feasible for a health care setting, such as school- and community-level components, or lacked drug-specific content), the setting (e.g., in schools or residential settings), condition (targeted youth with regular use, hazardous use, or a drug use disorder), and population (e.g., conducted in general adult populations, or among youth with psychotic disorders or who were mandated to an intervention). Six studies were excluded due to poor quality.

## Description of Included Studies

### Population and Setting

Most of the 29 included trials (N=18,353) addressed broad audiences for universal prevention, but some focused on selected populations at increased risk of substance use or harms from substance use, including three that were limited to pregnant American Indian youth ages 12 to 19 or 22 years, ^83,^ ^85,^ ^113^ as well as trials limited to girls in foster care,^98^ sexual minority teens (self-identifying as lesbian, gay, bisexual, transgender, or questioning),^112^ youth with asthma,^105^ youth who were truant^88^ or had school-related behavior problems^90^,or showed early signs of at-risk illicit drug use^103^ See Table 4 for a list of all included studies, and Tables 5 and 6 for summaries of the study and population characteristics.

Table 4 Study Characteristics of All Included Studies of Interventions to Prevent Illicit and Nonmedical Drug Use in Children, Adolescents, and Young Adults (29 Studies)

Study | Quality | No. rand (% FU) | Country | Brief population description | Baseline drug use, % used | IG description | Number of sessions (est hrs) | Other target behaviors | Intervention setting: format
Baldus, 2016^81^ | Fair | 302 (88.7) | DEU | Aged 10-14 youth not diagnosed with substance use disorder | Cannabis: 1.7; Any Drug: NR | IG1: Strengthening Families Program 10-14: 11 x 2-hour family-based group sessions to reduce risk of substance abuse and behavior problems | 11 (22) | Alc, Tob, Fam, SocLeg | Social services agency: Group (in-person)
Bannink, 2014^82^ | Fair | 1702 (73.8) | NLD | Aged 15-16 | Cannabis: NR; Any Drug: NR | IG1: 1 x 45-minute computer-based program to assess health-risk behavior and well-being with tailored messages; referred for consultation if at-risk of mental health problems or if youth self-refers | 2 (1.2) | Alc, Tob, MH, RSex | School: Individual (in-person), Computer-based
Bannink, 2014^82^ | Fair | 1702 (73.8) | NLD | Aged 15-16 | Cannabis: NR; Any Drug: NR | IG2: 1 x 45-minute computer-based program to assess health-risk behavior and well-being with tailored messages; option to self-refer to nurse | 1 (0.8) | Alc, Tob, MH, RSex | School: Computer-based
Barlow, 2006^85^ | Fair | 53 (77.4) | US | Pregnant American Indian youth aged 12 to 19 | Cannabis: NR; Any Drug: NR | IG1: Family Spirit: 25 x 90-minute in-home sessions on parenting, substance abuse prevention, coping, and other maternal and infant health topics | 25 (37.5) | Alc, Oth | Home: Individual (in-person)
Barlow, 2013^83^ | Good | 322 (92.0) | US | Pregnant American Indian youth aged 12-19 | Cannabis: 78.88; Any Drug: NR | IG1: Family Spirit: 43 x 60-minute in-home sessions on parenting, substance abuse prevention, coping, and other maternal and infant health topics | 43 (43) | Alc, Oth | Home: Individual (in-person)
D’Amico, 2018^116^ | Fair | 1702 (73.8) | US | Adolescents aged 12 to 18 at risk for alcohol abuse | Cannabis: NR; Any Drug: NR | IG1: 1 x 15-20 minute individual brief motivational interview for youth focusing on motivation to change and substance use prevention | 1 (0.3) | Alc | Primary Care: Individual (in-person)
Dembo, 2016^88^ | Fair | 300 (93.7) | US | Truant youth, aged 11-17 | Cannabis: 82.3; Any Drug: NR | IG1: 2 x 75-min youth sessions on substance use and consequences 1 x 75-min parent session on parental attitudes of use | 3 (3.8) | SocLeg | Home: Individual (in-person)
Dembo, 2016^88^ | Fair | 300 (93.7) | US | Truant youth, aged 11-17 | Cannabis: 82.3; Any Drug: NR | IG2: 2 x 75-minute individual sessions on substance use and consequences | 2 (2.5) | SocLeg | Home: Individual (in-person)
Estrada, 2018^90^ | Fair | 230 (75.2) | US | Eighth graders with behavior problems | Cannabis: NR; Any Drug: NR | IG1: Online version of Familias Unidas (eHealth Familias Unidas); 8 x 30-min online recorded e-parent group sessions accessed via the internet and 4 x 45-min parent-adolescent family sessions delivered by a facilitator via web-based video conferencing software | 12 (7) | Alc, Tob, Fam, RSex | Home: Computer-based, Video
Fang, 2010^92^ | Good | 108 (96.3) | US | Asian American girls, aged 10-14 | Cannabis: 3.8; Any Drug: NR | IG1: 10 x 35-45-minute interactive online sessions for mother-daughter dyads on family functioning, self-efficacy, social skills, and drug use prevention | 10 (7.5) | Alc, Tob, Fam, MH | Home: Computer-based
Foxcroft, 2016^93^ | Fair | 614 (75) | POL | Children ages 10 to 14 | Cannabis: NR; Any Drug: 4 | IG1: Strengthening Families Program 10-14: 7 x 120-min group substance use prevention sessions for parent-youth dyads | 7 (14) | Alc, Tob, Fam | NR: Group (in-person), Video
Gmel, 2013^94^ | Fair | 853 (79) | CHE | Male conscripts, age 19 or greater | Cannabis: 46; Any Drug: NR | IG1: 2 x 20-minute counseling sessions targeting multi-substance use behaviors in men ages 19 and older | 2 (0.7) | Alc, Tob | Other Medical: Individual (in-person)
Harris, 2012^80^ | Fair | 2685 (76.5) | US, CZE | Aged 12-18 (New England) or 13-17 (Prague) with a routine primary care appointment | Cannabis: 13.2; Any Drug: NR | IG1: 1 x 7-8-minute computer and clinician-based screening and intervention to not start/stop substance use | 1 (0.1) | Alc | Primary Care: Individual (in-person), Computer-based
Jalling, 2016^95^ | Fair | 271 (83.8) | SWE | At-risk youth not being treated for alcohol or drug use, aged 12-18 | Cannabis: NR; Any Drug: 16.9 | IG1: 6 x 120-min group sessions to increase parental understanding of youth development & skill improvement | 6 (12) | Alc, Fam, SocLeg | NR: Group (in-person)
Jalling, 2016^95^ | Fair | 271 (83.8) | SWE | At-risk youth not being treated for alcohol or drug use, aged 12-18 | Cannabis: NR; Any Drug: 16.9 | IG2: 10 x 150-minute group parent sessions to help to develop and enhance their skills and self-efficacy for parenting | 10 (25) | Alc, Fam, SocLeg | NR: Group (in-person)
Johnson, 2015^96^ | Fair | 200 (85.0) | US | Aged 14 to 21 with a primary care appointment | Cannabis: 18.5; Any Drug: NR | IG1: 3 positive youth development motivational interview sessions with phone or email followup targeting career readiness and addressing risky behaviors (time NR) | 6 (1.8) | RSex, SocLeg | Primary Care: Individual (in-person)
Kerr, 2013^97^ | Fair | 1654 (90.4) | US | Aged 14 to 17 | Cannabis: NR; Any Drug: NR | IG1: 2 x 8-hour group workshops covering diet, physical activity, and drug prevention | 2 (16) | Alc, Oth | NR: Group (in-person)
Kim, 2011^98^ | Good | 100 (90.0) | US | Girls in foster care, aged 10-12 | Cannabis: NR; Any Drug: NR | IG1: 6 group sessions of caregiver training; 6 group sessions of skill-building and 40 individual coaching sessions for adolescent girls (time NR) | 46 (86) | Alc, Tob, Fam, MH, RSex, SocLeg | NR: Individual (in-person), Group (in-person)
Knight, 2019^72^ | Fair | 871 (87.5) | US | Adolescents aged 12 to 18 | Cannabis: 12.2; Any Drug: NR | IG1: 1 X 2 to 5-minute conversation about the risks of substance abuse using motivational interviewing strategies | 1 (0.2) | Alc | Primary Care: Individual (in-person)
Lee, 2010^100^ | Good | 341 (94.4) | US | Incoming college freshmen with any use of cannabis in previous 3 months | Cannabis: NR; Any Drug: NR | IG1: 1 computer-based individualized personalized feedback session (time NR) | 1 (0.5) | – | Home: Computer-based
Malmberg, 2014^102^ | Fair | 2416 (92.0) | NLD | Aged 11 to 17 | Cannabis: NR; Any Drug: NR | IG1: 3 interactive modules (1 module per year for 3 years) on substance use prevention (time NR) | 3 (1.5) | Alc, Tob | School: Computer-based
Mason, 2015^103^ | Fair | 119 (98) | US | Youth at risk for substance use disorder, aged 14-18 | Cannabis: NR; Any Drug: NR | IG1: 1 x 20-minute individual motivational interviewing session with peer network counseling | 1 (0.3) | Alc | NR: Individual (in-person)
Rhee, 2008^105^ | Fair | 41 (85) | US | Youth with asthma, aged 14-20 | Cannabis: NR; Any Drug: NR | IG1: 3 x 30-min CD-ROM sessions covering decision-making and risk behaviors | 3 (3.2) | Alc, Tob | Other Medical, Home: Individual (phone), Computer-based
Sanci, 2015^106^ | Fair | 901 (68.8) | AUS | Aged 14-24, attending a primary care visit | Cannabis: NR; Any Drug: 26.5 | IG1: Clinician training to screen for risky behaviors and discuss protective factors with youth, plus supported plan-do-study-act cycle. | 1 (0.2) | Alc, Tob, MH, RSex, SocLeg | Primary Care: Individual (in-person)
Schinke, 2009a^107^ | Fair | 591 (90.0) | US | Females aged 11 to 13 | Cannabis: 2.7; Any Drug: NR | IG1: 9 x 45-minute individual computer sessions for mother-daughter dyads aimed to reduce substance use through mother-daughter interactions | 9 (6.8) | Alc, Tob, MH, Fam | Home: Computer-based
Schinke, 2009b^108^ | Good | 916 (94) | US | Females aged 11 to 13 | Cannabis: NR; Any Drug: NR | IG1: 9 X 45-minute weekly computer-based substance use prevention sessions plus two annual booster sessions for mother-daughter dyads | 11 (8.2) | Alc, Tob, MH, Fam | Home: Computer-based
Schwinn, 2010^110^ | Fair | 236 (91) | US, CAN | Females aged 13-14 | Cannabis: NR; Any Drug: NR | IG1: RealTeen: 12 x web-based modules and homepage access to curated online community | 12 (5) | – | Home: Computer-based
Schwinn, 2015^112^ | Fair | 236 (85) | US | Sexual-minority adolescents, aged 15-16 | Cannabis: NR; Any Drug: NR | IG1: 3 x 14-minute individual computer sessions for youth | 3 (0.7) | – | Home: Computer-based
Schwinn, 2018^111^ | Good | 788 (96.5) | US | Females aged 13 to 14 residing in the United States | Cannabis: NR; Any Drug: NR | IG1: RealTeen: 9 x 15-minute online substance use prevention sessions for girls aged 13-14 | 9 (2.8) | – | Home: Computer-based
Walkup, 2009^113^ | Fair | 167 (68.9) | US | Pregnant American Indian youth, aged 12-22 | Cannabis: NR; Any Drug: NR | IG1: Family Spirit: 25 x 60-minute in-home sessions on parenting, substance abuse prevention, and problem-solving and coping skills | 25 (25) | Alc, Oth | Home: Individual (in-person)
Walton, 2013^114^ | Fair | 328 (85) | US | Youth with previous-year cannabis use, aged 12 to 18, attending a primary care visit | Cannabis: 100; Any Drug: NR | IG1: 1 MI session (time NR) | 1 (0.6) | Alc | Primary Care: Individual (in-person)
Walton, 2013^114^ | Fair | 328 (85) | US | Youth with previous-year cannabis use, aged 12 to 18, attending a primary care visit | Cannabis: 100; Any Drug: NR | IG2: 1 computer-based MI session (time NR) | 1 (0.6) | Alc | Primary Care: Computer-based
Walton, 2014^115^ | Fair | 714 (88.1) | US | Youth with no cannabis use in previous year, aged 12-18, attending a primary care visit | Cannabis: 0; Any Drug: 6.9 | IG1: 1 x 38-minute MI session | 1 (0.6) | Alc | Primary Care: Individual (in-person)
Walton, 2014^115^ | Fair | 714 (88.1) | US | Youth with no cannabis use in previous year, aged 12-18, attending a primary care visit | Cannabis: 0; Any Drug: 6.9 | IG2: 1 x 33-minute computer-based MI session | 1 (0.6) | Alc | Primary Care: Computer-based

Abbreviations: Alc = Alcohol; AUS = Australia; CAN = Canada; CHE = Switzerland; CZE = Czech Republic; DEU = Germany; Est hrs = Estimated hours; Fam = Family functioning; FU = Followup; IG = intervention group; MH = Mental health; NR = Not reported; NLD = Netherlands; Oth = Other health behavior; POL = Poland; RSex = Risky sexual behavior; SocLeg = Social-legal; SWE = Sweden; Tob = Tobacco; US = United States.

Table 5 Summary of Study Characteristics of All Included Studies of Interventions to Prevent Illicit and Nonmedical Drug Use in Children, Adolescents, and Young Adults (29 Studies, N=18,353)

Characteristics | No. studies | %
All studies | 29 | 100
Study design
RCT | 24 | 83
Cluster RCT | 4 | 14
CCT | 1 | 3
Quality rating^*^
Good | 6 | 21
Fair | 23 | 79
Conducted in the US | 22 | 76
Recruitment setting
Primary care | 11 | 38
Other health care | 1 | 3
School (only) | 4 | 14
Online, media (only) | 6 | 21
Other | 7 | 24
Prevention type
Universal | 20 | 69
Selective | 9 | 31
Drug focus
Cannabis | 5 | 17
Any drug use | 24 | 83
Primary Intervention Outcomes
Drug only | 4 | 14
Drug and alcohol | 6 | 21
Drug, alcohol, tobacco | 3 | 10
Drug and nonsubstance | 2 | 7
Substance use and nonsubstance | 14 | 48
Non-substance outcomes^†^
Family functioning | 8 | 28
Risky sexual behavior | 5 | 17
Mental health | 6 | 21
Other | 10 | 34
Control Group
No. intervention/usual care | 17 | 59
Minimal intervention | 7 | 24
Attention control | 5 | 17
Median sample size (IQR), Range | 322; (230-853) | 41-2685
Median % followup at 6 to 12 months (IQR), Range | 87.5; (79.0-92.0) | 68.8-98.0

* 6 additional studies were rated as poor quality and excluded from the review.

† Interventions may have multiple non-substance-related primary outcomes.

Abbreviations: CCT = Controlled clinical trial; IQR = Interquartile range; No. = Number; RCT = Randomized controlled trial; US = United States.

Table 6 Summary of Population Characteristics of All Included Studies of Interventions to Prevent Illicit and Nonmedical Drug Use in Children, Adolescents, and Young Adults (29 Studies)

Characteristics | No. of trials | % of all trials or SD
Limited to pregnant adolescents | 3 | 10
Age; Mean, SD^*^ | 14.9 | 2.0
Age group
Middle school (~10-14) | 10 | 35
High school (~14-17) | 3 | 10
Young adults (~18-25) | 2 | 7
Wide age range | 14 | 48
Majority Hispanic or non-white^†^ | 15 | 68
| Total % across all trials | IQR (No. trials reporting)
Female | 59.4 | 50-66.5 (29)
Race^†^
% Black | 38.9 | 8.1-63.7 (17)
% Asian | 6.4 | 1.2-5.6 (8)
% Native American | 20.0 | 0.1-0.3 (8)
% White | 42.1 | 11.5-72.3 (15)
Hispanic ethnicity^†,‡^ | 16.5 | 8.6-23.1 (16)
Used cannabis, Median % | 24.0 | 12.2-18.5 (11)
Used alcohol, Median % | 37.7 | 32.3-53.1 (11)

* Mean across all trials, weighted by number randomized in each trial.

† Limited to trials conducted in the US (21 trials).

‡ Assuming majority white, non-Hispanic if race and ethnicity were not reported.

Abbreviations: IQR = Interquartile range; SD = Standard deviation; US = United States.

In addition to the trials conducted exclusively with pregnant females, several others were limited to females,^92,^ ^98,^ ^107,^ ^108,^ ^110,^ ^111^ and one was limited to Swiss male conscripts.^94^ Collectively, the trials included young people ages 10 through 24 years. Ten trials (35%) recruited only pre-adolescents and young adolescents (approximately 10-14 years),^81,^ ^90,^ ^92,^ ^93,^ ^98,^ ^102,^ ^107,^ ^108,^ ^110,^ ^111^ two (7%) recruited young adults (17 or 19 years and older),^94,^ ^100^ and the remaining either focused on high school-aged youth or covered a wide age range inclusive of high school age. Twenty-two (76%) of the included trials were conducted in the United States, and the remaining were in Germany,^81^ the Netherlands,^82,^ ^102^ Poland,^93^ Czech Republic,^94^ Sweden,^95^ and Australia.^106^ One trial had sites in both the United States and the Czech Republic.^80^ Reporting of race and ethnic background of participants was incomplete, but among the 21 trials conducted in the United States, three were limited to Native American females,^83,^ ^85,^ ^113^ one was limited to females of Asian descent,^92^ and ten included a majority of black and Hispanic youth.^88,^ ^90,^ ^96,^ ^97,^ ^103,^ ^107,^ ^108,^ ^114-116^ Detailed information on race and other population characteristics is provided in Appendix D Table 1. Participants in twelve of the trials were recruited from health care settings: primary care clinics,^72,^ ^80,^ ^96,^ ^103,^ ^106,^ ^114-116^ rural outpatient clinics,^105^ or the Indian Health Service.^83,^ ^85,^ ^113^

Baseline substance use was variably reported (see Appendix D Table 1). Two trials were limited to youth who had used cannabis in the previous 3 months^100^ or one year,^114^ and one trial was limited to youth with no cannabis use in the previous year.^115^ Of all 11 trials reporting the proportion or participants with cannabis use at baseline, the median was 24.0 percent with previous use (interquartile range [IQR], 12.2% to 18.5%, with recall periods ranging from lifetime to the previous month). The median proportion with previous alcohol use at baseline was 37.7 percent (IQR 32.3% to 53.1%), among the 11 trials reporting the proportion with previous alcohol use.

### Intervention Characteristics

Table 7 shows a summary of the intervention characteristics for all 34 intervention groups in the 29 included trials, and detailed information is available in Appendix D Tables 2 and 3. The aims of almost all interventions included other outcomes in addition to illicit drug use. Only four appeared to focus on illicit drugs without explicit discussion of other substances or behaviors.^100,^ ^110-112^ Nine trials focused broadly on substance use, including alcohol and/or tobacco, in their intervention messages.^72,^ ^80,^ ^94,^ ^102,^ ^103,^ ^105,^ ^114-116^ The remaining were broad prevention trials that addressed additional behaviors such as family functioning,^81,^ ^90,^ ^92,^ ^93,^ ^95,^ ^98,^ ^107,^ ^108^ risky sexual behavior,^82,^ ^90,^ ^96,^ ^98,^ ^106^ broader mental health and emotional well-being (including social skills training),^82,^ ^92,^ ^98,^ ^106-108^ truancy and delinquent behaviors,^88^ and breastfeeding and infant care.^83,^ ^85,^ ^113^

Table 7 Summary of Intervention Characteristics of Included Studies of Interventions to Prevent Illicit and Nonmedical Drug Use in Children, Adolescents, and Young Adults (34 Intervention Arms)

Characteristics | Median (IQR) | Range
Median duration (IQR), Range | 6 weeks; (1 day - 26 weeks) | 1 day – 3 years
Median no. sessions (IQR), Range | 3 (1-10) | 1-46
Median estimated planned contact hours (IQR), Range | 2.8 (0.6-12) | 0.1-86
| No. groups | %
Intervention participant
Youth only | 23 | 68
Youth and parent | 8 | 23
Parent only | 2 | 6
Clinician (for youth counseling) | 1 | 3
Format
Individual counseling (in person or phone-based) | 17 | 50
Computer-based (entirely) | 12 | 35
Group sessions offered | 6 | 18
Group AND individual counseling | 1 | 3
Setting
Primary care | 9 | 26
Other medical | 2 | 6
School^*^ | 3 | 9
Other or NR | 20 | 59
Primary care clinician involved in intervention delivery | 3 | 9
Total number of intervention groups | 34 | 100

* Studies in school settings were only included if they used schools only for recruitment purposes, as long as they recruited from multiple schools and met at locations other than schools, or if they studied entirely online interventions that did not involve interactions among students at the same school or between students and teachers.

Abbreviations: IQR = Interquartile range; No. = Number; NR = Not reported.

Across all trials, planned intervention dose was variable, with a median of three sessions (IQR 1-10 session), but a range of 1 10-minute session to 46 sessions. Duration ranged from 1 day to over 3 years, with a median of 6 weeks (IQR, 1 day–26 weeks). The intervention with the greatest number of sessions was a 46-session intervention among girls in foster care and their caregivers, initiated the summer before the girls entered eighth grade.^98^ The intervention involved six 2-hour group sessions for caregivers and the girls separately, followed by up to 40 individual coaching sessions for the girls that focused on establishing and maintaining positive peer relations, increasing knowledge of accurate norms for problem behaviors, and increasing self-competence in academic and social areas. Coaches also emphasized the risks of substance use and discussed issues around dating and partner relations. On average, participants completed 5.6 of the 6 group sessions and 20 of the 40 individual coaching sessions.

Interventions for 12 of the trials were delivered exclusively through a computer;^82,^ ^90,^ ^92,^ ^100,^ ^102,^ ^107,^ ^108,^ ^110-112,^ ^114,^ ^115^ two of these were delivered within school classroom settings but were included in this review because they had no interactive components involving the teachers or other students.^82,^ ^102^ Another computer-based intervention was an online version of Familias Unidas and involved eight online, prerecorded simulated parent group sessions that were accessed via a website and four interactive parent-adolescent family sessions that were delivered by a trained facilitator.^90^ This was a computer-based adaptation of a widely-studied intervention usually delivered to groups in an after-school setting. Like the after-school versions, the online version included in this review covered family communication, supportive parenting, and parental monitoring, with specific content addressing substance use and risky sexual behavior. Participants viewed and attended an average of 8.9 of the 12 sessions (combining the group videos and the interactive family sessions), and 72 percent completed all four of the family sessions.

Three computer-based interventions targeted mothers and daughters, with separate and joint activities.^92,^ ^107,^ ^108^ These interventions involved nine to 12 sessions that typically required 45 minutes per session. The program helped mothers learn to better communicate with their daughters, monitor their daughters’ behavior and activities, build their daughters’ self-image and self-esteem, establish rules about and consequences for substance use, create family rituals, and refrain from communicating unrealistic expectations. The girls acquired skills for managing stress, conflict, and mood; for resisting peer pressure; and for enhancing body esteem and self-efficacy. Only one of these studies reported adherence, finding that 97 percent of participants completed all available sessions.^107^

Interventions for seven trials (with 9 intervention arms) took place in primary care settings.^72,^ ^80,^ ^96,^ ^106,^ ^114-116^ One of the primary care-based interventions centered on clinician training, providing education and personal coaching (based on role plays with adolescent actors) for screening and counseling during primary care visits to reduce risky behaviors (tobacco use, alcohol use, illicit drug use, risky sex, unsafe driving/passenger safety) and increase protective behaviors.^106^ This intervention also included print materials for patients and clinicians and a supported plan-do-study-act cycle of continuous quality improvement (QI). Two of the primary care-based interventions were parallel studies, recruiting from the same larger population but limiting one study to youth with no cannabis use in the prior year^115^ and one to youth with cannabis use in the prior year.^114^ These trials had both in-person and online-only versions of the motivational interview intervention, but somewhat different intervention content. One of these reported that 93 percent of participants completed the interventions immediately or within 2 weeks of their appointment.^115^ Other similar primary care-based trials involved a single in-person motivational interviews.^72,^ ^80,^ ^116^ Four of these primary care-based trials had majority black and Hispanic or majority non-white samples.^72,^ ^114-116^

Three trials examined a home-visiting intervention for pregnant American Indian adolescents and young adults recruited through the Indian Health Service.^83,^ ^85,^ ^113^ The intervention (Family Spirit) involved 25 to 43 highly structured, culturally tailored, pre- and post-natal home visits by Native paraprofessionals that covered three target domains: parenting skills across early childhood, maternal life skills and psychosocial development, and maternal drug abuse prevention. The largest and best quality of these trials reported that 74 percent of participants completed at least 50 percent of the Family Spirit lessons by 12 months postpartum^83^; adherence rates were higher in the other two, which were characterized as pilot studies.^85,^ ^113^

### Quality Assessment

Six trials were rated as good-quality and the remaining 23 were fair-quality; six were excluded due to poor quality.^117-122^ Among those excluded, very high attrition was the most common concern, but two had other concerns, including lack of assurance of baseline comparability along with either missing important information or additional more minor concerns about other methods issues. Several had generally good methods but were graded down for high attrition.^82,^ ^96,^ ^102,^ ^106,^ ^115,^ ^116^ The remaining trials that were rated as fair-quality typically had more than one area where methodologic standards were not clearly met. The most common concerns were high attrition (>10%); differential attrition between groups (by >10%); lack of information on comparability between groups at baseline; and minor concerns or lack of reporting on randomization methods, allocation concealment, and blinding of outcomes assessment.

## KQ1 Do Primary Care-Feasible or Referable Interventions to Prevent Drug Use in Children, Adolescents, and Young Adults Improve Health Outcomes or Other Related Outcomes?

### Summary of Results

Health, social, or legal outcomes were reported in 16 of the general prevention trials^81,^ ^82,^ ^88,^ ^90,^ ^92,^ ^93,^ ^95,^ ^98,^ ^100,^ ^106-108,^ ^111,^ ^114-116^ and all three Family Spirit trials.^83,^ ^85,^ ^113^ No single outcome was widely reported. Mental health outcomes were the most commonly-reported health outcomes, and were reported by 9 of the general prevention trials^81,^ ^82,^ ^92,^ ^93,^ ^95,^ ^98,^ ^107,^ ^108,^ ^111^ and all three Family Spirit trials.^83,^ ^85,^ ^113^ Most general prevention trials found no group differences on mental health symptom scales after 3 to 24 months, and results were mixed in the Family Spirit trials. There were beneficial findings for family functioning outcomes (family communication, parental monitoring, and maternal closeness) in three general prevention trials examining computer-based interventions among middle school-aged females and their mothers^92,^ ^107,^ ^108^ (Figure 2) at up to 24 months’ followup. Other outcomes examined in the general prevention trials included consequences of illicit drug use (3 trials),^100,^ ^114,^ ^116^ health-related quality of life (1 trial),^82^ arrests (1 trial).^88^ No studies reported mortality or morbidity outcomes.

Figure 2 Mental Health and Family Functioning Outcomes Summary (KQ1) Among the General Prevention Trials, Standardized Mean Difference Between Intervention and Control Groups, by Outcome, for Main Timepoint Only

*Mean value at followup, rather than change from baseline.

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; MH = mental health; SD = standard deviation.

Note: Effect sizes include a variety of measures reported by studies, if available, or a calculated between-group difference if study-reported values were not reported; effects include mean difference in change between groups, mean difference between groups at followup, regression parameter estimates (e.g., beta-weights, b-weights), Cohen’s d.

This figure is a forest plot of a summary of mental health and family functioning outcomes among the general prevention trials, showing standardized mean difference between intervention and control groups, by outcome, for the main timepoint only.

### Detailed Results

All health, social, or legal outcomes are shown in Appendix D Table 4, which were reported in 16 of the general prevention trials^81,^ ^82,^ ^88,^ ^90,^ ^92,^ ^93,^ ^95,^ ^100,^ ^106,^ ^111,^ ^115,^ ^116,^ ^98,^ ^107,^ ^108,^ ^114^ None of the general prevention trials reported mortality, nor did any report on the onset of medical conditions. The most commonly reported health, social or legal outcomes were measures of mental health symptoms or functioning, reported in 9 general prevention trials.^81,^ ^82,^ ^92,^ ^93,^ ^95,^ ^98,^ ^107,^ ^108,^ ^111^ There were very few statistically significant group differences at any followup timepoint on any mental health outcomes among study-reported adjusted analyses, although there were some additional statistically significant group differences among unadjusted results that we calculated based on reported means and standard deviations. A sample of mental health outcomes reported in the general prevention trials are shown in Figure 2, selecting the main followup (6–12 months, or the closest) for the most intensive or comprehensive intervention group in each trial, if there were multiple groups. These findings are representative of the larger body of evidence for mental health-related outcomes, with all followups, intervention groups, and subgroup analyses (Appendix D Table 4). Effect sizes shown include many difference types of study-reported effects, including regression model parameter estimates, mean ratios, Cohen’s Ds, and between-group differences in change or in post-test scores.

The next most commonly-reported health, social, or legal outcomes in the general prevention trials were related to family functioning, reported in three computer-based intervention trials among middle school-aged females and their mothers.^92,^ ^107,^ ^108^ as well as the Familias Unidas trial^90^ and one of the Strengthening Families Program trials.^93^ Improvement in several family functioning outcomes (family communication, parental monitoring, and maternal closeness) were found in the three trials targeting middle school-aged females and their mothers^92,^ ^107,^ ^108^ (Figure 2, Appendix D Table 4). Across all timepoints (up to 24 months), differences in change between groups most commonly ranged from 0.3 to 0.6 on a 5-point scale. The other two trials did not find group differences on measures of communication, ^90,^ ^93^ parental monitoring,^90^ or positive parenting.^90^

Three general prevention trials reported on scales measuring consequences of illicit drug use.^100,^ ^114,^ ^116^ Two measured consequences on a scale that included items related to failure to maintain family and school responsibilities and difficulties with friends and family members due to illicit and nonmedical drug use, as well as symptoms of heavy or problematic use such as withdrawal symptoms and being unable to stop using.^100,^ ^114^ The other reported that participants were asked about four consequences related to cannabis use but specified only one of the items (trouble concentrating). One trial of a single-session online intervention for 17- to 19-year-olds with any cannabis use in the previous 3 months found no group differences at 3- or 6-month followups, with between-group differences in change ranging from 0.15 to 0.23 on a 72-point scale.^100^ The trial of a primary care-based motivational intervention in youth with cannabis use in the previous year, found differences only at 3 months’ followup (and not at 6 or 12 months) in the intervention group that completed their intervention entirely online (IG2), but no benefit for those with direct in-person counseling (IG1). At 3 months, the computer-only intervention group participants’ scores had declined by a mean of 2.8 points (SD 15.3) while control participants’ scores had declined by 0.4 points (SD 15.1, between-group p<0.05 for the study-reported treatment effect estimate). The range of this scale was not reported.^114^ The final trial, another primary care-based intervention involving a single motivational interview, found a declining trajectory in the intervention group but an increasing trajectory in the usual care group, with statistically significant differences at the 12-month followup (Mean [SD] scores: IG: 0.9 [3.3]; CG: 2.4 [9.3], p=0.04).^116^

One trial each reported on health-related quality of life^82^ and arrests.^88^ For health-related quality of life, a trial of two very similar brief online interventions reported improved health-related quality of life at 4 months’ followup for one group.^82^ Compared with a mean 0.1-point increase in the control group, intervention group scores increased by 3.9 (SD 17.3) and 2.4 (SD 18.5) points on a 100-point scale in the two intervention groups, although the difference was statistically significant in only one group (p<0.001 and 0.35, respectively). For arrests, a trial that involved two 75-minute intervention sessions with truant youth, with or without an additional parent session, reported a lower proportion of participants with official arrest charges at 25 months’ followup (but not at earlier followup assessments), but only for the intervention group that did not include a parent session.^88^

Among the Family Spirit intervention trials, all three reported depression symptoms. Only the largest and best-quality trial found group differences,^83^ and only at the last (38-month) followup (Figure 3). In this trial, the mean intervention group CESD score had declined by 0.9 points on a 60-point scale while the control mean had increased by 0.3 points. This trial also reported internalizing, externalizing, overall mental health score from the Problem-Oriented Screening Instrument for Teens, and a total emotion and behavior problem T-score. While all point estimates were in the direction of benefit, the only statistically significant finding was for externalizing.^83^ At the 38-month followup, the intervention group mean had declined of 0.6 points on a 100-point scale, compared with a 0.4-point increase in the control group. No other health, social, or legal outcomes pertinent to this review were reported, including mortality and disease onset.

Figure 3 Mental Health Outcomes Summary (KQ1) Among the Family Spirit Trials, Mean Difference Between Intervention and Control Groups, by Outcome

*Mean value at followup, rather than change from baseline.

Abbreviations: CES-D = Center for Epidemiologic Studies Depression Scale; CG = control group; CI = confidence interval; IG = intervention group; SD = standard deviation.

Note: Effect sizes are study-reported mean differences at followup (for Barlow, 2006, and Barlow, 2013) and beta-weight (Walkup, 2090).

This figure is a forest plot of a summary of mental health outcomes among the Family Spirit trials, showing mean difference between intervention and control groups, by outcome.

## KQ2 Do Primary Care-Feasible or Referable Interventions to Prevent Drug Use in Children, Adolescents, and Young Adults Improve Drug Use Outcomes?

### Summary of Results

The effects of the general prevention interventions on illicit and nonmedical drug use were wide ranging, and the pooled effect was not statistically significant (pooled SMD=−0.08 [95% CI, −0.16 to 0.001], k=24 [from 23 studies], n=12,801, I^2^=57.0%, Figure 4, Table 8), with results primarily reflecting 6 to 12 months of followup, primarily among adolescents. The pooled OR for any illicit drug use or any cannabis use was 0.82 (95% CI, 0.67 to 1.04, k=12 [11 studies], n=9031, I^2^=38.2%, Table 8). Among trials reporting any use of either cannabis or all illicit drugs, absolute proportions using at followup ranged from 2.3 to 38.6 percent in the control groups and 2.4 to 33.7 percent in the intervention groups. The median absolute risk difference between groups was −2.8 percent, favoring the intervention group (range, −11.5% to +14.8%). When examining times used in the previous 3 months, the pooled mean difference (MD) between groups was −0.21 times (95% CI, −0.44 to 0.02, k=11, n=3651, I^2^=51.0%, Table 8). Some interventions did show a benefit at one or more followups,^80,^ ^90,^ ^92,^ ^96,^ ^106-108,^ ^110,^ ^114,^ ^115^ but many showed no clear evidence of benefit and two reported increased illicit drug use in youth participating in the interventions for at least one drug-related outcome.^95,^ ^97^ 10 trials had less than 12 months’ followup, which may be insufficient to find differences younger adolescents with low use levels. We investigated a number of possible effect modifiers (study, population, intervention, and control characteristics) and none appeared to explain variability in effect sizes (Figure 2), and there was no evidence of a small studies effect. Pooled effects for alcohol and tobacco use both showed statistically significant but very small benefits (alcohol pooled SMD= −0.11 [95% CI, −0.16 to −0.07], k=23 [from 22 studies], n=12,307, I^2^=4.9%; tobacco pooled SMD=−0.09 [95% CI, −0.15 to −0.03], k=15, n=8366, I^2^=35.0%, Table 8, Figures 5 and 6). Other behavioral outcomes reported included delinquent behavior (5 trials)^98,^ ^88,^ ^93,^ ^95,^ ^115^ risky sexual behavior (3 trials),^82,^ ^90,^ ^106^ and unsafe driving or riding (3 trials),^72,^ ^106,^ ^114^ with most trials finding no differences between groups.

Figure 4 Primary Drug Use Outcome (KQ2) for General Prevention Trials, Standardized Mean Difference Between Intervention and Control Group, Sorted by Specific Outcome

*Mean value at followup, rather than change from baseline.

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; NS = Not significant; SD = Standard deviation.

This figure is a forest plot of primary drug use outcome for general prevention trials, showing standardized mean difference between intervention and control group, sorted by specific outcome.

Table 8 Summary of Meta-Analysis Results for Substance Use Outcomes for General Prevention Trials (KQ2)

Outcome | No. studies | Type of effect | Pooled result (95% CI) | No. studies (k) in MA | I^2^, % | Tau^2^ | N | Range of effects^*^ | Median (IQR) effects^*^
Primary drug outcome | 26 | SMD | −0.08 (−0.16, 0.001) | 23 (24) | 57.0 | 0.020 | 12,801 | −0.58 to 0.69 | −0.11 (−0.20 to 0.04)
% Any illicit drug use | 11 | OR | 0.82 (0.67, 1.04) | 11 (12) | 38.2 | 0.041 | 9031 | 0.42 to 3.52 | 0.80 (0.64 to 0.95)
% Any illicit drug use | 11 | ARD | – | – | – | – | – | −11.5 to 14.8 | −2.8 (−5.0 to −0.2)
% Any cannabis use | 6 | OR | 0.78 (0.64, 0.95)^‡^ | 6 (7) | 1.3 | 0.000 | 6520 | 0.51 to 1.34 | 0.77 (0.71 to 0.86)
% Any cannabis use | 6 | ARD | – | – | – | – | – | −11.5 to 2.8 | −3.0 (−5.0 to −1.3)
Times used in previous 3m | 12 | MD | −0.21 (−0.44, 0.02) | 11 (11) | 51.0 | 0.037 | 3651 | ∆∆: −7.5 to 1.0; ∆: −1.1 to 1.5 | ∆∆: −0.3 (−1.6 to 0.0); ∆: 0.7 (−0.4 to 1.3)
Times used cannabis in previous 3m | 10 | MD | −0.23 (−0.48, 0.01) | 10 (10) | 58.1 | 0.045 | 3616 | ∆∆: −2.7 to 1.0; ∆: −1.1 to 1.6 | ∆∆: −0.3 (−0.9 to 0.0); ∆: 0.7 (−0.4 to 1.3)
Primary alcohol outcome | 24^†^ | SMD | −0.11 (−0.16, −0.07) | 22 (23) | 4.9 | 0.001 | 12,307 | −0.46 to 0.40 | −0.08 (−0.18 to 0.05)
% Any alcohol use | 6 | OR | 0.79 (0.64, 0.96)^‡^ | 5 (6) | 0 | 0.009 | 5854 | 0.56 to 1.40 | 0.98 (0.81 to 1.18)
% Any alcohol use | 6 | ARD | – | – | – | – | – | −10.4 to 10.2 | 1.0 (−5.0 to 4.0)
% Risky alcohol use | 5 | OR | 0.92 (0.72, 1.17)^‡^ | 5 (5) | 0 | 0.0 | 5078 | 0.77 to 1.45 | 0.94 (0.88 to 1.20)
% Risky alcohol use | 5 | ARD | – | – | – | – | – | −4.7 to 8.9 | 0.8 (−2.4 to 4.6)
Times used alcohol in previous 3m | 8 | MD | −0.29 (−0.53 to −0.05)^‡^ | 8 (8) | 20.7 | 0.014 | 3192 | ∆∆: −1.2 to 0.8; ∆: −1.9 to −0.5 | ∆∆: −0.2 (−0.4 to 0.2); ∆: −0.6 (−1.3 to −0.5)
Total drinks in previous 3m | 3 | MD | – | – | – | – | – | ∆∆: −3.8 to 2.8; ∆: NA (0 trials) | ∆∆: 1.4 (−2.2 to 2.5); ∆: NA (0 trials)
Primary tobacco outcome | 16^†^ | SMD | −0.09 (−0.15 to −0.03) | 15 (15) | 0 | 0.0 | 8366 | −0.41 to 0.29 | −0.06 (−0.14 to 0.04)
% Any tobacco use | 7 | OR | 0.91 (0.73 to 1.14)^‡^ | 6 (6) | 0 | 0.0 | 5373 | 0.63 to 1.69 | 1.08 (0.88 to 1.32)
% Any tobacco use | 7 | ARD | – | – | – | – | – | −8.6 to 8.5 | 0.8 (−2.1 to 5.8)
Times used tobacco in previous 3m | 8 | MD | −0.30 (−0.58 to −0.02)^‡^ | 8 (8) | 0 | 0.0 | 2893 | ∆∆: −5.5 to −0.2; ∆: 0.54 | ∆∆: −1.0 (−2.2 to −0.3); ∆: NA (1 trial)

* Range of effects for all study arms and timepoints, i.e., not limited to records in the meta-analysis.

† Number of trials reporting the specific substance use outcomes (any use, risky use, times used, total drinks) does not add up to the total number of trials reporting any outcome because some trials reported only a continuous scale score and are not shown in this table.

‡ Effect based on restricted maximum likelihood model. Remaining effects based on DerSimonian & Laird model.

Abbreviations: ∆ = difference between group at followup; ∆∆ = difference between groups in change from baseline; ARD = absolute risk difference; IQR = interquartile range; k = number of effects in the meta-analysis; MD = mean difference between groups; OR = odds ration; obs. = observations; SMD = standardized mean difference (Hedges g).

Figure 5 Primary Alcohol Use Outcome (KQ2) for General Prevention Trials, Standardized Mean Difference Between Intervention and Control Group, Sorted by Specific Outcome

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; NS = Not significant; SD = Standard deviation.

This figure is a forest plot of primary alcohol use outcome for general prevention trials, showing standardized mean difference between intervention and control group, sorted by specific outcome.

Figure 6 Primary Tobacco Use Outcome (KQ2) for General Prevention Trials, Standardized Mean Difference Between Intervention and Control Group, Sorted by Specific Outcome

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; NS = Not significant; SD = Standard deviation.

This figure is a forest plot of primary tobacco use outcome for general prevention trials, showing standardized mean difference between intervention and control group, sorted by specific outcome.

### Detailed Results

#### Illicit and Nonmedical Drug Use Outcomes

All included trials reported on illicit and nonmedical drug use. The pooled effect of illicit and nonmedical drug use for the general prevention trials did not show a statistically significant benefit (pooled SMD=−0.08 [95% CI, −0.16 to 0.001], k=24 [from 23 studies], n=12,801, I^2^=57.0%), Figure 4, Table 8, Appendix D Table 5). For this and all meta-analyses we included one observation per study (or per study site, if results were only reported separately for each site), preferentially selecting 6- to 12-month followup records if available (or closest, if not available), 1-month prevalence over lifetime use, and outcomes assessing the use of any illicit drug over the use of a single drug (e.g., cannabis). This effect size (Hedge’s g) can be interpreted as a Cohen’s D, where a small effect is typically considered to be 0.20 to 0.50.^123^ Five^81,^ ^92,^ ^93,^ ^98,^ ^108^ of the general prevention trials reported longer-term outcomes, ranging from 20 to 38 months post-baseline, and three of these found statistically significant group differences in the long term.^92,^ ^98,^ ^108^

The pooled OR for any illicit drug use or any cannabis use (preferentially selecting any illicit drug use, if available) was 0.82 (95% CI, 0.67 to 1.04, k=12 [11 studies], n=9031, I^2^=38.2%, Table 8), with ORs that ranged from 0.42 (95% CI 0.24, 0.72)^80^ to 3.52 (95% CI 1.23, 10.10)^95^ across all followup timepoints and intervention groups (even those not included in the meta-analysis). Recall periods (the time window during which participants’ illicit drug use was assessed) ranged from lifetime^102^ to 1 month,^81,^ ^82,^ ^103,^ ^106^ and, not surprisingly, there was a wide range of absolute rates of illicit drug use. At followup, the proportion reporting illicit or nonmedical drug use ranged from 2.3 to 38.6 percent in the control groups and 2.4 to 33.7 percent in the intervention groups, at followup ranging from 3 to 33 months. The median absolute risk difference between groups was −2.8 percent, favoring the intervention group (range, −11.5% to +14.8%). When examining times used in the previous 3 months, the pooled mean difference (MD) between groups was −0.21 times (95% CI, −0.44 to 0.02, k=11, n=3651, I^2^=51.0%, Table 8). Across all followups and intervention groups, between-group differences in change from baseline ranged from −7.5 times (95% CI −16.9 to 1.9)^90^ to +1.0 times (95% CI −1.0 to 3.0)^111^ over the previous 3 months (range of followup: 3 to 36 months). Results were very similar when limited to cannabis outcomes only, except that the pooled effect was statistically significant for the proportion reporting any cannabis use (OR=0.78, 95% CI, 0.64 to 0.95, k=7 [6 studies], n=6520, I^2^=1.3%, Table 8). Only four trials reported the impact of their interventions on misuse of prescription medications specifically, although the interventions were broadly targeted at substance use and other non-substance-related outcomes.^90,^ ^92,^ ^107,^ ^108^ All of these were computer-based interventions: Familias Unidas^90^ and 3 targeting young adolescent girls and their mothers.^92,^ ^108,^ ^110^ All reported greater reductions misuse of prescription medications with the intervention, ranging from 0.1 (95% CI NR)^90^ to 11.3 (95% CI −22.6 to −0.08)^92^ fewer times used over the previous 3 months, at up to 24 months’ followup.

We found no evidence of a small-studies effect (Figure 7, Egger’s test p=0.68) and no study or intervention characteristics that influenced effect size based on meta-regressions. Subgroup analyses for some of the potential effect modifiers are shown in Figure 8.

Figure 7 Funnel Plot Examining Small Studies Effect for Primary Drug Use Outcome (KQ2) for General Prevention Trials

Abbreviations: SMD = Standardized mean difference.

This figure is a funnel plot examining the small studies effect for the primary drug use outcome for general prevention trials.

Figure 8 Summary of Sensitivity Analyses of Primary Drug Outcome (KQ2) for General Prevention Trials: Results of Meta-Analyses for Subgroups of Studies With the Indicated Characteristics

Abbreviations: CI = Confidence interval; DL = DerSimonian and Laird; REML = Restricted maximum likelihood; USA = United States of America.

This figure is a forest plot that shows the results of meta-analyses for subgroups of studies with the indicated characteristics, which is a summary of sensitivity analyses of primary drug outcome for general prevention trials.

Some general prevention interventions did show a consistent benefit across multiple time points or multiple outcomes,^90,^ ^92,^ ^98,^ ^106-108,^ ^110^ or at least had some positive findings on primary drug use outcomes.^80,^ ^96,^ ^114,^ ^115^ Two trials reported increased illicit drug use for at least one drug use outcome in youth participating in the interventions,^95,^ ^97^ and the remaining showed no clear evidence of benefit or harm. Among those showing the strongest evidence of benefit, five were computer-based interventions, of which four targeted middle-school aged girls (with 3 including both mothers and daughters in the intervention.^92,^ ^107,^ ^108^ Effect sizes were generally very small in these trials targeting middle-school aged girls, typically differences between groups of less than one time used over the prior 3 months, among girls with very low use levels at baseline. Interestingly, a replication^111^ of the successful computer-based trial among young adolescent girls that did not involve mothers^110^ did not find reduced illicit drug use in their trial at either 3 or 15 months’ followup.

The other effective computer-based program was the online version of Familias Unidas.^90^ This trial found larger effects than the other computer-based trials, for example at 12 months’ followup it found that participants had used cannabis an average of 2.7 fewer times (95% CI −3.7 to 0.5, p<0.01 in study-reported repeated measures analyses) over the previous 3 months, had misused prescription medications 0.2 fewer times (95% CI −1.8 to 1.6, study-reported p<0.01), and used inhalants 1.4 fewer times (95% CI −3.5 to 0.77, study-reported p<0.001). Dichotomous outcomes representing the proportion with any illicit or nonmedical drug use and prescription drug misuse were both statistically nonsignificant, but with fairly large point estimates favoring the intervention groups (any illicit drug use: 7.3% [6/82] in the intervention group vs. 14.3% [14/98] in the control group, OR=0.47 [95% CI 0.09 to 2.46]; prescription drug use: 2.4% [2/82] in the intervention group vs. 5.1% 5/98] in the control group, OR=0.47 [95% CI 0.09 to 2.46] at 12-month followup).

The remaining two general prevention trials showing a beneficial effect at multiple followups or for multiple outcomes were the primary care clinician training and QI intervention^106^ and the 46-session program for foster youth and their foster parents.^98^ In the clinician training intervention, 10.1 percent [38/377] of intervention group participants and 15.7 percent [82/524] of control group participants reported any illicit or nonmedical drug use in the previous month (OR=0.61, 95% CI 0.38 to 0.97) at 12 months’ followup, and a slightly larger effect at 3 months (OR=0.55, 95% CI 0.33 to 0.90).^106^ The trial among foster families reported a mean 1.04-point lower score (95% CI −1.74 to 0.34) on a 9-point cannabis use scale and 0.19-point lower score (95% CI −0.33 to −0.04) on a 9-point composite substance use score in the intervention than control participants at 36 months’ followup.^98^

Among the Family Spirit trials, only the largest, best-quality trial found reductions in illicit drug use, and only at the final followup timepoint (Table 9). At 38 months’ followup, 10.7 percent of intervention participants reported any cannabis use in the previous month, compared with 15.6 percent of the control group participants (OR=0.65 [95% CI 0.48 to 0.89], p=0.007). Findings were similar for any illicit drug use (12.3% in the intervention group vs. 17.3% in the control group, OR=0.67 [95% CI 0.50 to 0.91], p=0.01).

Table 9 Drug Use Outcomes for Family Spirit Trials to Prevent Illicit Drug Use Among Pregnant American Indian Adolescents and Young Adults (3 Trials)

Outcome | Study | Planned followup, months | n/N (%) or Mean (SD), IG | n/N (%) or Mean (SD), CG | Study-reported p-value | OR or Group Diff. (95% CI)
Any cannabis use | Barlow, 2013^83^ | 4 | 33/159 (20.6) | 34/163 (21.0) | 0.68 | 0.87 (0.44 to 1.70)
Any cannabis use | Barlow, 2013^83^ | 8 | 20/159 (12.4) | 31/163 (18.8) | 0.10 | 0.57 (0.29 to 1.11)
Any cannabis use | Barlow, 2013^83^ | 14 | 30/159 (18.9) | 32/163 (19.6) | 0.57 | 0.83 (0.44 to 1.58)
Any cannabis use | Barlow, 2013^83^ | 38 | 17/159 (10.7) | 25/163 (15.6) | 0.007 | 0.65 (0.48 to 0.89)
Any illicit drug use | Barlow, 2013^83^ | 4 | 36/159 (22.9) | 36/163 (21.9) | 0.84 | 1.03 (0.61 to 1.74)
Any illicit drug use | Barlow, 2013^83^ | 8 | 22/159 (13.8) | 33/163 (20.2) | 0.09 | 0.58 (0.31 to 1.10)
Any illicit drug use | Barlow, 2013^83^ | 14 | 34/159 (21.3) | 36/163 (21.9) | 0.55 | 0.83 (0.44 to 1.55)
Any illicit drug use | Barlow, 2013^83^ | 38 | 20/159 (12.3) | 28/163 (17.3) | 0.01 | 0.67 (0.50 to 0.91)
Any illicit drug use | Walkup, 2009^113^ | 5 | 7/54 (13.0) | 5/71 (7.0) | NR, NS | 2.02 (0.51 to 7.92)
Any illicit drug use | Walkup, 2009^113^ | 9 | 3/47 (7.0) | 2/68 (3.0) | NR, NS | 2.57 (0.37 to 18.00)
Severity score related illicit drug use (Range 0-17, lower indicates better outcome) | Barlow, 2013^83^ | 4 | - 0.1 (NR), 159 | 0 (NR), 163 | 0.78 | −0.1 (−0.4 to 0.3)
Severity score related illicit drug use (Range 0-17, lower indicates better outcome) | Barlow, 2013^83^ | 8 | −0.3 (NR), 159 | −0.1 (NR), 163 | 0.34 | −0.2 (−0.5 to 0.2)
Severity score related illicit drug use (Range 0-17, lower indicates better outcome) | Barlow, 2013^83^ | 38 | −0.5 (NR), 159 | −0.2 (NR), 163 | 0.19 | −0.3 (−0.8 to 0.2)
Use score for any illicit drug use (Range 8-32, directionality NR) | Barlow, 2006^85^ | 5 | 23.9 (8), 19^*^ | 22.5 (7), 22^*^ | 0.67 | 1.1 (−3.9 to 6.0)
Use score for any illicit drug use (Range 8-32, directionality NR) | Barlow, 2006^85^ | 9 | 25.1 (6), 19^*^ | 22.4 (8), 22^*^ | 0.27 | 2.6 (−2.2 to 7.4)

* Post-test score, rather than change from baseline.

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; NS = Not significant; OR = Odds ratio; SD = Standard deviation.

#### Other Substance Use Outcomes

Alcohol and tobacco use outcomes were commonly reported in the general prevention trials, which was not surprising since most also aimed to reduce alcohol and tobacco use in addition to illicit and nonmedical drug use. Pooled effects for alcohol and tobacco use both showed statistically significant but very small benefits (alcohol pooled SMD=−0.11 [95% CI, −0.16 to −0.07], k=23 [from 22 studies], n=12,307, I^2^=4.9%; tobacco pooled SMD=−0.09 [95% CI, −0.15 to −0.03], k=15, n=8366, I^2^=35.0%, Table 8, Figures 5 and 6). However, we did not consider these findings to be robust, because newly published findings could easily lead to a loss of statistical significance for these pooled effects, given how close the upper confidence intervals are to the null. The four computer-based trials targeting young adolescent females that showed reduced illicit and nonmedical drug use also found statistically significant reductions in alcohol use, but not tobacco use.^92,^ ^107,^ ^108,^ ^110^ In the trials that involved mothers, mean change in the number of times the girls used alcohol over the previous 3 months ranged from 0.0 (SD 0.6) to +0.3 (SD 0.9) in the intervention groups and +0.2 (SD 1.3) to +0.8 (SD 3.9) in the control groups at 12 months’ followup.^92,^ ^107,^ ^108^ The Familias Unidas trial,^90^ the trial among foster girls and their caregivers,^98^ and the clinician training trial^106^ found no group differences in use of alcohol at followup, although the Familias Unidas and foster family trials did report reductions in tobacco use,^90,^ ^98^ as did another trial of a computer-based intervention in young adolescent females.^111^

Two of the Family Spirit trials report on alcohol use^83,^ ^113^ and one reported tobacco use,^113^ with no group differences at any followup (Table 10).

Table 10 Alcohol and Tobacco Use Outcomes for Family Spirit Trials to Prevent Illicit Drug Use Among Pregnant American Indian Adolescents and Young Adults (3 Trials)

Outcome | Study | Planned followup, months | n/N (%) or Mean (SD), IG | n/N (%) or Mean (SD), CG | Study-reported p-value | OR or Group Diff. (95% CI)
Any alcohol use | Barlow, 2013^83^ | 4 | 28/159 (17.9) | 29/163 (17.8) | 0.60 | 0.8 (0.35 to 1.83)
Any alcohol use | Barlow, 2013^83^ | 8 | 27/159 (16.9) | 33/163 (20.0) | 0.33 | 0.71 (0.36 to 1.4)
Any alcohol use | Barlow, 2013^83^ | 14 | 41/159 (25.8) | 35/163 (21.6) | 0.67 | 1.14 (0.63 to 2.05)
Any alcohol use | Barlow, 2013^83^ | 38 | 26/159 (16.5) | 26/163 (15.7) | 0.68 | 1.06 (0.8 to 1.41)
Any alcohol use | Walkup, 2009^113^ | 5 | 6/54 (11.0) | 5/71 (7.0) | NR, NS | 1.52 (0.42 to 5.46)
Any alcohol use | Walkup, 2009^113^ | 9 | 5/47 (12.0) | 4/68 (6.0) | NR, NS | 2.19 (0.55 to 8.78)
Any tobacco use | Walkup, 2009^113^ | 5 | 7/54 (13.0) | 12/71 (17.0) | NR, NS | 0.74 (0.24 to 2.3)
Any tobacco use | Walkup, 2009^113^ | 9 | 9/47 (22.0) | 8/68 (13.0) | NR, NS | 2.06 (0.64 to 6.62)

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; NS = Not significant; OR = Odds ratio; SD = Standard deviation.

#### Other Behavioral Outcomes

Few other behavioral outcomes were reported. Five general prevention trials reported on delinquent behavior^88,^ ^93,^ ^95,^ ^98,^ ^115^ (Appendix D Table 6). In a primary care-based trial among youth with no use of cannabis in the previous year, those randomized to receive a computer-guided, in-person motivational intervention from a research interventionist reported lower scores than control participants on a composite measure of 10 different delinquent behaviors (raw proportions or scores not provided).^115^ However group differences were present only at 3 months’ followup, and disappeared at the 6- and 12-month assessments. The other four trials found no differences in self-reported delinquent behavior.

Three studies reported condom use, with no statistically significant group differences,^82,^ ^90,^ ^106^ although one of these (the clinician training intervention) reported lower risk of unplanned pregnancy in the prior 3 months in the intervention group (7.0% [26/377]) than the control group (10.2% [53/524]).^106^ The clinician training trial found no differences in the proportion reporting one or more road safety risks (71.4% [269/377] and 73.9% [387/524] in the intervention and control groups, respectively).^106^ One primary care-based trial examining a brief motivational intervention found lower self-reported frequency of driving under the influence of cannabis in the intervention condition that included an in-person counseling session, but not for the intervention condition that was entirely computer-based.^114^ In addition, another primary care-based trial reported reduced risk of riding with someone under the influence at 1 year followup among youth who had reported riding with someone under the influence at baseline (38% in the intervention group vs. 68% in the control group; aRR=0.58 [95% CI 0.37 to 0.91]), however this effect was smaller and not statistically significant at earlier followups or among youth who had not reported a history of risky riding at baseline.^72^

None of the Family Spirit trials reported other behavioral outcomes.

#### Differential Effects Across Population Subgroups

We examined all 29 included studies to determine whether effect sizes differed with respect to age, gender, race/ethnicity, risk level, rural vs. urban residence, and substance used. We found interaction or subgroup analyses for gender;^81,^ ^82,^ ^88,^ ^95,^ ^103,^ ^105^ race/ethnicity;^82,^ ^105^ and risk level, based on having a family history of drug problems,^100^ education level of the child^82^ or parents,^81^ family functioning,^81^ family income,^81^ nuclear vs. joint family type,^81^ family history of migration,^81^ baseline substance use,^72,^ ^83^ and high baseline psychosocial dysfunction, based on the Strengths and Difficulties Questionnaire.^95^ The impact of gender on treatment effect ran the full gamut, from favoring females,^82,^ ^88,^ ^105^ favoring males,^103^ no differential effect,^81,^ ^95^ to tending toward increased illicit drug use in boys (but tending toward benefit in girls).^82^ For race/ethnicity, one trial found a larger benefit among nonwhite than white participants for alcohol use,^105^ and another found a benefit for condom use only for youth of Dutch ethnicity, in contrast to nonDutch participants.^82^ Greater benefits were seen on illicit drug outcomes for youth with a family history of drug problems,^100^ and young women with a personal history of drug use (in one of the Family Spirit trials) improved their internalizing symptom score, in contrast to the full sample.^83^ In addition, one trial reported improvements on the Life Quality in Children and Adolescents composite score for those with high baseline Strengths and Difficulties Questionnaire scores.^81^ One primary care-based trial found a benefit for participants who had used alcohol or illicit drugs at baseline but not among those with no substance use at baseline.^72^ Most, but not all, of these trials explicitly examined interaction terms or stated that their subgroup analyses were preplanned.

## KQ3 What Are the Harms of Primary Care-Feasible or Referable Interventions to Prevent Drug Use in Children, Adolescents, and Adults?

Only one of the included trials (a Family Spirit trial) directly reported on harm.^83^ Adverse events identified by both assessment staff and home visitors were recorded and reviewed by the trial’s data safety and monitoring board. The authors stated that the proportion of adverse events and serious adverse events was similar between groups after accounting for increased contact time within the intervention group, but did not provide detailed data.^83^

In addition, as mentioned above, two general prevention trials reported increased illicit drug use in intervention groups over the control groups.^95,^ ^97^ In one of these was conducted in Sweden and included at-risk youth aged 12 to 18 years and tested two different interventions that involved either 6- or 10-session group interventions for parents.^95^ After 6 months, 17.1 and 25.9 percent of the intervention group youth reported any illicit drug use since baseline, compared with 11.1 percent of the control group youth. This study was rated as fair quality and had a number of methodological limitations, including an imbalance in the distribution of males and females bewteen groups (58% of the control group were female, compared with 38% and 46% of the two intervention groups), a lack of objective intervention fidelity ratings, and lifetime illicit drug use reported at baseline was higher in the control than the intervention group (contrary to the findings at followup), although none of these factors seemed likely to explain the harmful result. The other trial involved community recruitment of 14 to 17-year-olds from several US cities and provided participants with two 8-hour workshops covering diet, physical activity, and illicit drug prevention topics.^97^ Raw proportions of participants with illicit drug use at follow-up were not reported, but regression coeficients indicated that lifetime cannabis use has increased less in the control group than the intervention group. However, there were no group differences in 30-day cannabis use and the direction of effect was to the benefit of the intervention group. This was a large study (n=1654) with low attrition (10%) and generally good methods, however was rated as fair quality because they did not report whether allocation was concealed, did not show baseline characteristics by group (although the study did control for gender and baseline values of outcome variables in their analyses), and did not report intervention fidelity. Additionally, seven other trials reported statistically non-significant increases in illicit drug, alcohol, or tobacco use with SMD>0.20 or OR>2.0.^82,^ ^85,^ ^93,^ ^102,^ ^105,^ ^113,^ ^114^