# Chapter 2 Methods

## Scope and Purpose

This systematic review examined the evidence on benefits and harms of interventions to prevent illicit and nonmedical drug use in children, adolescents, and young adults. It will be used by the USPSTF to update its 2014 recommendation on this topic. Because of the paucity of evidence in the previous review, we expanded this update to include trials with shorter minimum followup time, additional settings, and included trials of young adults. On the other hand, the scope was narrowed from the previous review to no longer include trials among adolescents with regular or problematic drug use because interventions to reduce illicit and nonmedical drug use in these populations are addressed in another USPSTF review.^7^

## Key Questions and Analytic Framework

Using the USPSTF’s methods (detailed in Appendix A), we developed an analytic framework (Figure 1) and three Key Questions (KQs):

1. Do primary care–feasible or referable interventions to prevent drug use in children, adolescents, and young adults improve health outcomes or other related outcomes?
2. Do primary care–feasible or referable interventions to prevent drug use in children, adolescents, and young adults improve drug use outcomes?
3. What are the harms of primary care–feasible or referable interventions to prevent drug use in children, adolescents, and adults?

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts three Key Questions to be addressed in the systematic review. The figure illustrates how interventions to prevent drug use in children, adolescents, and young adults without regular illicit or nonmedical drug use may result in improved health and related outcomes including morbidity, mortality, social, educational, and legal outcomes (Key Question 1), and behavioral outcomes including drug abstinence, frequency or quantity of drug use, and other risky behaviors (Key Question 2). Additionally, the figure addresses whether interventions to reduce drug use among children, adolescents, and young adults without regular illicit or nonmedical drug use may result in any harms (Key Question 3).

## Data Sources and Searches

We developed a search strategy designed to capture relevant literature published from 6 months prior to the search date in the previous USPSTF review to identify newly published studies of behavioral counseling interventions to prevent illicit drug use in children, adolescents, and young adults, as well as previously published studies targeting young adults that were not included in the previous review’s searches (Appendix A). We searched MEDLINE, PubMed (for publisher-supplied records only), PsycINFO, and the Cochrane Central Register of Controlled Trials for relevant English-language literature published between January 1, 2013 (for children and adolescents), or January 1, 1992 (for young adults), and January 30, 2019. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian. Surveillance searches were continued through March 20, 2020 to identify newly published studies that may affect the findings of the review. This was accomplished through review of publications in high-impact-factor journals and article alerts. One relevant RCT was identified during the surveillance window and was included in this review.^72^

We evaluated all studies included in the previous review for inclusion in the current review. In addition, since the current review reduced the minimum followup required and expanded the list of allowable settings, we reviewed studies from the “excluded studies” appendix of the previous review that had been excluded due to the setting or insufficient followup. We also examined the reference lists of other reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials. We imported the literature from these sources directly into EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

Detailed inclusion and exclusion criteria were developed to guide study selection (Appendix A Table 1). This review comprised studies that targeted children, adolescents, and young adults (age ≤25 years), including pregnant females, who did not regularly use illicit drugs or medications for nonmedical psychoactive effects. This included interventions targeting parents or caregivers to prevent or reduce illicit drug use in young persons.

We included randomized controlled trials (including cluster randomized trials), and nonrandomized controlled trials assessing behavioral counseling interventions designed to prevent or reduce illicit and nonmedical drug use. Interventions to assist or support young people in avoiding the use of illicit drugs are considered, and may include educational and/or motivational messages and may be delivered through a variety of means, including in person, over the phone, via computer, through print materials. The interventions could target other risk behaviors in addition to illicit drug use (e.g., alcohol use, tobacco use, risky sexual behavior) but were required to have some intervention content that directly addressed illicit drug use. Consistent with other USPSTF reviews on substance-related topics, we also required that studies report a drug use outcome for inclusion in the review.^6^ A minimum of 3 months’ followup was required. Interventions were excluded that included components that could not be replicated in a health care setting, such as broad public health, media, or policy interventions.

We included trials conducted in health care settings or judged to be generalizable to primary care, including research settings, community settings, school health clinics, and virtual settings. Interventions in community or research settings were included if all components of the intervention were judged feasible for implementation in a healthcare setting, i.e., clinicians and/or related staff in the primary care setting should have [or could have] the skills necessary to deliver the intervention, or could refer to others in the health system with the necessary skills. We excluded trials in inpatient, residential, or other institutional settings and those conducted in substance abuse treatment centers. In addition, we excluded studies conducted in classroom and most other school settings based on the logic that effects of school-based interventions may not generalize to primary care because of the pre-existing relationships among participants and between participants and school staff, the limited capability for confidentiality in school settings, and the potential for disciplinary consequences when illicit drug use is revealed. However, we included studies if they used schools only for recruitment purposes, as long as they recruited from multiple schools and met at locations other than schools, or if they studied entirely online interventions that did not involve interactions among students at the same school or between students and teachers.

Comparative effectiveness studies were excluded, and allowable control groups included no intervention (e.g., usual care, wait list), a minimal intervention (e.g., pamphlets, links to pre-existing internet resources, or no more than a single brief contact per year), and attention controls (with similar format and intensity but a different content area). We limited inclusion to English language studies in countries rated as “Very High” human development according to the United Nations, based on 2015 indicators.^73^

Two reviewers independently reviewed titles and abstracts for potential inclusion, then two reviewers reviewed the full-text articles. Discrepancies were resolved via discussion and consultation with the larger review team as needed. Title, abstract, and full-text review were conducted in DistillerSR (Evidence Partners, Ottawa, Canada).

## Quality Assessment and Data Abstraction

Two reviewers applied USPSTF design-specific criteria (Appendix A Table 2)^74^ to assess the methodological quality of all eligible studies. We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were reviewed and discussed, with consultation from the full review team as needed. Studies rated as poor quality were excluded from the review. Good-quality studies were those that met all or nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study, and followup was 90% or higher), whereas fair-quality studies did not meet all of these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study. Intervention studies rated as poor quality generally had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%), differential attrition between intervention arms (generally >20%); substantial lack of baseline comparability between groups without adjustment; or issues in trial conduct, analysis, or reporting of results that put the validity of the findings in doubt (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, questionable validity of randomization and allocation concealment procedures).

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR. A second reviewer checked the data for accuracy. For each study, we abstracted its general characteristics (e.g., author, year, study design, recruitment methods), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), and results. Outcomes of interest included health outcomes (e.g., drug-related morbidity, injuries or accidents, quality of life, consequences of illicit drug use, mortality, pain); social, educational, and related outcomes (e.g., global functioning, educational attainment and school performance, incarceration and criminal activity); behavioral outcomes (illicit drug use, other substance use, other risky behaviors); and harms (e.g., treatment-related harms, demoralization due to failed quit attempt, harms of parents discovering child’s illicit drug use, discontinuation of effective treatment due to fears of addiction).

## Data Synthesis and Analysis

We created summary tables for all KQs showing study, population, intervention characteristics, and outcomes for qualitative evidence synthesis. Three trials provided very intensive pre- and post-natal home visits to pregnant American Indian youth. Because these trials (the Family Spirit trials) were substantially different from the other included trials, both due to the population of interest and the nature of the intervention, results will be discussed separately for Family Spirit trials and the remaining trials, which we will refer to as the “general prevention” trials. However, summary tables encompass all included studies unless specified otherwise.

We assigned prevention type according to the SAMHSA definitions^75^ for universal direct prevention (interventions that target the general public and/or the whole population that has not been identified on the basis of individual risk, referred to as “universal” [since indirect universal interventions were out of scope for this review]) or selective prevention (interventions that target individuals or a specific population whose risk of developing mental or substance abuse disorders is significantly higher than average). Indicated prevention programs (i.e., those that target individuals at high risk who have minimal but detectable signs or symptoms of mental illness or substance abuse problems) were out of scope for this review but were included in a separate review of covering screening and treatment for unhealthy substance use.^7^

Since an illicit drug use outcome was required for inclusion in the review, we selected this as our primary outcome for meta-analysis. Trials were almost evenly divided between reporting a continuous measure, most commonly the number of times illicit drugs were used over a specified period, and the dichotomous outcomes of any illicit drug use or any cannabis use. Continuous measures were converted to Hedges g, which is a standardized mean difference (SMD), based on either change from baseline or mean post-test scores, after converting all “times used” variables to the same time window of the previous 3 months. For dichotomous outcomes, log-ORs were converted to Cohen’s d and then converted to Hedges g using standard formulae.^76^ Odds ratios were either extracted from the studies directly or calculated based on the study-reported numbers of persons with and without the event for each group.

We conducted pooled analyses of the general prevention trials (i.e., all trials except the Family Spirit intervention trials). We ran random effects meta-analyses on SMDs for three categories of substances: illicit and nonmedical drug use (preferentially choosing outcomes covering any illicit or nonmedical use of drugs over cannabis-specific measures if they were both provided), alcohol use (preferentially selecting any use over risky or unhealthy use), and tobacco. Across all of these categories, dichotomous outcomes were preferentially included if both continuous and dichotomous outcomes were reported, due to the ease of interpretation. Where multiple intervention groups or followup timepoints were provided, we selected the intervention group with the most intensive or comprehensive drug prevention component, reported at 6 to 12 months if available or the closest to that time frame. In addition, we conducted separate analyses pooling ORs and between-group mean differences to better understand effects in the native units. We also provided analyses of cannabis-specific results in native units.

We used the DerSimonian and Laird (DL) model for pooling. In addition, because the DL method is prone to insufficient coverage of the full 95 percent confidence intervals when the number of studies is small or statistical heterogeneity is high (and I^2^ were typically near or above 50% in this review), we also ran restricted maximum likelihood (REML) models with the Knapp-Hartung correction for small samples when pooling fewer than 10 trials. We generated a funnel plot and ran Egger’s test to explore small-study effects, which can be an related to publication bias.^77^ Additionally, we conducted meta-regression and subgroup analyses to explore factors that were associated with effect size for the primary drug use outcome, pooling SMDs. We examined the following as potential effect modifiers: study quality (good vs. fair), publication year, majority nonwhite sample (yes vs. no or race and ethnicity not reported), country (United States vs. other), setting (health care vs. other), type of prevention (universal vs. selective), intervention duration, planned number of intervention sessions, estimated hours of contact with the intervention, group (vs. individual) sessions, mode of intervention (computer only vs. others), whether the intervention focused only on illicit drug use (vs. targeting additional substances or other behaviors), whether then intervention focused only on substance use (vs. also targeting other behaviors), specific additional intervention targets (separate regressions for presence of family functioning, risky sexual behavior, mental health, and other social or legal outcomes as intervention targets), age group (middle school age only [approximately 10 to 14] vs. others), and type of control group (usual care, waitlist, or no intervention vs. attention control or minimal intervention). We used Stata version 15.1 (StataCorp LP, College Station, TX) for all analyses. All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each key question. We adapted the Evidence-based Practice Center approach,^78^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^79^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the key questions (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall key question (e.g., evidence of reporting bias, lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, low, or insufficient. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit an estimate of an effect. At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion with the full review team, consulting with outside reviewers as needed.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from May 10 to June 7, 2018. Comments from five individuals, organizations, and groups of organizations were received and resulted in updates to the proposed scope of the review that included clarification and improved consistency of wording and the addition of some pertinent outcomes. The draft version of this report was reviewed by experts and USPSTF Federal Partners and posted for public comment on the USPSTF Web site from October 1 to October 28, 2019.

## USPSTF Involvement

We worked with USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. The Agency for Healthcare Research and Quality (AHRQ) funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.