# Chapter 1 Introduction

## Condition Background

### Condition Definition

This review focuses on illicit and nonmedical drug use in young people.^1,^ ^2^ Illicit drugs are those that are illegal, including cannabis under federal law (even though recreational use is legal in some states), and prescription medications that are not taken as directed by the person for whom they were prescribed. Nonmedical use refers to use of a prescription and over-the-counter drugs in ways other than instructed.^3^ For brevity, we will use the term “illicit” to encompass illicit and nonmedical use. This review does not cover interventions addressing the prevention of alcohol or tobacco use (unless they are part of an intervention that also addresses drug use); tobacco use prevention is covered by a separate USPSTF review,^4,^ ^5^ as is counseling to reduce alcohol use among youth with a history of alcohol use.^6^

Illicit Drug use occurs along a continuum that ranges from abstinence to a severe use disorder (Table 1), and youth generally move progressively to higher levels of use, however they may also move backward from problematic use and above to lower use levels. In this report, we include interventions related to preventing illicit drug use among children, adolescents, and young adults in the abstinence, sporadic, and limited use stages. General preventive counseling may be offered broadly to all young people without knowing their history or illicit drug use, or may be delivered after establishing that they do not already regularly use illicit drugs. In this review, we do not address the complementary literature on counseling to reduce of illicit drug use among young persons with problematic use or a substance use disorder; this literature is examined in another USPSTF review on screening for illicit drug use and interventions to be delivered to those who screen positive for problematic use.^7^ For the current review, we considered regular use (on at least a weekly basis) to be problematic use.

Table 1 Stages of Illicit and Nonmedical Drug Use Among Children and Adolescents

Stage | Description
Abstinence | The time before an individual has ever used drugs
Sporadic use | The first 1-2 times that a substance is used and the adolescent wants to know how intoxication from using a certain drug(s) feels (sometimes also refers to extremely infrequent or non-persistent use)
Limited use | Use together with ≥ 1 friends in relatively low risk situations and without related problems; typically, use occurs at predictable time such as on weekends
Problematic/harmful use | Use in a high-risk situation, such as when driving or babysitting; use associated with a problem such as a fight, arrest, or school suspension; or use for emotional regulation such as to relieve stress or depression
Substance use disorder (mild, moderate, or severe) | Drug use associated with recurrent problems or that interferes with functioning. Previously, the Diagnostic and Statistical Manual of Mental Disorders (DSM) system distinguished substance abuse from substance dependence (which includes loss of control or compulsive use)

Adapted from: Levy SJ, Kokotailo PK. Substance use screening, brief intervention, and referral to treatment for pediatricians. Pediatrics 2011 Nov;128(5):e1330-e1340^153^ and Levy SJL, Williams JF, Committee on Substance Use and Prevention. Substance Use Screening, Brief Intervention, and Referral to Treatment [Clinical Report]. Pediatrics. 2016.^67^

### Prevalence of Illicit and Nonmedical Drug Use

The 2018 Monitoring the Future report on adolescent drug use indicates that 47.8 percent of 12^th^ graders in the United States have ever used an illicit drug (cannabis/hashish, cocaine [including crack], heroin, hallucinogens, inhalants, or prescription-type psychotherapeutics used nonmedically), with cannabis being the most frequently used drug (lifetime prevalence was 13.9%, 32.6%, and 43.6% among 8^th^, 10^th^, and 12^th^ graders, respectively).^8^ The National Survey on Drug Use and Health (NSDUH), administered by the Substance Abuse and Mental Health Services Administration (SAMHSA), reports previous-month illicit drug use among 7.9 percent of adolescents ages 12 to 17 years in 2016, or approximately 2.0 million adolescents (Table 2).^9^ Among adolescents ages 12 to 17 years, previous-month use of cannabis was 6.5 percent, while an estimated 1.6 percent used prescription psychotherapeutic drugs nonmedically, including pain relievers (1.0%), tranquilizers (0.5%), stimulants (0.4%), and sedatives (0.1%). Other illicit drugs were used by a smaller percentage: cocaine (0.1%), hallucinogens (0.5%), and inhalants (0.6%). To put the rates of illicit drug use in context with the use of other substances, in 2016 the rate of any previous-month alcohol use was 9.2 percent and tobacco use was 3.4 percent in persons ages 12 to 17 years.^9^

Table 2 Current (Previous Month) Percentage of Illicit Drug Use, 2016 National Survey on Drug Use in Health^15^

Illicit drug | All adolescents (12-17 years) | Male adolescents (12-17 years) | Female adolescents (12-17 years) | 12-13 years | 14-15 years | 16-17 years | 18-25 years
Any illicit drug | 7.9 | 7.9 | 7.8 | 2.0 | 6.7 | 14.5 | 23.2
Cannabis | 6.5 | 6.8 | 6.1 | 0.8 | 5.3 | 12.9 | 20.8
Non-medical use of any prescription psychotherapeutic (pain relievers, specifically) | 1.6 (1.0) | 1.2 (0.6) | 2.0 (1.3) | 0.7 (0.6) | 1.5 (0.9) | 2.4 (1.3) | 4.6 (1.8)
Cocaine | 0.1 | 0.1 | 0.1 | * | 0.1 | 0.2 | 1.6
Hallucinogens | 0.5 | 0.6 | 0.3 | 0.1 | 0.4 | 0.8 | 1.9
Inhalants | 0.6 | 0.4 | 0.8 | 0.7 | 0.5 | 0.6 | 0.4

* Estimate suppressed due to low precision.

Young adults ages 18 to 25 years have the highest rate of illicit and nonmedical drug use, with 23.2 percent (as compared with 7.9% of adolescents) using illicit drugs in the past month, according to the 2016 NSDUH results.^9^ Similar to adolescents, the drugs most commonly used were cannabis (20.8%) and prescription psychotherapeutic drugs (4.6%).^9^ For comparison, 23.5% of young adults used tobacco in the past month and 57.1% had used alcohol.

While there has been a long-term declining trend in the use of illicit drugs in adolescents in the US since the late-1990s, the use of cannabis has increased in each of the past 2 years for both 8^th^ and 10^th^ graders; from 2016 to 2018 annual prevalence increased from 9.4% to 10.5% in 8^th^ graders and 23.9% to 27.5% in 10^th^ graders, while holding relatively steady in 12^th^ graders (35.6% in 2016, 35.9% in 2018).^8^

Initiation of illicit drug use during college is relatively common. A 2012 survey found that 25 percent of cannabis users started using after starting college.^10^ Similarly, a survey during a 5-year period from 2004 to 2009 found 61.8 percent of college students had been offered prescription stimulants, mostly by friends with a prescription, and 31.0 percent had used prescriptions illicitly by their fourth year of college.^11^ In one 2015 study, the risk of cannabis initiation among high school graduates who had never used cannabis was found to be 51 percent higher among those who went on to college than among peers who did not go onto college.^12^

The prevalence of illicit drug use is not equally distributed across the U.S. population. Specific populations of adolescents that experience a higher prevalence of substance use include males of any race/ethnicity and nonwhite Hispanic adolescents.^13-15^ Illicit drug use, including nonmedical use of prescription drugs, is more common in sexual minority adolescents than their heterosexual peers.^16^ ^17^

### Burden of Illicit and Nonmedical Drug Use

Illicit drug use is associated with multiple negative health, social, and economic consequences. In 2015, drug overdose (both intentional and unintentional) accounted for 9.7 per 100,000 deaths in those ages 15 to 24 years.^18^ National tracking systems of fatal poisonings, which capture deaths due to drug use, report that the majority of poisoning deaths are due to illicit and legal drugs (9 of 10 poisoning deaths for all ages are caused by drugs).^19^ Between 1999 and 2016, drug overdose death rates among 15 to 24-year-olds increased from 3.2 (CI NR) to 12.4 (CI NR) per 100,000. Over the same time period, opioid-related deaths among 15 to 19-year-olds increased from 0.78 (95% CI 0.68 to 0.88) to 2.75 (95% CI 2.55 to 2.96) per 100,000,^20^ and the rate associated with synthetic opioids other than methadone continued to rise in 2017.^21^ Eight-five percent of these deaths were unintentional.^20^

Illicit drug use is associated with an increased risk of motor vehicle accidents,^22,^ ^23^ violence,^24,^ ^25^ and suicidal behavior^26,^ ^27^ in young people. In 2016, 73.6% percent of all deaths in young people ages 10 to 24 years in the United States resulted from three causes: unintentional injuries, including motor vehicle accidents (41.4%); suicide (17.3%); and homicide (14.9%).^28^

In 2011, the Drug Abuse Warning Network (DAWN) estimated that approximately 1.1 million emergency department (ED) visits by individuals ages 0 to 21 years involved illicit drugs.^29,^ ^30^ Cannabis, cocaine, ecstasy, and stimulants were the most commonly reported illicit drugs that led to an ED visit by children and adolescents.^29^ DAWN also estimated that in 2011 there were over 79,000 ED visits related to nonmedical use of prescription opioids of those ages 12 to 25 years.^31^ Visits to EDs of adolescents ages 12 to 20 years involving alcohol and illicit drugs were more likely to result in a serious outcome than visits involving alcohol alone (33% vs. 12%).^32^

Illicit drug use can also have deleterious effects on educational achievement and attainment. Cross-sectional and longitudinal studies show that students who dropped out of school or were at risk for dropping out of school had higher rates of cannabis use than students who remained in school or graduated.^33^ A long-term cohort study of black urban youth that matched participants who had used cannabis at least 20 times by age 16 with those who had not on a wide range of demographic, psychosocial, academic, and family characteristics found increased odds of becoming a high school dropout (OR=3.11, 95% CI 1.31 to 7.38) and reduced odds of obtaining a college degree (OR=0.32, 95% CI 0.14 to 0.76) among the heavier users.^34^ Analysis of the 1997 National Longitudinal Survey of Youth, representing those between the ages of 12 and 16 living in the United States, found that African Americans were 247% and Hispanics 60% more likely than Whites to be arrested for a drug distribution offense in the period of observation. African Americans’ greater likelihood of arrest was not explained by differences in youth’s rate of offending or the community context, but represents disparities in arrests and sentencing.^35^ Juvenile arrests have been shown to be related to poor rates of high school graduation and college enrollment.^36^ Studies that examined the relationship between other noncannabis drug use and dropping out of school report mixed results, with some showing that illicit drug use and dropping out of high school are related, while others indicate that the association varies by race/ethnicity and is confounded by other factors.^33^ A recent review including studies among nationally representative samples of high school students found a significant relationship between poorer academic performance (including dropping out of school), and nonmedical use of prescription drugs.^37^ In addition, problematic illicit drug use decreases the risk of both continuous college enrollment^38^ and college graduation.^39^

Some long-term negative psychosocial and neurocognitive effects have been associated specifically with adolescent cannabis use. For example, a prospective cohort study found an increased risk of anxiety in midlife (up to age 42) in those who had used cannabis 20 or more times by age 16 compared with those who had not (OR 2.12, 95% CI 1.00 to 4.48), even after controlling for anxiety, depression, suicidality, and a wide range of other factors during adolescence and for cannabis use in adulthood.^34^ In addition, a longitudinal study with annual substance use assessment and measures of emotional functioning at 3-year intervals starting at age 11 found that, among youth who had used cannabis 100 or more times, emotional resiliency and negative emotionality changed little between cannabis initiation (mean age 13) and long-term followup (mean age 23), but for matched controls who had used cannabis fewer than 10 times, emotional resiliency increased and negative emotionality decreased over time.^40^ In other words, emotional development was hindered in those who had used cannabis 100 or more times. Finally, evidence is also mounting that heavy cannabis use increases the risk of psychosis.^41-43^

Similarly, meta-analyses of nonacute neurocognitive effects show associations between cannabis consumption and lower performance on abstract thinking, attention, learning, and psychomotor functioning.^44,^ ^45^ These effects may be reversible in adults; however, other studies show that impairments in psychomotor velocity, attention, memory, and planning are more likely to linger after 4 weeks’ abstinence in those who began using cannabis in adolescents.^46^ A long-term prospective birth cohort found that persistent cannabis use was associated with neuropsychological decline across multiple domains (even after controlling for years of education), impairment was more severe and more persistent among adolescent-onset users, and functioning was less likely to be restored up to one year after cessation in adolescent-onset users.^47^

### Perception of Risk Among Youth

Despite growing evidence of the potential harms of heavy cannabis use, there has been a steep decline in recent years in the proportion of 12th graders who see “great risk” in regularly using cannabis, dropping from 77.8 percent in 1990 to 31.1 percent in 2016.^48^ Interestingly, ratings of other substances as having “great risk” have held steady or increased among young people, including heroin use (76.6% in 1990, 78.7% in 2016 for occasional use), alcohol (47.1% in 1990, 48.4% in 2016 for weekly binge use), and smoking (68.2% in 1990, 76.5% in 2016 for smoking 1 pack per day or more).^48^ Evidence of the effect of legalization of recreational marijuana is mixed. Data from the Monitoring the Future survey found steep declines in ratings of harmfulness after legalization of recreational use in Washington state, but not Colorado; in Washington, the prevalence of perceived harmfulness of marijuana use declined among 8th and 10th graders from 74.9 to 60.7 percent, and from 62.8 to 46.6 percent, respectively.^49^

### Risk and Protective Factors

Research has identified multiple risk and protective factors that influence adolescent substance use. Risk factors include: substance use by immediate family members,^50^ poor parental supervision^51^ and household disruption, low academic performance or aspirations, decreased participation in school activities, poor relationships with teachers,^52^ untreated attention-deficit disorder and attention-deficit/hyperactivity disorder, perceived peer acceptance of substance use and actual use among peers,^51^ experience of violence or trauma including childhood sexual abuse,^53^ victimization of lesbian, gay, or bisexual identities,^54^ delinquent behavior,^37^ gambling,^55^ poor mental health, ^54,^ ^56^ use of alcohol or tobacco,^37^ sensation seeking, ^37^ low school connectedness,^57^ and poor parental monitoring.^37^ Protective factors include: parents who set clear rules and enforce them, parents who regularly talk with their children about the dangers of substance use,^51^ having a parent in recovery, having a positive school climate^51,^ ^52^ and a positive sense of community, involvement in religious or other community programs, and having adequate opportunities in the community for prosocial involvement.^51,^ ^52,^ ^58,^ ^59^

Evidence to date is mixed on the effect of legalization of recreational cannabis on the risk of cannabis use in adolescents. Based on the Monitoring the Future survey, use increased in Washington 2.0 percentage points among eighth graders and 4.1 percentage points among 10th graders following legalization, however prevalence did not increase in Colorado, and did not increase in 12^th^ graders in either state.^49^ However, a survey that recruited U.S. teenagers ages 14 to 18 years via social media found that lifetime prevalence of vaping and/or edible use was approximately 15 percent greater among those in states with any legal cannabis status (medical and/or recreational). Adolescents started using edibles approximately 5 months earlier in states where legalization had been in place for 10 years or longer compared with those in states with less than 5 years or no legalization.^60^

### Behavioral Interventions to Prevent Illicit and Nonmedical Drug Use

A wide range of approaches have been explored to prevent initiation of illicit drug use, including a number of family-based interventions that could potentially be feasible for implementation in healthcare settings (e.g., in primary care, or offered broadly by a health system).^61^ Most of these programs target substance use broadly, including alcohol and often tobacco use as well as illicit drug use. The programs may target the parent only, the youth only, or both, and commonly address many of the following topics: substance use knowledge, attitudes, and values; parental monitoring and behavior management; fostering school success; positive family relationships; self-regulation and stress management; problem-solving; resisting peer pressure; promoting a future orientation; supporting positive ethnic identity.^61^ These programs may be delivered individually or in groups, in-person or via computer or DVD. Most of these interventions have been tested in the context of schools, with recruitment from schools and the interventions typically taking place after school, on school grounds. In addition, some computer-based interventions have been developed, covering similar content areas, which have been designed for implementation in school, home, and health care settings.^62^

### Current Clinical Practice in the United States and Recent Recommendations

We found no information on the use of behavioral counseling in primary care to prevent initiation of illicit drug use among young people who have not used drugs, or escalation of use among those who do not use them regularly. Preventing and reducing illicit drug use among adolescents is explicitly prioritized as an objective of Healthy People 2020. These objectives include increasing the proportion of high school seniors who have never used illicit drugs, decreasing the proportion of young people who use cannabis for the first time, and decreasing the proportion of adolescents who report using cannabis and nonmedical use of prescription drugs or inhalants.^63^ Looking more broadly than prevention of use among those who do not use, SAMHSA recommends that universal screening for substance use, brief intervention, and/or referral to treatment (SBIRT) become a part of routine health care to reduce the health burden related to substance use and substance use disorders.^64^ SBIRT is an early intervention approach that targets individuals with nondependent substance use and provides strategies for intervention before the need for more extensive or specialized treatment. In child and adolescent populations, the term “brief intervention” includes a wide spectrum of clinical actions intended to prevent, delay, or reduce substance use among individuals with a variety of experience with substances. According to SAMHSA, a brief intervention usually involves one to five sessions of 5 minutes to 1 hour in duration.^65^ These interventions can be delivered via face-to-face sessions, written self-help materials, a computer intervention, or telephone counseling.

The American Academy of Pediatrics (AAP) has developed guidelines through Bright Futures for counseling about illicit substance use.^66^ The AAP specifically recommends that pediatricians provide substance abuse education to adolescents during routine clinical care, incorporating the SBIRT guidelines designed by SAMHSA.^66,^ ^67^ For patient reporting no substance use, the AAP recommends providing “positive reinforcement for making this smart decision”, and further suggest the use of normative correction statements such as “I am glad to hear that you, just like most others your age, have never used illicit drugs.” For patients who use substances, it advises that brief counseling and in-office followup may be sufficient if substances are not used regularly and there have been no adverse consequences of substance use. More intensive intervention and referral for treatment are indicated when children or adolescents are identified as having experienced adverse events related to their substance use (e.g., injuries associated with acute intoxication, trouble with the law, decline in school performance), are regularly using illicit drugs, or are using illicit drugs to “feel normal.”^67^

Additionally, the National Institute for Health and Care Excellence in the United Kingdom recommends that clinicians consider providing preventive skills training to young people who are assessed as vulnerable to illicit and nonmedical drug use as well as to their parents or caregivers. See Table 3 for a brief description of these and other relevant guidelines.

Table 3 Other Relevant Guidelines on Assessment and Prevention of Illicit and Nonmedical Substance Use in Children and Adolescents

Organization; Title (year) | Recommendation(s)
American Academy of Pediatrics; Substance Use Screening, Brief Intervention, and Referral to Treatment (2016) ^66^ | Pediatricians should increase their capacity in substance use detection, assessment, and intervention; and become familiar with adolescent SBIRT practices and their potential to be incorporated into universal screening and comprehensive care of adolescents in the medical home.
Canadian Pediatric Society; Cannabis and Canada’s children and youth (2017) ^154^ | Screen all children and youth for cannabis exposure; be aware of and communicate the health risks related to cannabis use; and provide anticipatory guidance to parents and older children on the potential health risks of cannabis use.
Canadian Pediatric Society; Harm reduction: An approach to reducing risky health behaviours in adolescents (2008, reaffirmed 2016) ^155^ | Screen all preadolescent and adolescent patients for potentially risky behaviors at regular health care visits; provide messages that encourage delay in initiation of potentially risky behaviors, and at the same time, promote risk-reduction strategies if adolescents choose to engage in the behavior; use principles of motivational interviewing in the assessment and discussion of risky health behaviors with adolescent patients; and become familiar with the resources in their communities that provide harm reduction programs for substance abuse, pregnancy prevention, and injury prevention.
National Institute for Health and Care Excellence; Drug misuse prevention: targeted interventions (2017) ^156^ | Deliver drug misuse prevention activities to people at risk through a range of existing statutory, voluntary, or private services (e.g., primary care services, mental health services, dental services); at routine appointments and opportunistic contacts with statutory and other services, assess whether someone is vulnerable to drug misuse; and consider skills training for children and young people who are assessed as vulnerable to drug misuse. If skills training is delivered to children and young people, ensure that their carers or families also receive skills training. Offer older adolescents/young adults who are assessed as vulnerable to drug misuse clear information on drugs and their effects, advice and feedback on any existing drug use, and information on local services and where to find further advice and support; and offer information and advice both verbally and in writing.
United Nations Office on Drugs and Crime/World Health Organization; International Standards on Drug Use Prevention - Second updated edition | Recommended services potentially relevant to health care settings include:; Infancy/early childhood: prenatal and infancy visitation programs to provide support in accessing needed resources and in parenting skills.; Middle childhood: parenting skills programs emphasizing warm child-reading style, clear rules, monitoring, role modeling; supporting children, adolescents and parents in addressing emotional and behavioral disorders as early as possible.; Early adolescence: Skills-based prevention programs to encourage social competence, including substance and peer refusal skills; addressing individual psychological vulnerabilities as needed, such as coping with sensation-seeking, impulsivity, anxiety sensitivity and hopelessness.; Adolescence: Brief interventions for those using substances but have not experienced important consequences and are unlikely to seek treatment

Abbreviations: SBIRT = Screening, Brief Intervention, and Referral to Treatment.

### Previous USPSTF Recommendation

In 2014, the USPSTF concluded that current evidence was insufficient to assess the balance of benefits and harms of primary care-based behavioral interventions to prevent or reduce illicit drug or nonmedical pharmaceutical use in children and adolescents (I statement). Evidence was judged as insufficient due to inadequate evidence of the benefits of these interventions on health outcomes and illicit drug initiation or use, with only 6 included studies, several covering narrow populations. The recommendation applies to children and adolescents younger than age 18 years who have not been diagnosed with a substance use disorder.^68^ There are additional USPSTF recommendations on substance-related services for young people: I statements for screening and brief behavioral counseling interventions to reduce both illicit drug use^69^ and unhealthy alcohol use^70^, and a B recommendation for education or brief counseling to prevent initiation of tobacco use among school-aged children and adolescents.^71^