# Appendix F Ongoing Studies

Trial identifier | Study name | Location | Estimated N and Age range | Interventions | Outcome Measures | Status
NCT02290938 | Motivational Interviewing and Culture for Urban Native American Youth (MICUNAY) | USA | 200; 14 - 18 years | Motivational Interviewing and Culture for Urban Native American Youth vs. Community Wellness Gathering | Alcohol use \| marijuana use \| spirituality \| Cultural identification \| cultural identification | Recruiting; Start date: July 2014; Est completion date: June 2018
NCT01813123 | A Web-Based Intervention to Prevent Drug Abuse Among Adolescent Girls | USA | 788; 13 - 14 years | RealTeen vs. No Intervention | 30-day alcohol and drug use | Active, not recruiting; Start date: Mar 2013; Est completion date: Sept 2018
NCT01744951 | ADAPT: Adoption-specific Treatment Prevention Pilot Trial | USA | 60; 5 - 14 years | Adoption-specific Treatment Prevention Pilot Trial vs. Care as Usual | Parent Weekly Report \| Number of child participants whose internalizing and externalizing behaviors improve | Active, not recruiting; Start date: Oct 2012; Est completion date: Dec 2018
NCT03051633 | Substance Use Prevention Campaign for American Indian Youth | USA | 548; 11 - 14 years | Be Under Your Own Influence vs. No Intervention | Substance use survey \| Attitudes survey | Active, not recruiting; Start date: April 2014; Est completion date: Feb 2019
NCT03157700 | Interactive Technology for Media Literacy Drug Prevention in Community Groups | USA | 1200; 13+ years (youth: 13 - 15 years; adults: 21+) | REAL media curriculum vs. Programming as usual | Change in 15-item Intentions to Use Substances Measure (3 mo) \| Change in 15-item Intentions to Use Substances Measure (9 mo) \| Change in 5-item Lifetime Substance Use Measure (3 mo) \| Change in 5-item Lifetime Substance Use Measure (9 mo) \| Change in 5-item Frequency of Substance Use Measure (3 mo) \| Change in 5-item Frequency of Substance Use Measure (9 mo) | Recruiting; Start date: Mar 2018; Est completion date: Feb 2019
NCT03142009 | Family Listening Program: Multi-Tribal Implementation and Evaluation | USA | 576; 8 - 11 years | Intergenerational culturally adapted curriculum vs. No Intervention | Child substance abuse \| Child well-being \| Family well-being | Recruiting; Start date: April 2014; Est completion date: Mar 2019
NCT02383225 | Culturally Grounded Early Substance Use Prevention for American Indian Families | USA | 832; 10 - 85 years | Substance Use Resistance Skills vs. Facebook Supplement vs. Lakota Language enhancement vs. Lakota Language enhancement + Facebook + Supplement + Substance Use Resistance Skills | Youth lifetime alcohol use \| Youth past-month alcohol use \| Youth maximum alcohol use in past month \| Youth age of first alcohol use \| Youth lifetime cigarette use \| Youth past-month cigarette use \| Youth age of first cigarette use \| Youth prevalence of smokeless tobacco use \| Youth frequency of past-month smokeless tobacco use \| Youth age of first smokeless tobacco use \| Youth lifetime prevalence of e-cigarette use \| Youth past-month e-cigarette use \| Youth lifetime marijuana use \| Youth past-month marijuana use \| Youth age of first marijuana use \| Youth lifetime prevalence of huffing glue/gas \| Youth past-month huffing \| Youth age of first huffing \| Youth perceived consistency of parental discipline practices \| Youth perceived parental standard setting \| Youth perceived parental monitoring \| Youth perceived parental positive affect \| Youth perceived parental approval \| Youth perceived parental negative affect \| Youth perceived parent-child communication \| Youth perceived parent-child communication about alcohol and drugs \| Youth perceived enforcement of family rules \| Youth perceived parental autonomy support \| Parent-child shared activities - youth report \| Family cohesion - youth report \| Family conflict resolution - youth report \| Family expressiveness - youth report \| Lakota cultural socialization - youth report \| Youth perceived parental disapproval of alcohol, tobacco, and marijuana \| Descriptive norms for alcohol, tobacco, and marijuana - youth report \| Youth antisocial behavior \| Youth prosocial behavior \| Youth deviant peer influences \| Youth prosocial peer influences \| Youth peer resistance skills \| Youth lifetime history of stressful life events \| Youth stress management skills \| Youth psychological well-being \| Youth knowledge of Lakota kinship terminology \| Youth self-esteem \| General parent-child communication - parent/guardian report \| Parent-child communication about family issues - parent/guardian report \| Parent-child communication about alcohol and drugs - parent/guardian report \| Parent/guardian report of youth behavior \| Parent/guardian report parent-child shared activities \| Parental monitoring - parent/guardian report \| General family rules - parent/guardian report \| Family rules about substance use - parent/guardian report \| Parent discipline practices \| Other household member discipline practices \| Standard setting \| Parent-child conflict, parent/guardian report \| Parent support, parent/guardian report \| Parental positive affect, parent/guardian report \| Parental negative affect, parent/guardian report \| Parental anger management, parent/guardian report \| Parental self-efficacy \| Family meetings, parent/guardian report \| Family cohesion, parent/guardian report \| Family conflict resolution, parent/guardian report \| Family expressiveness, parent/guardian report \| Lakota cultural socialization, parent/guardian report \| Lakota parenting practices \| Knowledge of Lakota kinship terminology \| Parent lifetime alcohol use \| Parent past month alcohol use \| Parent past month alcohol use quantity \| Parent past month alcohol use maximum quantity \| Parent past month alcohol use usual quantity \| Parent past month alcohol intoxication frequency \| Parent first age of alcohol use \| Parent first age of alcohol intoxication \| Parent lifetime cigarette use \| Parent past month cigarette use \| Parent age of first cigarette use \| Parent lifetime smokeless tobacco use \| Parent past month smokeless tobacco use \| Parent age of first smokeless tobacco use \| Parent lifetime e-cigarette use \| Parent frequency of past-month e-cigarette use \| Parent lifetime marijuana use \| Parent past-month marijuana use \| Parent age of first marijuana use \| Parent lifetime huffing \| Parent past month huffing \| Parent age of first huffing \| Parent lifetime use of non-prescription painkillers \| Parent past month non-prescription painkiller use \| Parent lifetime stimulant use \| Parent past month stimulant use \| Parent lifetime sedative use \| Parent past month sedative use \| Parent lifetime heroin use \| Parent past month heroin use \| Parent lifetime methamphetamine use \| Parent past month methamphetamine use \| Parent lifetime hallucinogen use \| Parent past month hallucinogen use \| Parent lifetime club drug use \| Parent past month club drug use \| Parent lifetime cocaine/crack use \| Parent past month cocaine/crack use \| Parent HIV risk behavior \| Parent psychological distress \| Parent life satisfaction | Active, not recruiting; Start date: Mar 2015; Est completion date: Mar 2019
NCT02420990 | CASALEAP IT2A: Integrated Treatment for Adolescents With ADHD | USA | 140; 12 - 18 years | Medication decision-making intervention vs. Family psycho-education, family-based motivation, and academic training | Conduct Problems \| Substance Use Problems \| ADHD Symptoms \| Medication Uptake | Recruiting; Start date: April 2015; Est completion date: Mar 2019
NCT02744118 | Helping Eliminate Marijuana Use Through Pediatric Practice (HEMPP) | USA | 1020; 13 - 25 years | 5A’s Model vs. Healthy Internet Use Model | Change in Adolescent Marijuana Use \| Health and Behavioral Outcomes Related to Adolescent Marijuana Use | Recruiting; Start date: April 2016; Est completion date: Mar 2019
NCT03086434 | Intertribal Talking Circle for the Prevention of Substance Abuse in Native Youth | USA | 630; 10 - 55 years | Culturally Tailored Intervention vs. Standard Substance Abuse Education | Substance Use \| Native Self-Reliance | Enrolling by invitation; Start date: May 2014; Est completion date: April 2019
NCT03074877 | SKY: Substance Use Screening and Prevention for Adolescents in Pediatric Primary Care | USA | 1000; 9 - 13 years | Family Check-Up vs. Waitlist Group vs. No Intervention | Assessment of Liability and EXposure to Substance use and Antisocial behavior (ALEXSA) \| Centers for Epidemiological Studies Depression Scale\|Demographic Questionnaire (DEMO) \| Dyadic Adjustment Scale\|Financial Stress Questionnaire (FINCE) \| Me and My Neighborhood Questionnaire (MMNQ) \| Parent Substance Use Questionnaire (SUBST-PC)\| Child Behavior Checklist (CBCL) \| Extracurricular Activities (ECA) \|Recent Activities Interview (RAI) \| Screen for Child Anxiety‐Related Emotional Disorders (SCR) \| Self‐Report of Delinquency (SHORT) (SRD) \| Child Substance Use (TC Subst) \| Youth Risk Behavior Survey (YRBS) \| Adult Child Relationship scale (ACRS) \| Experiences Microaggression Scale (MIC) \| Child Daily Face‐to‐Face Racial Discrimination (CDIS) \| Parental Involvement Scale (PI) \|Parental Monitoring Interview - Parent Response, - Child Response (PMI-PR, PMI-CR) \| Parenting Children and Adolescents measure (PARCA) \| Parental Rating of Peers and Social Skills (PPRSK) \| Parent Child Hot topics Discussion Task \| Parent Child Hot Topics Questionnaire (PCHT) \| Monitoring & Listening Discussion Task \| Recognition Discussion Task \| Family Culture Discussion Task | Recruiting; Start date: June 2014; Est completion date: May 2019
NCT02622451 | Differential Sensitivity Markers in Youth Drug Abuse Prevention | USA | 200; 12 - 17 years | Teen Intervene vs. Everyday Parenting | Delayed Discounting Task \| Iowa Gambling Task \| Urinalysis \| Peer Substance Use Test \| Peer Delinquency Scale \| Project Towards No Drug Abuse Survey \| Alcohol Expectancy Questionnaire \| Single-item self-efficacy Scale \| Client Satisfaction Questionnaire \| Highly Sensitive Person Scale \| Parental Monitoring Instrument \| Parenting Relationship Questionnaire (PRQ) \| Family Problem Solving Communication Index \| Parental Locus of Control Questionnaire \| Family Assessment Measure - III \| Conflict Behavior Questionnaire | Recruiting; Start date: Dec 2015; Est completion date: May 2019
NCT03119415 | Enlisting Peer Cooperation and Prosociality in the Service of Substance Use Prevention in Middle School (Prosocial) | USA | 2064; Students in 7th grade (first year) or 8th grade (second year) | Cooperative Learning vs. Business as Usual | Substance use \| Strengths and Difficulties Questionnaire \| Engagement vs. Disaffection with Learning \| Classroom Life Scale \| University of Illinois Bully Scale | Active, not recruiting; Start date: July 2016; Est completion date: June 2019
NCT02038231 | PM: Parenting Mindfully Study | USA | 100; 12 - 16 years | Parenting Mindfully Program vs. Parent Education Program | Change in Substance Use \| Change in Adolescent Sex Behaviors \| Change in Parenting \|Change in Adolescent Stress Responses | Active, not recruiting; Start date: Feb 2014; Est completion date: July 2019
NCT02375516 | Preventing Drug Abuse Among Hispanic Adolescents | USA | 678; 12 - 15 years | Prevention Program vs. Control group | Change in average number of drug abuse instances | Active, not recruiting; Start date: Sept 2012; Est completion date: Aug 2019
NCT03125291 | Bridges: Optimizing a Drug Abuse Prevention Program for Dissemination | USA | 600; 10 - 15 years | Bridges 4-week Program vs. Bridges Workshop | Substance Use Problems and Risky Behaviors \| Mental Health \| Academic Outcomes | Active, not recruiting; Start date: July 2015; Est completion date: Sept 2019
NCT03060291 | Prevention of Substance Use in At-Risk Students: A Family-Centered Web Program | USA | 347; Youth: enrolled in 6th or 7th grade | Web/Mobile-only vs. Web/mobile + coach vs. Wait list control | Youth Behavioral Control (parent report) \| Youth Behavioral Control (youth report) \| Youth Substance Use (parent report) \| Youth Substance Use (youth report) \| Youth Problem Behavior (parent report)\|Youth Problem Behavior (youth report) \| Family Conflict (parent report) \| Family Conflict (youth report) \| Positive Family Relationships (parent report) \|Positive Family Relationships (youth report) \| Positive Behavior Support (parent report) \| Limit Setting (parent report) \| Monitoring (parent report)\| School Involvement (parent report)\|Parenting Self-Efficacy (parent report) | Active, not recruiting; Start date: Feb 2017; Est completion date: Sept 2019
ACTRN12612000026820 | The CAP Study: Evaluating a comprehensive universal and targeted intervention designed to prevent substance use and related harms in Australian adolescents | Australia | 1920; 12 - 15 years | Climate Schools and Preventure (CAP) vs. Standard treatment vs. Climate Schools only vs. Preventure only | Uptake and harmful use of alcohol and illicit substance \| Substance use related harms \| Alcohol and cannabis knowledge and attitudes \| Mental health comorbidity \| Behavioural problems \| Other drug use \| Use of illicit drugs \| Assess efficacy of intervention in reducing aggression \| Peer problems | Active, not recruiting; Start date: Jan 2012; Est completion date: Oct 2019
NCT02803567 | Trial of a Novel Brief Intervention on Health Behaviors for Youth With Chronic Medical Conditions | USA | 450; 14 - 17 years | Brief psycho-educational intervention vs. Control | Frequency and quantity of alcohol use \| Frequency of marijuana use \| Perceived risk of harm of substance use \| Medication Adherence | Recruiting; Start date: April 2017; Est completion date: Dec 2019
NCT03157895 | A Trial of Connecting to Promote Foster Teen Well-Being | USA | 240; 11 - 15 years | Connecting program vs. Children’s Administration services as usual | Delay in drug use initiation \| Substance use frequency \| Non-violent delinquent behavior frequency \| Violent delinquent behavior frequency \| Delay in initiation of sexual activity \| Residential placement stability \| Growth in caregiver/youth bonding \| Youth attitudes about HIV related risks \| Youth attitudes favorable toward substance use | Recruiting; Start date: Dec 2016; Est completion date: Jan 2020
NCT03009539 | eHealth Evidence-based Intervention (EBI) for Latino Youth in Primary Care | USA | 456; 12-16 years | eHealth Familias Unidas Primary Care vs. Treatment as usual | Change from baseline in past 90-day drug use as measured at 6, 12, 24 and 36 months post baseline \| Change from baseline in unprotected sexual behavior \| Change from baseline in sexually transmitted infection incidence (i.e., gonorrhea and chlamydia) \| Change from baseline in family functioning | Recruiting; Start date: April 2017; Est completion date: March 2020
NCT02502799 | Intervention for Teens With ADHD and Substance Use | USA | 300; 12 - 16 years | Parent training and adolescent cognitive behavioral therapy (PT/ACBT) vs. PT/ACBT plus concurrent stimulant medication (PT/ACBT + MED) vs. Continued monitoring of substance use with no additional treatment | Past 90-day substance use \| Evidence of illicit substances in urine screen \| Parent-adolescent conflict \| Disruptive Behaviors \| Likelihood of future substance use \| Youth impairment | Recruiting; Start date: July 2015; Est completion date: Aug 2020
NCT03107117 | JJMISCOPE: Computer-Assisted Brief Intervention | USA | 90; 14 - 17 years | Computer Counseling vs. Standard Care | Time Line Follow Back Interview (TLFB) \| Marijuana and alcohol problems | Not yet recruiting; Start date: Sept 2017; Est completion date: Aug 2020
NCT02553616 | An Intervention to Promote Healthy Behaviors in Homeless Youth | USA | 600; 18 - 23 years | Intervention to Promote Healthy Behaviors vs. No Intervention | Substance use \| Condom use most recent sex \| life satisfaction \| condom use intention \| substance use refusal self-efficacy | Recruiting
NCT02700035 | BZDDD: A Family-Centered Ojibwe Substance Abuse Prevention | USA | 1500; 8 - 100 years | Bii-Zin-Da-De-Dah (Listening to One Another) vs. BZDDD Prevention Program Control | Change in Cigarette Use \| Change in Alcohol Use \| Change in Illicit Drug Use | Enrolling by invitation; Start date: Jan 2017; Est completion date: April 2021
NCT03642106 | The Together We Can Against Alcohol Tobacco and Drug Use: A Feasibility Trial With Latino Immigrant Youth (TWC) | USA | 400; 12 to 17 | Unidos Se Puede vs. Attention placebo control | Change in past 30-day ATOD use (alcohol, tobacco, marijuana) \| Change in Allostatic Load | Recruiting; Start date: Jan 2017; Est completion date: June 2021
NCT03409328 | Understanding and Reducing HIV Risk Behavior and Substance Use Among Self-identified Bisexual Adolescent Men | USA | 60; 14- 17 years | HIV and substance use prevention vs. Waitlist | Feasibility \| Acceptability \| HIV knowledge \| STI knowledge \| Preventive behavior intentions \| Condom use self-efficacy \| Bisexual stigma and pride \| Condom use \| Past-month alcohol and drug use \| Alcohol and drug use before/during sex | Not yet recruiting; Est start date: Sept 2020; Est completion date: Aug 2021
NCT03710720 | Trauma Informed Prevention for Substance Use and Risky Sex (TIPS) | USA | 40; 13 - 18 years | Trauma Focused-Cognitive Behavioral Therapy plus TIPS app vs. Trauma Focused-Cognitive Behavioral Therapy | Risky Sexual Behaviors Scale \| Family Environment Scale \| Bad Friends Subscale of the Pittsburgh Youth Study \| Alabama Parenting Questionnaire \| UCLA PTSD Index DSM-V \| Children’s Depression Inventory \| Timeline Follow Back \| CRAFFT Screening Tool for Adolescent Substance Abuse | Not yet recruiting; Est start date: Nov 2018; Est completion date: Aug 2021
NCT03227809 | First Years Away From Home: Letting Go and Staying Connected (FYAH:LGSC) | USA | 900; 17 - 22 years | Handbook condition vs. Handbook plus condition vs. Control | Change over time in 30-day alcohol use \| Cumulative grade point average \| Continuous matriculation at university during first two years \| Past 30-day frequency of risky sexual behavior \| Lifetime alcohol use \| Past 30-day frequency of marijuana use \| Past 30-day frequency of prescription drug misuse \| Past 30-day frequency of illicit drug use \| Lifetime marijuana use \| Lifetime prescription drug misuse \| Lifetime illicit drug use \| Lifetime risky sexual behaviors \| Past two-week heavy episodic drinking episodes \| Rutgers Alcohol Problem Index \| Marijuana Consequences Index \| Sexual Consequences Index \| Reinforcement of positive behaviors by parents \| Peer rewards for antisocial behaviors \| Parental attitudes favorable to drug use \| Student attitudes favorable to drug use \| Sense of belonging \| Parent-Student Communication about Alcohol Scale \| Parental Monitoring and Consequences \| Perception of Parents Scale \| Emotional closeness between parent and student \| Frequency of parent-student communication \| Modality of parent-student communication \| Content of parent-student communication \| Emotional tone of parent-student communication | Recruiting; Start date: April 2017; Est completion date: Sept 2021
ACTRN12613000723785 | The CSC intervention: A comprehensive universal internet-based intervention to prevent anxiety, depression, substance use, and related harms in Australian adolescents aged 13 to 16 years. | Australia | 8400; 13 - 14 years | Climate Schools-Substance Use (CS-SU) vs. Climate Schools-Mental Health (CS-MH) vs. The Climate Schools Combined (CSC) vs. Control | Use and harmful use of alcohol and cannabis \| Overall anxiety/depression levels \| Anxiety, depression and substance use knowledge \| Alcohol use related harms \| Peer alcohol use \| Self-efficacy to resist peer pressure \| General disability \| Truancy \| Link between personality and substance use \| Moderators of the primary outcomes \| Suicide risk \| Psychotic experiences \| Emotion regulation \| Peer networks \| Cost effectiveness | Active, not recruiting; Start date: Jan 2013; Est completion date: Dec 2021
NCT03735784 | Intervention for Substance Use and Sexual Risk Behavior in Homeless Youth | USA | 400; 18 - 25 years | AWARE curriculum vs. Standard Care | Substance use \| Unprotected sex | Not yet recruiting; Est start date: Nov 2018; Est completion date: Mar 2022
NCT03458299 | Strategies: Motivational Interviewing/Psychoeducation | USA | 300; 13 - 20 | Motivational Interviewing vs. Psychoeducation | Drinking QF \| Binge drinking/being drunk Frequency \| Commercial Tobacco and Other Drug Use days \| DUI/RWDD days \| Negative consequences of drinking or using drugs composite | Enrolling by invitation; Start date: Jan 2018; Est completion date: Mar 2022
NCT03219190 | A High School Program for Preventing Prescription Drug Abuse | USA | 3000; 11 - 14 years | LST High School Online vs. Treatment as Usual | Change in any prescription drug use in the past year | Active, not recruiting; Start date: May 2017; Est completion date: April 2022
NCT03489434 | Technology-Based Prevention for Adolescents in Primary Care | USA | 48; 14 - 18 years | Preliminary prevention program component content based on evidence-based prevention programs for substance use, sexual assault, and sexual risk behaviors vs. No Intervention | Substance use | Recruiting; Est start date: Feb 2018; Est completion date: June 2022
NCT03517111 | The Impact of a Parenting Intervention on Latino Youth Health Behaviors (FPNG+) | USA | 2988; 12 + years (youth: 12 - 14 years; adults: 18+ years) | Nutrition/substance use prevention vs. Substance use prevention only vs. Academic success program | Recent use of substances \| Drug resistance strategies \| Nutrition outcomes \| Overall family functioning \| Parents’ social support \| Acculturation \| Food Insecurity \| Resilience \| Self-efficacy for Parenting Index \| Parent self-agency \| Parent-child communication \| Child Feeding Questionnaire \| Multidimensional Acculturative Stress Inventory \| Body weight \| Height \| Body mass index \| Systolic blood pressure \| Diastolic blood pressure \| Total cholesterol \| Glycosylated hemoglobin (HbA1c) \| Diet of adolescents \| Diet of the parents \| Home food environment | Not yet recruiting; Est start date: Aug 2018; Est completion date: Sept 2022