# Appendix E List of Abbreviations

List of Abbreviations
AA: Associate Degree
AAP: American Academy of Pediatrics
AHRQ: Agency for Healthcare Research and Quality
AI/AN: American Indian/Alaska Native
Alc: Alcohol; AUS = Australia
ARD: absolute risk difference
ASEBA: Achenbach System of Empirically Based Assessment
AUS: Australia
AUDIT: Alcohol Use Disorder Test
BA: Bachelor of Arts
BL: Baseline
CAN: Canada
CCT: Controlled clinical trial
CD: Children’s Depression Inventory
CES-D: Center for Epidemiologic Studies Depression Scale
CG: Control group
CHE: Switzerland
CHQ-CF-GH4: Child Health Questionnaire-Child Form-General Health
CI: Confidence interval
CZE: Czech Republic
DAWN: Drug Abuse Warning Network
DEU: Germany
DL: DerSimonian and Laird
DSM: Diagnostic and Statistical Manual of Mental Disorders
ED: Emergency department
EPC: Evidence-based Practice Center
Fam: Family functioning
FU: Follow up
GED: General Education Development
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HDI: Human Development Index
HS: High School
IG: Intervention group
IQR: Interquartile range
KQ: Key Question
MD: Mean difference
MH: Mental health
NA: Not applicable
NLD: Netherlands
NR: Not reported
NS: Not significant
NSDUH: National Survey on Drug Use and Health
Obs.: Observations
OR: Odds ratio
Oth: Other health behavior
POL: Poland
POSIT: Problem Oriented Screening Instrument for Teenagers
RAASI: Reynolds Adolescent Adjustment Screening Inventory
RCT: Randomized controlled trial
REML: Restricted maximum likelihood
RSex: Risky sexual behavior
SAMHSA: Substance Abuse and Mental Health Services Administration
SBIRT: Substance use, brief intervention, and/or referral to treatment
SD: Standard deviation
SDQ: Strengths and Difficulties Questionnaire
SES: Socioeconomic status
SFP: Strengthening Families Program
SMD: Standardized mean difference
SocLeg: Social-legal
SS: Secondary school
SWE: Sweden
THC: Tetrahydrocannabinol
Tob: Tobacco
USA: United States of America
USPSTF: U.S. Preventative Services Task Force
Y-OQ: Youth Outcome Questionnaire