# Appendix D Intervention Details

Appendix D Table 1 Population Characteristics, Sorted by Author

Author, year | Population | Mean age (range) | Female, % | Race/Ethnicity, % | SES | BL drug use | BL alcohol use | BL mental health | BL other comorbidities
Baldus, 2016^81^ | Aged 10-14 youth not diagnosed with substance use disorder | 12 (10-14) | 41.4 | NR | Financial strain, n (%):; No: 155 (53.1%); Yes: 137 (46.9%); Participating parent’s education, n (%):; High school graduate: 148 (95.5%); Other: 5 (3.2%); None: 2 (1.3%); Living with both biological parents: 51% | % Used Cannabis: 1.7; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: Lifetime | % Used: 21.6; Frequency:; Other:; Over: Lifetime | NR | Problem behavior, n (%): Self-reported score above cut-off (>85th percentile of norm): 20 (6.8%) Parent-reported score above cut-off (93rd percentile of norm): 25 (8.6%)
Bannink, 2014^82^ | Aged 15-16 | 15.9 (15-16) | 45.3 | NR | Ethnicity classified as Dutch/non-Dutch where Dutch = person whose parents were born in the Netherlands regardless of where you were born. Dutch = 957/1256; Non-Dutch 299/1256. | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | % Used:; Frequency:; Other:; Over: | NR | NR
Barlow, 2006^85^ | Pregnant American Indian youth aged 12 to 19 | 17 (14-20) | 100 | AI/AN: 100 | Education <12 years:41 (77%); >=12 years: 12 (23); Currently employed: 7 (13%) | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | % Used: 87; Frequency:; Other:; Over: Lifetime | Depression, mean:; IG: 17.7; CG: 18.4 | NR
Barlow, 2013^83^ | Pregnant American Indian youth aged 12-19 | 18.12 (12-19) | 100 | AI/AN: 100 | n (%); Currently unmarried: 311 (96.58%); Currently in school: 131 (40.68%); Currently employed: 23 (7.14%); Completed high school/GED: 88 (27.33%) | % Used Cannabis: 78.88; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: Lifetime | % Used: 84.16; Frequency:; Other:; Over:; Lifetime | CES-D score for depressive symptoms, n (%) (score of 16+ = depressive symptoms) ≤16: 218 (67.70%) >16: 104 (32.30%) | NR
D’Amico, 2018^116^ | Adolescents aged 12 to 18 at risk for alcohol abuse | 16.0 (12-18) | 56.8 | White: 11.5; Black: 16.7; Hisp: 66.3; Other: 5.4 | n (%); Maternal education some college or more: 65 (22.1) | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: 9.8; Times used any drug: NR; Over: 1 year | % Used: NR; Frequency: 10.0; Other:; Over: 1 year | NR | NR
Dembo, 2016^88^ | Truant youth, aged 11-17 | 14.80 (11-17) | 37.0 | White: 37.3; Black: 25.7; Asian: 1.0; AI/AN: 0.3; Hisp: 28.7; Other: 7.0 | Family annual income level % (n=297):; <$5000: 5.1% $5000-10,000: 8.1%; $10,000-25,000: 26.3%; $25,000-40,000: 27.9%; $40,000-75,000: 22.9%; >$75,000: 9.8% | % Used Cannabis: 82.3; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: 1 month | % Used: NR; Frequency:; Other:; Over: | NR | Legal problem resulting in jail time or detention: 26.4%
Estrada, 2018^90^ | Eighth graders with behavior problems | 13.6 (NR) | 37 | Hisp: 100 | % yearly household incomes below $20,000 = 55.7; Majority of adolescents born outside USA mainly from Cuba (20%), Honduras (6%), and Colombia (3%) | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: 0.61; Times used any drug: NR; Over: 3 months | % Used:; Frequency: 0.64; Other:; Over: 3 months | NR | NR
Fang, 2010^92^ | Asian American girls, aged 10-14 | 13.10 (10-14) | 100 | Asian: 100 | Single mothers % (n): 16.67 (18); Foreign born mothers % (n): 58.33 (63); Foreign born girls % (n): 19.44 (21); Mother’s education % (n); High school: 27.78 (30); College: 31.7 (33); Graduate school: 32.41 (35) | % Used Cannabis: 3.8; % Used Any Drug: NR; Times used cannabis: 0.03; Times used any drug: NR; Over: 1 month | % Used: 6.7; Frequency: 0.16; Other:; Over: 1 month | Depression: CDI = 1.51 | NR
Foxcroft, 2017^93^ | Children ages 10 to 14 | 11.9 (10-14) | 40 | NR | Highest parent education level, primary = 14.0; Highest parent education level, secondary = 28.1; Highest parent education level, college = 24.4; Highest parent education level, university = 33.6; Family structure, % dual parent = 74.3; Parent employment status, % employed full time = 57.3 | % Used Cannabis: NR; % Used Any Drug: 4; Times used cannabis: NR; Times used any drug: NR; Over: 1 year | % Used: 15; Frequency:; Other:; Over: 1 month | NR | NR
Gmel, 2013^94^ | Male conscripts, age 19 or greater | 20.1 (NR) | 0 | NR | Mandatory (9 years of schooling), 40.7%; Apprenticeship, professional school, 31.8%; High school preparing for eligibility for universities, 27.5% | % Used Cannabis: 46; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: 6 months | % Used: 55; Frequency:; Other: heavy use (binge episode) >1; Over: 1 month | NR | NR
Harris, 2012^80^ | Aged 12-18 (New England) or 13-17 (Prague) with a routine primary care appointment | 15.6 (12-18) | 55.8 | NR | Parents’ highest education level (%):; College/Uni or higher: 1165 (43.4);; High school/secondary school graduate: 1049 (39.1);; Did not complete HS/SS: 171 (6.4);; Don’t know: 222 (8.4) | % Used Cannabis: 13.2; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: 3 months | % Used: 32.3; Frequency:; Other:; Over: 3 months | NR | NR
Jalling, 2016^95^ | At-risk youth not being treated for alcohol or drug use, aged 12-18 | 14.60 (12-18) | 47.2 | NR | Foreign born mother, %:; IG2: 19.8; IG1: 20.0; CG: 20.9; Single-parent family, %:; IG2: 43.7; IG1: 50.7; CG: 41.5; Parent has university degree, %:; IG2: 28.4; IG1: 17.1; CG: 28.0; Parent is employed, %:; IG2: 86.4; IG1: 84.5; CG: 84.1 | % Used Cannabis: NR; % Used Any Drug: 16.9; Times used cannabis: NR; Times used any drug: NR; Over: 6 months | % Used: 70; Frequency:; Other:; Over: Lifetime | NR | 95.4% of the adolescents reported having engaged in any delinquent behavior in previous 6 months.
Johnson, 2015^96^ | Aged 14 to 21 | 17 (14-21) | 60 | Black: 96.0; Other: 4.0 | Maternal education Some college: 39%; HS grad/GED: 40; Dropout, no GED: 21; Participant education Drop out: 5%; HS student: 68; HS grad/GED: 27 | % Used Cannabis: 18.5; % Used Any Drug: NR; Times used cannabis: 2.4; Times used any drug: NR; Over: 30 days | % Used: 22; Frequency: 0.7; Other:; Over: 30 days | NR | NR
Kerr, 2013^97^ | Aged 14 to 17 | NR (12-18) | 60 | White: 0.2; Black: 92.0; Asian: 1.2; AI/AN: 0.1; Hisp: 4.7; Other: 6.6 | Free or reduced lunch: 73% | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | NR | NR | NR
Kim, 2011^98^ | Girls in foster care, aged 10-12 | 11.54 (10-12) | 100 | White: 63.0; Black: 9.0; AI/AN: 4.0; Hisp: 10.0; Other: 14.0 | Caregiver family income, n (%):; $24,999 or below: 20 (20%); $25,000-59,999: 50 (50%); $60,000 or more: 30 (30%) | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | NR | Psychological adjustment (ASEBA) Internalizing behavior, mean (SD):; CG 11.56 (9.42); IG 11.96 (8.19); Externalizing behavior, mean (SD):; CG 14.38 (11.65); IG 16.06 (11.05) | NR
Knight, 2019^72^ | Aged 12 to 18 | 14.8 (12-18) | 50.6 | White: 44.5; Hisp: 29.5; Other: 26.0 | Two parents at home (%): 76.8; College-graduated parents or guardians (%): 64.2; In grades 9-12 (%): 57.2 | % Used Cannabis: 12.2; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: 1 year | NR | NR | NR
Lee, 2010^100^ | Incoming college freshmen with any use of marijuana in previous 3 months | 18 (17-19) | 54.6 | White: 75.7 | NR | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: 9.86; Times used any drug: NR; Over: 90 days | NR | NR | NR
Malmberg, 2014^102^ | Aged 11 to 15 years | 13.0 (11-15) | 50.0 | NR | Ethnicity classified as Dutch/non-Dutch where Dutch = person whose parents were born in the Netherlands regardless of where you were born. Dutch = 2332/2416; Non-Dutch 84/2416. | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | NR | NR | NR
Mason, 2015^103^ | Youth at risk for substance use disorder, aged 14-18 | 16.4 (14-18) | 71 | Black: 84 | NR | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: 1 month | % Used: Frequency: 0.9; Other: Score from 0 (0 days) to 7 (all 30 days); Over: 1 month | NR | NR
Rhee, 2008^105^ | Youth with asthma, aged 14-20 | 16.05 (14-20) | 68 | White: 63; Black: 29; AI/AN: 2; Hisp: 2; Other: 2 | Family income <$30,000, 54% | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | NR | NR | Asthma severity: Mild intermittent, 43%; Mild persistent, 33%; Moderate persistent, 24%
Sanci, 2015^106^ | Aged 14-24 | NR (14-24) | 75.7 | NR | Born in Australia, n (%): 756 (83.9%); Employment/Study status, n (%):; Studying only: 237 (26.3%); Working only: 223 (24.8%); Both working and studying: 373 (41.4%); Neither working or studying: 65 (7.2%) | % Used Cannabis: NR; % Used Any Drug: 26.5; Times used cannabis: NR; Times used any drug: NR; Over: 1 year | % Used: NR; Frequency: NR; Other: Risky use 364/901 (40.4%); Over: 1 year | Emotional distress (in last month): 264/901 (29.3%) | NR
Schinke, 2009a^107^ | Females aged 11 to 13 | 12.7 (11-13) | 100 | White: 26.4; Black: 48.9; Hisp: 24.7 | NR | % Used Cannabis: 2.7; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: Lifetime | % Used: 34.2; Frequency:; Other:; Over: Lifetime | Depression score, mean: 1.67 (scale of 1-5 where lower scores are better) | NR
Schinke, 2009b^108^ | Females aged 11 to 13 | 13 (11-13) | 100 | White: 23.2; Black: 40.6; Asian: 10.8; Hisp: 23.1; Other: 1.7 | Single-parent household: 43.7%; Two-parent household: 56.3%; Mother’s education, < High school: 6.3%; Mother’s education, High school: 9.1%; Mother’s education, Some college: 28.3%; Mother’s education, A.A. or B.A. degree: 42.6%; Mother’s education, Graduate degree: 13.7% | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: 0.09; Times used any drug: NR; Over: 1 month | % Used:; Frequency: 0.16; Other:; Over: 1 month | 3.35 on 5-point scale, higher scores better | NR
Schwinn, 2010^110^ | Females aged 13-14 | 14 (13-14) | 100 | White: 61; Black: 16; Asian: 7; Hisp: 7; Other: 9 | Live with mother and father, 53.0 % | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | NR | NR | NR
Schwinn, 2015^112^ | Sexual-minority adolescents, aged 15-16 | 16 (15-16) | 50 | White: 62.1; Black: 9.6; Asian: 7.4; Hisp: 13.2; Other: 7.5 | NR | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: 1.8; Times used any drug: NR; Over: 30 days | % Used:; Frequency: 0.92; Other:; Over: 30 days
Schwinn, 2018^111^ | Females aged 13 to 14 residing in the United States | 13.7 (13-14) | 100 | White: 64.5; Black: 24.5; Hisp: 15.0; Other: 18.5 | More than 80% of girls resided in urban areas, 9% in large towns, 10% in small towns/rural areas. The most recent average letter grade earned in school was 1.68 (where “mostly A’s” = 1 and “mostly B’s” = 2). One-half of parents had 2 or more years of college. | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: 0.82; Times used any drug: NR; Over: 1 month | % Used:; Frequency: 1.09; Other:; Over: 1 month
Walkup, 2009^113^ | Pregnant American Indian youth, aged 12-22 | 18 (14-22) | 100 | AI/AN: 100 | HS/GED/some college: 39%; Current employment: 12% | % Used Cannabis: NR; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: NR | NR
Walton, 2013^114^ | Youth with past year cannabis use, aged 12 to 18 | 16.3 (12-18) | 66.5 | Black: 60.7; Hisp: 11.0 | Dropped out of school: 5.8%; Failing grades: 25.9% | % Used Cannabis: 100; % Used Any Drug: NR; Times used cannabis: NR; Times used any drug: NR; Over: 3 months | % Used: 53.1; Frequency: 0.4; Other: Score from 0-4 where lower is better; Over: 3 months
Walton, 2014^115^ | Youth with no cannabis use in past year, aged 12-18 | 14.9 (12-18) | 57 | Black: 63.7; Hisp: 9.2 | Failing grades: 17.1% | % Used Cannabis: 0; % Used Any Drug: 6.9; Times used cannabis: NR; Times used any drug: NR; Over: 3 months | % Used: 12.0; Frequency: 0.2; Other: Score from 0-13 where lower is better; Over: 3 months

Abbreviations: AI/AN = American Indian/Alaska Native; ASEBA = Achenbach System of Empirically Based Assessment; BL = Baseline; CDI = Children’s Depression Inventory; CES-D = Center for Epidemiologic Studies Depression Scale; CG = Control group; GED = General Education Development; HS = High School; IG = Intervention group; NR = Not reported; SES = Socioeconomic status; SD = Standard Deviation; SS = Secondary school.

Appendix D Table 2 Intervention Characteristics, Sorted by Author

Author, year | IG | Int target | Brief IG description | Int dur., wks | No. of sess. | Est hours | Int. format | Int. setting | Int. provider | CG category | Brief CG description
Baldus, 2016^81^ | IG1 | Youth, Parent | Strengthening Families Program 10-14: 11 x 2-hour family-based group sessions to reduce risk of substance abuse and behavior problems | 26 | 11 | 22 | Group (in-person) | Social services agency | Educator or Counselor NOS | Minimal | 2-hour parent session on physical and mental changes effecting teenagers.
Bannink, 2014^82^ | IG1 | Youth | 1 x 45-minute computer-based program to assess health-risk behavior and well-being with tailored messages; referred for consultation if at-risk of mental health problems or if youth self-refers | NR | 2 | 1.2 | Individual (in-person), Computer-based | School | Nurse, Self-Admin | Usual care | Usual care, briefer assessment of risk behaviors, option to self-refer to nurse
Bannink, 2014^82^ | IG2 | Youth | 1 x 45-minute computer-based program to assess health-risk behavior and well-being with tailored messages; option to self-refer to nurse | 0.14 | 1 | 0.8 | Computer-based | School | Self-Admin | Usual care | Usual care, briefer assessment of risk behaviors, option to self-refer to nurse
Barlow, 2006^85^ | IG1 | Youth | Family Spirit: 25 x 90-minute in-home sessions on parenting, substance abuse prevention, coping, and other maternal and infant health topics | 39 | 25 | 37.5 | Individual (in-person) | Home | Educator or Counselor NOS | Attention control | Breast-feeding/nutrition education during 23 1- to 1.5-hour home visits
Barlow, 2013^83^ | IG1 | Youth | Family Spirit: 43 x 60-minute in-home sessions on parenting, substance abuse prevention, coping, and other maternal and infant health topics | 168 | 43 | 43 | Individual (in-person) | Home | Educator or Counselor NOS | Minimal | Transportation assistance to regularly scheduled, clinic-based 7 prenatal and 9 well-baby visits, provision of pamphlets about child care and community resources for parents, and referrals to local services as needed.
D’Amico, 2018^116^ | IG1 | Youth | 1 x 15-20 minute individual brief motivational interview for youth focusing on motivation to change and substance use prevention | 0.14 | 1 | 0.3 | Individual (in-person) | Primary Care | Research staff NOS | Usual care | Brochure that included information on the effects of AOD use, how to prepare for risky situations, and online and telephone resources to obtain additional information.
Dembo, 2016^88^ | IG1 | Youth, Parent | 2 x 75-min youth sessions on substance use and consequences 1 x 75-min parent session on parental attitudes of use | 3 | 3 | 3.8 | Individual (in-person) | Home | Research staff NOS | Attention control | Usual truancy services plus 3 weekly 1-hour visits to project staff with information on local services.
Dembo, 2016^88^ | IG2 | Youth | 2 x 75-minute individual sessions on substance use and consequences | 2 | 2 | 2.5 | Individual (in-person) | Home | Research staff NOS | Attention control | Usual truancy services plus 3 weekly 1-hour visits to project staff with information on local services.
Estrada, 2018^90^ | IG1 | Youth, Parent | Online version of Familias Unidas (eHealth Familias Unidas); 8 x 30-min online recorded e-parent group sessions accessed via the internet and 4 x 45-min parent-adolescent family sessions delivered by a facilitator via web-based video conferencing software | 13 | 12 | 7 | Computer-based, Video | Home | Research staff NOS, Self-Admin | Usual care | HIV prevention curriculum in health science class
Fang, 2010^92^ | IG1 | Youth, Parent | 10 x 35-45-minute interactive online sessions for mother-daughter dyads on family functioning, self-efficacy, social skills, and drug use prevention | 26 | 10 | 7.5 | Computer-based | Home | Self-Admin | Assessment only | No access to intervention
Foxcroft, 2017^93^ | IG1 | Youth, Parent | Strengthening Families Program 10-14: 7 x 120-min group substance use prevention sessions for parent-youth dyads | 7 | 7 | 14 | Group (in-person), Video | NR | Research staff NOS | Minimal | Leaflets
Gmel, 2013^94^ | IG1 | Youth | 2 x 20-minute counseling sessions targeting multi-substance use behaviors in men ages 19 and older | 0.28 | 2 | 0.7 | Individual (in-person) | Other Medical | Psychologist | Assessment only
Harris, 2012^80^ | IG1 | Youth | 1 x 7-8-minute computer and provider based screening and intervention to not start/stop substance use | 13 | 1 | 0.1 | Individual (in-person), Computer-based | Primary Care | PCP | Usual care | NR
Jalling, 2016^95^ | IG1 | Parent | 6 x 120-min group sessions to increase parental understanding of youth development & skill improvement | 6 | 6 | 12 | Group (in-person) | NR | Social Worker | Waitlist | 6-month wait-list
Jalling, 2016^95^ | IG2 | Parent | 10 x 150-minute group parent sessions to help to develop and enhance their skills and self-efficacy for parenting | 9 | 10 | 25 | Group (in-person) | NR | Social Worker | Waitlist | 6-month wait-list
Johnson, 2015^96^ | IG1 | Youth | 3 positive youth development motivational interview sessions with phone or email followup targeting career readiness and addressing risky behaviors (time NR) | 26 | 6 | 1.8 | Individual (in-person) | Primary Care | Educator or Counselor NOS | Minimal | Invitation to bi-annual job and college fairs at the clinic, monthly newsletters with information about local opportunities to build their resume.
Kerr, 2013^97^ | IG1 | Youth | 2 x 8-hour group workshops covering diet, physical activity, and drug prevention | 2 | 2 | 16 | Group (in-person) | NR | NR | Attention control | Focus on Youth, a sexual risk reduction HIV/STI-prevention intervention. Similar frequency, length, and structure as the IG.
Kim, 2011^98^ | IG1 | Youth, Parent | 6 group sessions of caregiver training; 6 group sessions of skill-building and 40 individual coaching sessions for adolescent girls (time NR) | 43 | 46 | 86 | Individual (in-person), Group (in-person) | NR | Research staff NOS, Lay provider | Usual care | Usual child welfare agency services
Knight, 2019^72^ | IG1 | Youth | 1 2 to 5-minute conversation about the risks of substance abuse using motivational interviewing strategies | 0.14 | 1 | 0.25 | Individual (in-person) | Primary Care | PCP | Usual care | Self-administered computer screening
Lee, 2010^100^ | IG1 | Youth | 1 computer-based individualized personalized feedback session (time NR) | 0.14 | 1 | 0.5 | Computer-based | Home | Self-Admin | Assessment only | No intervention
Malmberg, 2014^102^ | IG1 | Youth | 3 interactive modules (1 module per year for 3 years) on substance use prevention (time NR) | 156 | 3 | 1.5 | Computer-based | School | Self-Admin | Usual care | Control schools agreed not to start any substance-related interventions in target group during study period, but could continue with already established programs.
Mason, 2015^103^ | IG1 | Youth | 1 x 20-minute individual motivational interviewing session with peer network counseling | 0.14 | 1 | 0.3 | Individual (in-person) | NR | Educator or Counselor NOS | Attention control | 20-min review of handout on health behaviors (e.g., exercise, nutrition, weight management, life skills)
Rhee, 2008^105^ | IG1 | Youth | 3 x 30-min CD-ROM sessions covering decision-making and risk behaviors | 17 | 3 | 3.2 | Individual (phone), Computer-based | Other Medical, Home | Nurse, Self-Admin | Minimal | Study skills CD-ROM, comparable time and duration
Sanci, 2015^106^ | IG1 | Youth, Practitioner | Provider training to screen for risky behaviors and discuss protective factors with youth, plus supported plan-do-study-act cycle. | NR | 1 | 0.2 | Individual (in-person) | Primary Care | Nurse, PCP | Assessment only | 3-hour clinician seminar on youth-friendly care, including recommendations to discuss health risks with young people.
Schinke, 2009a^107^ | IG1 | Youth, Parent | 9 x 45-minute individual computer sessions for mother-daughter dyads aimed to reduce substance use through mother-daughter interactions | 9 | 9 | 6.8 | Computer-based | Home | Self-Admin | Assessment only | No intervention
Schinke, 2009b^108^ | IG1 | Youth, Parent | 9 X 45-minute weekly computer-based substance use prevention sessions plus two annual booster sessions for mother-daughter dyads | 104 | 11 | 8.2 | Computer-based | Home | Self-Admin | Assessment only
Schwinn, 2010^110^ | IG1 | Youth | RealTeen: 12 x web-based modules and homepage access to curated online community | 4 | 12 | 5 | Computer-based | Home | Self-Admin | Assessment only | No intervention
Schwinn, 2015^112^ | IG1 | Youth | 3 x 14-minute individual computer sessions for youth | 4 | 3 | 0.7 | Computer-based | Home | Self-Admin | Assessment only | None
Schwinn, 2018^111^ | IG1 | Youth | RealTeen: 9 x 15-minute online substance use prevention sessions for girls aged 13-14 | 14 | 9 | 2.8 | Computer-based | Home | Self-Admin | Assessment only | No intervention
Walkup, 2009^113^ | IG1 | Youth | Family Spirit: 25 x 60-minute in-home sessions on parenting, substance abuse prevention, and problem-solving and coping skills | 38 | 25 | 25 | Individual (in-person) | Home | Lay provider | Attention control | Breast-feeding/nutrition education during 23 1-hour home visits
Walton, 2013^114^ | IG1 | Youth | 1 MI session (time NR) | 0.14 | 1 | 0.6 | Individual (in-person) | Primary Care | Educator or Counselor NOS | Minimal
Walton, 2013^114^ | IG2 | Youth | 1 computer-based MI session (time NR) | 0.14 | 1 | 0.6 | Computer-based | Primary Care | Self-Admin | Minimal
Walton, 2014^115^ | IG1 | Youth | 1 x 38-minute MI session | 0.14 | 1 | 0.6 | Individual (in-person) | Primary Care | Educator or Counselor NOS | Minimal | Brochure with warning signs of problematic cannabis use and community resources
Walton, 2014^115^ | IG2 | Youth | 1 x 33-minute computer-based MI session | 0.14 | 1 | 0.6 | Computer-based | Primary Care | Self-Admin | Minimal | Brochure with warning signs of problematic cannabis use and community resources

Abbreviations: CG = Control group; STI = Sexually transmitted infection; IG = Intervention group; MI = Motivational interviewing; NOS = Not otherwise specified; NR = Not reported; PCP = Primary care provider.

Appendix D Table 3 Intervention Descriptions

Author, year | IG | Intervention target | Detailed IG description | Intervention duration; No of sessions; Total min | Intervention setting; Intervention format; Intervention provider | CG category | Detailed CG description
Baldus, 2016^81^ | IG1 | Youth, Parent | Manual-based, 7 weekly sessions plus another 4 booster sessions that are conducted 4–6 months after the 7th session. In each session, at least three group facilitators work with 8–12 families, at first separately with parents and children, later with the whole family. Children sessions aim at improving children’s self-efficacy and their ability to cope with stress and peer pressure. Parent sessions encourage caregivers to reflect their parenting style, to develop a more consistent form of parenting (“using love and limits”), and to express positive affect more openly. After each session, a family meal is provided to strengthen support and sharing between families. Families receive a €15 voucher after each session.; Per clinical trial register: During the first hour of the training, parents and adolescents are separated and attend individual groups. In the second hour, families are reunited for the family session. | 26 wks; 11; sessions 1320 min | Social services agency; Group (in-person); Educator or Counselor NOS | Minimal | Developed for ‘assessment reactivity effects’. The programme gives information about the physical and mental changes affecting teenage youth. Parents are informed how they best can react to these changes and keep a trusting relationship. Video segments are used to show typical conflict situations at home and different ways to react to them. Material for this intervention came from a brochure with information about parenting for parents of adolescents (Starke Kinder - Ein Magazin für Eltern, BZgA; www.bzga.org) while the video segments came from another video-based prevention programme (“Freiheit in Grenzen”). A presentation with instructions along with video segments was sent to the cooperating agencies. At each agency, a staff member was assigned to deliver the event adhering closely to the slide show and instructions. Families allocated to the control condition are invited to a one-evening-only event, at which the two-hour programme was delivered. The event is closed with a complementary meal.
Bannink, 2014^82^ | IG1 | Youth | A 45-minute computer program covering 9 topics related to health risk behavior and well-being: alcohol consumption, drugs use, smoking, sexual behavior, bullying, mental health status, suicidal thoughts, suicidal attempts and unpleasant sexual experience. The messages were tailored for ages 12-18. For each topic a score is computed and compared to Dutch norms. Based on the score, a message related a message is presented that reflects the person’s current behavior or well-being, the Dutch health norm, and offers advise to change unhealthy behavior or to talk to a person they trust, and links to websites. Immediately following completion of the program, adolescents are invited to join a Facebook group with further information. Adolescents can check a box for a self-referral with the nurse, or can send an e-mail to the nurse. Those who report/score mental health problems are invited to have a consultation with the school nurse. After one month the adolescents receive a reminder of the tailored messages.; Optional nurse consultation The consultation took place at school and was provided by school nurses who were already working at the schools and who had already provided consultations to adolescents at approximately 13 years of age. These nurses were trained to apply motivational interviewing with adolescents at age 15-16 years. They received the results of the assessment for each referred adolescent before the consultation. During the consultation, the nurses focused on specific risk areas and on mental health in particular. Furthermore, they either initiated a further consultation with themselves or referred adolescents to another professional if they deemed this necessary. | NR wks; 2; sessions 75 min | School; Individual (in-person), Computer-based; Nurse, Self-Admin | Usual care | Completed the same questionnaire assessing health-risk behaviors and well-being as adolescents in the intervention groups, with the exception of the questions on unpleasant sexual experience, suicidal thoughts, and suicidal attempts. The control group received care as usual (i.e., adolescents could check a box for a self-referral with the nurse or could send an email to the nurse with any question or request for information or care).
Bannink, 2014^82^ | IG2 | Youth | A 45-minute computer program covering 9 topics related to health risk behavior and well-being: alcohol consumption, drugs use, smoking, sexual behavior, bullying, mental health status, suicidal thoughts, suicidal attempts and unpleasant sexual experience. The messages were tailored for ages 12-18. For each topic a score is computed and compared to Dutch norms. Based on the score, a message related a message is presented that reflects the person’s current behavior or well-being, the Dutch health norm, and offers advise to change unhealthy behavior or to talk to a person they trust, and links to websites. Immediately following completion of the program, adolescents are invited to join a Facebook group with further information. Adolescents can check a box for a self-referral with the nurse, or can send an e-mail to the nurse. After one month the adolescents receive a reminder of the tailored messages. | 0.14 wks; 1; sessions 45 min | School; Computer-based; Self-Admin | Usual care | Completed the same questionnaire assessing health-risk behaviors and well-being as adolescents in the intervention groups, with the exception of the questions on unpleasant sexual experience, suicidal thoughts, and suicidal attempts. The control group received care as usual (i.e., adolescents could check a box for a self-referral with the nurse or could send an email to the nurse with any question or request for information or care).
Barlow, 2006^85^ | IG1 | Youth | The home-visiting intervention was modeled on “Healthy Families America.” Healthy Families America is a national program founded on 12 research-based principles to ensure quality of home-visiting interventions for at-risk families. The content of the home-visiting intervention was derived from extensive community input on what teen parents needed to learn and was based on the American Academy of Pediatrics Guide to Baby Care: Caring for Your Baby and Young Child: Birth to Age 5. Lessons covered prenatal care, labor, delivery, breastfeeding, nutrition, parenting, home safety, immunizations, well-baby care, family planning, sexually transmitted disease prevention, and maternal goal setting for personal and family development. The curricular content was scheduled chronologically to provide key instruction at developmentally appropriate times for participants’ children. The protocol included 25 home visits and 41 discrete lessons taught from 28 weeks’ gestation until 6 months post-partum (about 9 months total) by the educators using tabletop flip charts. Home visits were scheduled to last approximately 1.5 hours. Cultural adaptations—including style, graphics, delivery, and content—were achieved through a community-based participatory process. | 39 wks; 25; sessions 2250 min | Home; Individual (in-person); Educator or Counselor NOS | Attention control | Control participants received a breastfeeding education program that was developed in 1996-1997 by Johns Hopkins Center for American Indian Health and the participating communities. Participants assigned to the control arm were scheduled to receive 23 home visits covering 20 breastfeeding lessons. The expected visit duration was 1 to 1.5 hours.
Barlow, 2013^83^ | IG1 | Youth | Family Spirit: consists of 43 highly structured lessons delivered by Native paraprofessionals. Content targets three domains: parenting skills across early childhood (0–3 years); maternal drug abuse prevention; and maternal life skills and positive psychosocial development. Home visitors deliver lessons one-on-one in participants’ homes using tabletop flip charts. The flip chart is designed so that the participant views illustrated content that often includes a real-life scenario while the home visitor reviews an outline of key points relating to the scenario and illustration. Each home visit was designed to last ≤1 hour, including a brief warm-up conversation, conducting the lesson, a question/answer period, and providing summary handouts. Home visits occurred weekly through the end of pregnancy, biweekly until 4 months postpartum, monthly between 4 and 12 months postpartum, and bimonthly between 12 and 36 months postpartum. Staff also distribute quarterly study newsletters, birthday cards for mothers and their babies and annual certificates of program completion. Incentives in the form of Walmart gift cards are given for assessments, and increase with duration of participation in the study (i.e., start at $10 for initial assessment and increase by $5 per time point for maximum of $50 for final assessment).; Optimized Standard Care (OSC, offered to both IG and CG, not counted in total session count): consists of transportation assistance to regularly scheduled, clinic-based prenatal and well-baby visits as recommended by the IHS and American Academy of Pediatrics, provision of pamphlets about child care and community resources for parents, and referrals to local services as needed. OSC visits include seven prenatal visits, nine well-baby visits during the first 3 years of life. 1 week, 2 weeks, and 2, 4, 6, 9, 12, 24 and 36 months postpartum), and four social support visits between years 2 and 3. | 168 wks; 43; sessions 2580 min | Home; Individual (in-person); Educator or Counselor NOS | Minimal | OSC consists of transportation assistance to regularly scheduled, clinic-based prenatal and well-baby visits as recommended by the HIS and American Academy of Pediatrics, provision of pamphlets about child care and community resources for parents, and referrals to local services as needed. OSC visits include seven prenatal visits, nine well-baby visits during the first 3 years of life. 1 week, 2 weeks, and 2, 4, 6, 9, 12, 24 and 36 months postpartum), and four social support visits between years 2 and 3.
D’Amico, 2018^116^ | IG1 | Youth | CHAT is a 15- to 20-min brief MI intervention that first focuses on assessing motivation for change by discussing adolescents’ personal pros and cons of AOD use and determining what their friends think about AOD use and how this might affect their own use. The facilitator then provides normative information for AOD use. Next, adolescents are asked to discuss what they think might happen if they continue to use AOD in the same way. Depending on where adolescents are at in terms of wanting to make changes in their behavior, a discussion that addresses their willingness and confidence to cut back and/or stop their use follows. Finally, if adolescents are willing, they discuss a plan to prepare for high-risk situations where AOD might be present and how they could make a healthy choice in those situations. Facilitators delivered CHAT after adolescents completed their baseline survey | 0.14 wks; 1; sessions 20 min | Primary Care: Individual (in-person); Research staff NOS | Usual care | Usual care participants received a brochure that included information on the effects of AOD use, how to prepare for risky situations, and online and telephone resources to obtain additional information.
Dembo, 2016^88^ | IG1 | Youth, Parent | Youths were administered two BI sessions, and their parents/guardians were administered one BI session. Each BI session lasted for 1-1/4 hours, and occurred about a week apart. Each youth and parent/guardian was paid $15 for completing the baseline interview and each followup session.; Youth; The first BI session with the youth focused on discussing the youth’s substance use and related consequences, the level of willingness to change, the causes and benefits of change, and what goals for change the youth wanted to select and pursue. The youth was encouraged to pursue goals of drug abstinence or reduction in drug use. In the second session with the youth, the counselor reviewed the youth’s progress with the agreed upon goals, identified risk situations associated with difficulty in achieving goals, discussed strategies to overcome barriers toward goal achievement, reviewed where the youth was in the process of change, and negotiated either continuation or advancement of goals. Informed by an integrated behavioral and family therapy approach.; Parent/guardian; The parent BI session addressed the youth’s substance use issues, parent attitudes and behaviors regarding this use, parent monitoring and supervision to promote progress towards their child’s intervention goals, and parent communication skills to enhance youth-parent connectedness. | 3 wks; 3; sessions 225 min | Home; Individual (in-person); Research staff NOS | Attention control | In addition to the normal truancy services provided, CG youths/families received a referral service overlay of three weekly hour long visits by a project staff member. The point of the CG condition was to provide publicly available contact information on local services available to the youth’s family. No form of counseling or therapy was offered.
Dembo, 2016^88^ | IG2 | Youth | Each BI session lasted for 1-1/4 hours, and occurred about a week apart. Each youth was paid $15 for completing the baseline interview and each followup session.; The first BI session with the youth focused on discussing the youth’s substance use and related consequences, the level of willingness to change, the causes and benefits of change, and what goals for change the youth wanted to select and pursue. The youth was encouraged to pursue goals of drug abstinence or reduction in drug use. In the second session with the youth, the counselor reviewed the youth’s progress with the agreed upon goals, identified risk situations associated with difficulty in achieving goals, discussed strategies to overcome barriers toward goal achievement, reviewed where the youth was in the process of change, and negotiated either continuation or advancement of goals. Informed by an integrated behavioral and family therapy approach. | 2 wks; 2; sessions 150 min | Home; Individual (in-person); Research staff NOS | Attention control | In addition to the normal truancy services provided, CG youths/families received a referral service overlay of three weekly hour long visits by a project staff member. The point of the CG condition was to provide publicly available contact information on local services available to the youth’s family. No form of counseling or therapy was offered.
Estrada, 2018^90^ | IG1 | Youth, Parent | Eight online pre-recorded e-parent group sessions that are accessed via a website (Parental Investment in Adolescent Worlds, Enhancing Communication Skills, Family Support and Behavior Management, Parent Monitoring of Peer World, Adolescent Drug Use, Parent Investment in Adolescent’s School, Adolescent Sexual Risk Behaviors, Prevention Has To Be Acheived All Over Again Everyday), and four parent-adolescent family sessions (Engagement and Orientation, Family Communication, Parental Monitoring of Peer World and Adolescent Drug Use, Adolescent Sexual Risk Behaviors) that are delivered by a trained facilitator. E-parent group sessions consisted of video recordings with three components: simulated parent group discussions, a culturally syntonic telenovela (soap opera) series, and interactive exercises. Sessions were designed so that parents were unable to fast forward or skip through sessions. Each participant was assigned a unique login name and password. The login procedure facilitated close monitoring of participants, particularly as it related to session participant rates. The research team was able to track who, when, how long, and for what purpose the intervention website was accessed. | 13 wks; 12; sessions 420 min | Home; Computer-based, Video; Research staff NOS,Self-Admin | Usual care | Prevention as usual consisted of the HIV prevention curriculum provided by MDCPS via health science classes. The curriculum has six lessons delivered in a classroom setting and aim to provide information about HIV/AIDS and other sexually transmitted infections. Given that prevention as usual represents current community prevention activities, it is likely that participants from the experimental condition also received this curriculum.
Fang, 2010^92^ | IG1 | Youth, Parent | Nine 35-45 minute interactive online sessions (each including three to five modules) completed by mother-daughter dyads covering. Aiming to preventing girls’ substance use through enhancing mother-daughter interactions, the program helped mothers establish clear rules about consequences for substance use, manage conflict, monitor their daughters’ behavior and activities, improve their children’s self-esteem, and gain competency in empathizing with their daughters and assisting them in coping with stress. At the same time, the program assisted girls to manage stress and interpersonal conflict, build refusal skills, enhance self-efficacy, increase their social supports and prosocial activities, and maintain close relationships with their mothers. (Titles of sessions: my mom and me; conflict management; substance use opportunities; body image; mood management; stress management; problem solving; social influences; and self efficacy.); One booster session reviewing initial program material and highlighting the issue on self-efficacy, problem solving, refusal skills, parent monitoring, parent-child communication, and parent-child closeness one year after initial program completion. | 26 wks; 10; sessions 450 min | Home; Computer-based; Self-Admin | Assessment only | No access to intervention
Foxcroft, 2017^93^ | IG1 | Youth, Parent | Strengthening Families Program 10-14; the video based program was delivered by trained facilitators where parents/guardians and children learned together. In the first hour of each session parallel groups of children and parents develop their understanding and skills, led by parent and child group facilitators; in the second hour, parents and children come together in family units to practice principles they have learned. | 7 wks; 7; sessions 840 min | NR; Group (in-person),Video; Research staff NOS | Minimal | Communities in the control arm of the trial received information leaflets for families
Gmel, 2013^94^ | IG1 | Youth | Conscripts were invited to a counseling session on tobacco, cannabis, and alcohol use lasting approximately 20 minutes in order to reinforce motivation to change using motivational interviewing. Interviewing involved exploring the use of tobacco, cannabis, alcohol and other substances by introducing and discussing behavior change perspectives in a non-judgmental, empathic and collaborative manner. Interviewing consisted of the following components to focus on the main problem(s) of each individual: (a) establish a collaborative rapport to enable elicitation of multiple substance use; (b) ensure confidentiality; (c) ask permission to talk about behaviors; (d) ask with open questions about substance use and focus on areas that the conscript considers problematic; (d) explore pros and cons; (f) reflect and affirm change talk and enhance values that might be incompatible with present substance use; (g) explore the importance, confidence and readiness to change; (h) evoke commitment to a change plan; and (i) support the conscript’s self-efficacy. | 0.28 wks; 2; sessions 40 min | Other Medical; Individual (in-person); Psychologist | Assessment only
Harris, 2012^80^ | IG1 | Youth | 1 session that included a computer-based self-administered screening about substance use including CRAFFT questions and score and 1o pages information materials; a 5-min computer-based intervention immediately following screening; and a 2-3 min provider discussion to not start/stop substance use. Providers received a report showing CRAFFT results, risk level, and 6-10 points to use as a basis for discussion. | 13 wks; 1; sessions 8 min | Primary Care; Individual (in-person), Computer-based; PCP | Usual care | NR
Jalling, 2016^95^ | IG1 | Parent | ParentSteps is conveyed and practiced by means of video vignettes, group discussions, and home assignments. The themes for the six sessions and home assignments are Love and limits; Encouragement and consequences; Risks and protection; Stress, fights and different points of view; Youth, parents and alcohol; and Youth, parents and drugs. ParentSteps has a highly structured format, and the video film for each session also provides the time-points for the starting and ending of group discussions and the assignments for that session. | 6 wks; 6; sessions 720 min | NR; Group (in-person); Social Worker | Waitlist | 6-month wait-list
Jalling, 2016^95^ | IG2 | Parent | Comet 12-18. overall aim is to help parents to develop and enhance their skills and self-efficacy for parenting. Principle program components are rehearsals of the use of reinforcement principles (e.g. encouragement and praise and ignoring minor problems) through role-play and home-assignments where parents practice and develop the principles in their daily lives. Parents keep a diary to document their interactions with their adolescent and home assignments are followed-up in subsequent sessions. Video vignettes are used in each session to enhance learning. Examples of themes covered during the nine group sessions include taking initiatives for spending time together with the adolescent, dealing with rejection, basic interactional (behavioral) analysis, positive communication and encouragement, problem solving, and rules and consequences. | 9 wks; 10; sessions 1500 min | NR; Group (in-person); Social Worker | Waitlist | 6-month wait-list
Johnson, 2015^96^ | IG1 | Youth | The Healthy Futures intervention takes a positive youth development (PYD) perspective, which is based on the belief that successful adult development is not the absence of involvement in risk behaviors, but the presence of developmentally appropriate skills. The Healthy Futures intervention seeks to understand additional health implications of career readiness intervention taking advantage of the strengths of locating such an intervention in a pediatric primary care clinic. Building on the Social Cognitive Theory, the intervention focuses on identifying and overcoming environmental and behavioral barriers to future plans as well as improving self-efficacy through skill-building activities. These activities are facilitated through motivational interviewing (MI).; Participants received 3 in-person MI sessions (approximately 1 every other month), which took place at the clinic with follow-up contact via phone or email after each session (i.e., in the in-between month). The MI sessions were facilitated by master’s level educators trained in MI. Intervention activities were not part of a clinic visit, although clinicians were informed if their patient was taking part in the Healthy Futures intervention. Activities in each session provided opportunities for the youth to discuss their goals for the future, identify barriers to accomplishing these goals (including involvement in risk behaviors), practice the skills necessary to accomplish these goals (e.g., research careers, explore jobs and educational programs, develop their resume, complete applications), and link them to community resources. Explicit efforts were made to create cognitive dissonance around involvement with violence, substance use, and unsafe sexual practices and stated future plans, as the research team identified these behaviors as both prevalent and possibly negatively influencing vocational plans. For example, the MI coach might ask youth about the barriers to accomplishing their future plans. This conversation could be facilitated by a statement such as “I sometimes see in the youth that I work with that having a child before they are ready, their involvement with the law, and their drug use preventions them from accomplishing their goals. Why might some of these be/not be a problem for you?”.; All participants (IG and CG) were invited to participate in bi-annual job and college fairs held at the clinic and received a monthly newsletter containing information about local opportunities to build their resume. | 26 wks; 6; sessions 105 min | Primary Care; Individual (in-person); Educator or Counselor NOS | Minimal | All participants were invited to participate in bi-annual job and college fairs held at the clinic and received a monthly newsletter containing information about local opportunities to build their resume.
Kerr, 2013^97^ | IG1 | Youth | PHAT is a culturally tailored intervention for African American adolescents, focusing on three dimensions of health behavior (dietary behavior, physical activity, and substance use) for premature cancer and cardiovascular disease prevention. The intervention used various interactive learning activities to increase health knowledge, develop health behavior skills, change attitudes, increase self-efficacy, and explore beliefs regarding personal health behaviors. PHAT utilized cultural pride, goal setting, and instruction in dietary behaviors, physical activity, nutrition cognition, proper sleeping habits, and substance abuse. PHAT is designed to increase healthy behaviors of adolescents through the following: knowledge building, reexamination of beliefs regarding risk and consequences, development of skills to delineate and execute behaviors that reduce health risk, increasing self-efficacy to engage in health-beneficial behavior, and increasing motivation to implement healthy behaviors. PHAT was conducted using group facilitation, role-playing, games, and classroom multimedia messages.; Based on Social Cognitive Theory (SCT). The PHAT curriculum was designed to modify intrapersonal attributes that affect health behavior such as knowledge, self-efficacy, and perceived susceptibility. Furthermore, the program was designed to modify expectancies regarding health behaviors and subsequent health outcomes. It also promoted self-efficacy to perform healthy dietary, physical activity, and drug use behaviors. In particular, activities in this intervention were designed to increase confidence to conduct healthy behaviors and overcome barriers that prevent their execution. The program was also designed to raise awareness concerning how behaviors affect the community as well as how the community influences behaviors and personal beliefs. Finally, PHAT was designed to increase skills to execute behaviors that prevent cardiovascular disease and cancer. | 2 wks; 2; sessions 960 min | NR; Group (in-person); NR | Attention control | Focus on Youth, a sexual risk reduction HIV/STI-prevention intervention. Similar frequency, length, and structure as the IG.
Kim, 2011^98^ | IG1 | Youth, Parent | Delivered the summer prior to entering middle school. Both interventions met twice a week for 3 weeks.; Caregiver intervention 6 group-based sessions on caregiver management training for foster parents focusing on establishing and maintaining stability in the foster home, preparing girls for the start of middle school, and preventing early adjustment problems during the transition to middle school to develop a behavioral reinforcement system to encourage adaptive behaviors across home, school, and community settings. A 10-min phone interview with caregivers about behavioral and emotional issues and the types of discipline and supervision used during the past 24 hr, to connect the planned curriculum to the daily challenges the foster parents were facing. Facilitators used items on the PDR to review specific problem behaviors that occurred during the day, and these behaviors were then used as the week’s examples of the curriculum. Weekly home practice assignments were provided to encourage foster parents to apply new skills. When a participant missed a session, the interventionist either went to the family’s home to deliver the content in person or delivered the content via a telephone call. Caregiver sessions were led by 2 facilitators. Follow-up services/support was available for 2 hours per week throughout the first year of middle school (up to 40 sessions).; Adolescent intervention 6 group sessions on skill-building to prepare for the middle school transition by increasing their social skills for establishing and maintaining positive relationships with peers, increasing their self-confidence, and decreasing their receptivity to initiation from deviant peers. Each session typically included an introduction to the session topic, role plays, and a game or activity during which girls practiced the new skill. In addition, the girls engaged in overt discussions about self-image and the personal characteristics and behaviors (e.g., being a good friend, getting good grades, and abstaining from substance use) they wished to project as they entered middle school.; During the final summer session, each girl proclaimed and solidified her goals and commitments in a small ceremony. The ceremony included members of the girl’s session group and their foster parents; it was designed to help the girls build confidence in who they are and who they want to become and to build supportive ties between the girls and their foster parents by “publicizing” their goals and commitments. Girls sessions were led by 1 facilitator and 3 assistants to allow for more individualized attention, one-on-one modeling/practicing of new skills, and frequent reinforcement of positive behaviors. During the school year each girl had individual weekly coaching sessions delivered by female college grads serving as role models. These sessions continued to focus on establishing and maintaining positive peer relations, increasing knowledge of accurate norms for problem behaviors, and increasing self-competence in academic and social areas. Coaches also emphasized the risks of substance use and discussed issues around dating and partner relations. | 43 wks; 46; sessions 5160 min | NR; Individual (in-person), Group (in-person); Research staff NOS,Lay provider | Usual care | Received the usual services provided by the child welfare system, including services such as referrals to individual or family therapy, parenting classes for biological parents, and case monitoring. Child Welfare caseworkers managed each case and were responsible for making all decisions on referrals to community resources, including individual and family therapy and parenting classes.
Knight, 2019^72^ | IG1 | Youth | Patient self-administered a tablet-based screening questionnaire that assessed the number of days of alcohol, cannabis, and other drug use in the past 12 months and the 6 CRAFFT questions. The tablet then immediately displayed to patients their CRAFFT score and level of risk, followed by 10 interactive pages of scientific information and true-life vignettes illustrating the health risks of substance use. This took on average 4 minutes to complete in a private location before the visit. Practitioners then logged into the tablet to see the patient’s screen results, risk level, talking points designed to prompt a 2- to 5-minute conversation using motivational interviewing strategies, and the recommended follow-up plan. Practitioners gave a printed Contract for Life to all patients (and parents or guardians, if present) as a prevention strategy for high- and low-risk patients. The Contract for Life asks youths to agree never to drive after substance use or accept a ride from a substance-impaired driver and instead to call a parent, guardian, or other trusted adult for a safe ride home. Parents or guardians agree to provide safe and sober transportation home and postpone discussion until the following day. Practitioners instructed patients to discuss the Contract for Life with their parent(s) or guardian(s) and to follow up if additional discussion was needed. Practitioners also gave all patients a flyer for a 20-minute family-centered online educational program, Teen-Safe, on preventing adolescent substance use. | 0.14 wks; 1; sessions 15 min | Primary care; Individual (in-person); PCP | Usual care | Patients in the UC group self-administered the computer screening but did not receive any other intervention components.
Lee, 2010^100^ | IG1 | Youth | Individualized personalized feedback based on the baseline survey. The individual PFI intervention is based on the MI approach described by Miller and Rollnick and the brief PFI approach pioneered by Marlatt and colleagues for alcohol prevention. The approach was also informed by recent work by Walker and colleagues regarding PFI for adolescent marijuana smokers and studies of computerized normative feedback for alcohol prevention. The feedback was primarily text based, but incorporated pictures to enhance interest and appeal as well as figures/graphs representing normative information and comparisons. Participants were presented with feedback about their marijuana use (e.g., frequency and quantity of use), perceived and actual descriptive norms for marijuana use (e.g., how frequently they believe the typical student uses marijuana), and perceived pros and cons of using marijuana. Self-reported negative consequences were included in the feedback, as well as ways in which reducing or eliminating marijuana use might be associated with reduced social and academic harm and participants own cost-benefit scale for use. Finally, skills training tips for avoiding marijuana and making changes in one’s use were provided, as well as limited alcohol feedback. Perceived high-risk contexts and alternative activities around campus and in the community were provided. | 0.14 wks; 1; sessions 30 min | Home; Computer-based; Self-Admin | Assessment only | No feedback or information. Asked to complete assessments.
Malmberg, 2014^102^ | IG1 | Youth | E-learning module about alcohol (4 lessons) between April and July 2009; tobacco (3 lessons) between April and July 2010; and marijuana (3 lessons) between April and July 2011. Lessons based on ASE model. The lessons consist of small films, animations and several types of interactive tasks. Also, adolescents are able to discuss relevant topics or to exchange their opinions through chatrooms and forums. | 156 wks; 3; sessions 90 min | School; Computer-based; Self-Admin | Usual care | Control schools agreed not to start any substance-related interventions in target group during study period, but could continue with already established programs.
Mason, 2015^103^ | IG1 | Youth | Adolescents assigned to the intervention condition received a 20-minute intervention referred to as Peer Network Counseling. The intervention is guided by five key MI clinical issues: rapport, acceptance, collaboration, reflections, and non-confrontation. The intervention follows Motivational Enhancement procedures with age-matched substance use normative data presented as feedback. The intervention is structured into four component parts each lasting for 5 minutes: (a) rapport building and laptop presentation of substance use feedback in simple graphic form, (b) discussion of substance use likes/dislikes and discrepancies between current use and future goals and values, (c) introduction of peer network information and graphical feedback, and (d) summary, change talk, and plans.; The peer network component begins by introducing the concept of peer network and its influence on health using the laptop to illustrate this concept. Next, the teen’s peer network is reviewed for risks and protection. Peer networks are reviewed for support, prosocial activities, and encouragement for healthful behavior as well as for substance use, influence/offers to use substances, and risky/dangerous activities. Adolescents are shown the composition of their peer network in graphic form, such as a bar graph representing levels of risk and protection for each their closest three peers. Teens are encouraged to reflect on their network and to consider making small modifications, such as adjusting the amount of time spent with particular peers as well as time spent at particular locations, in order to support participants’ willingness for peer network adjustment | 0.14 wks; 1; sessions 20 min | NR; Individual (in-person); Educator or Counselor NOS | Attention control | Adolescents reviewed an informational handout with the therapist, which covered several topics related to health behaviors such as exercise, nutrition/weight management, and life skills. These sessions lasted 20 minutes, matching the experimental condition in length.
Rhee, 2008^105^ | IG1 | Youth | After baseline data collection, a family nurse practitioner, conducted a 10- minute brief counseling session guided by the Risk Behavior Facts Sheet with information about the harmful effect of risk behaviors within the context of asthma and its treatment. Then participants completed a 1-hour CD-ROM intervention that included decision-making and risk behavior prevention modules via a laptop computer. The decision-making module discussed the basic principles of the decision-making model as the basis for understanding the consequences of poor decision making. At the 2-month contact, the decision-making module CD-ROM was mailed to the intervention group along with a workbook to provide reinforcement and an opportunity to apply the information in real-life situations and required approximately 1.5 hours to complete. The intervention group was mailed another intervention booster on risk behavior prevention by interactive CD-ROM at 4 months which required 30 minutes to complete. NPs called intervention participants to ask about the content of the CD-ROM to determine adherence. Further encouragement, guidance and follow-ups were provided to those of suspected noncompliance. | 17 wks; 3; sessions 190 min | Other Medical, Home; Individual (phone), Computer-based; Nurse, Self-Admin | Minimal | Received a sham CD-ROM program about study skills which ran for a comparable time duration to the intervention program
Sanci, 2015^106^ | IG1 | Youth, Practitioner | Provider screened for risky behaviors (tobacco use, alcohol use, drug use, risky sex, road safety) and discussed protective health behaviors using the HEADSS framework.; From supplemental material: Workshops covered 3 topics of 3 hours each: youth-friendly care; screening for and discussing health risks using the HEADSS framework; and providing a response to detected risky behaviours with a brief intervention based on motivational interviewing principles, including health promotion advice. Adolescent actors allowed clinicians to practice new skills by role play and provided feedback and coaching in youth-friendly communication skill. Two to three hours of interactive training in youth-friendly care was also provided to practice support staff (PSS: receptionists and practice managers). Training was delivered to each practice by an expert in adolescent primary care either at the practice or a local venue. During workshops, clinicians were introduced to the study screening tool designed to prompt them to raise and discuss health risk behaviours and also protective factors and strengths with their patients.; After the workshops, two practice visits were conducted two weeks apart. Using the plan-do-study-act (PDSA) cycle of continuous quality improvement, practices were assisted with integrating screening into office and clinical procedures. The RA also assisted with updating practice referral lists with local youth specialist services, and provided posters and pamphlets addressing youth-friendly care (e.g. confidentiality) and health risk behaviours (e.g. road safety). Data collected from the profile exit interviews were presented to participating clinicians and PSS to help them identify aspects of care that could be improved. These data included patients’ risk profile, whether clinicians discussed health behaviours during the consultation, and the young person’s satisfaction, trust, and likelihood to return to the practice. | NR wks; 1; sessions 15 min | Primary Care; Individual (in-person); Nurse, PCP | Assessment only | 3-hour clinician seminar on youth-friendly care, including recommendations to discuss health risks with young people.
Schinke, 2009a^107^ | IG1 | Youth, Parent | Guided by family interaction theory, the intervention program aimed to reduce girls’ substance use through mother-daughter interactions. The program helped mothers learn to better communicate with their daughters, monitor their daughters’ behavior and activities, build their daughters’ self-image and self-esteem, establish rules about and consequences for substance use, create family rituals, and refrain from communicating unrealistic expectations. In the program, girls acquired skills for managing stress, conflict, and mood, for refusing peer pressure, and for enhancing body esteem and self-efficacy.; Working together in their homes and at times convenient to them, mother-daughter dyads interacted with the program’s nine sessions. Though participants were advised to complete one session per week, completion time varied somewhat. On average, participants required roughly 45 minutes to complete each intervention session. Session content was delivered by voice-over narration, skills demonstrations, and interactive exercises for mothers and daughters to complete jointly. | 9 wks; 9; sessions 405 min | Home; Computer-based; Self-Admin | Assessment only | No intervention
Schinke, 2009b^108^ | IG1 | Youth, Parent | Computer intervention with sessions focused on building daughters’ self-image and self-esteem, establish rules about and consequences for substance use, create family rituals, and refrain from placing unrealistic expectations on their daughters. Mothers learned to better communicate with their daughters, and monitor their daughters’ activities. Girls learned to manage stress, conflict, and mood; refuse peer pressure; enhance body esteem and self-efficacy; and accurately assess prevalence of cigarette, alcohol, and drug use among their age-mates. | 104 wks; 11; sessions 495 min | Home; Computer-based; Self-Admin | Assessment only
Schwinn, 2010^110^ | IG1 | Youth | RealTeen program; comprised of two components: the homepage and 12 intervention sessions. The homepage features, available for access anytime, included news feeds, horoscopes, beauty tips, quotes of the day, fortunes, and access to their blog, pen pal, and the chat forum girls used optionally as a response to intervention session questions. The sessions incorporated not only general personal and social skills (self-efficacy, communication, asserting one’s self), but also skills specific to dealing with drug use opportunities. Girls sequentially completed nine theory-based sessions on: goal setting, decision making, coping (particularly with stress, puberty, and bodily changes), self-esteem, assertion, communication, media influences, peer pressure, and drug facts. The first session served as an introduction; the final two sessions reviewed material and provided additional quizzes. Across sessions, an older female animated character guided girls through the content and practice exercises. | 4 wks; 12; sessions 300 min | Home; Computer-based; Self-Admin | Assessment only | Girls in the control group completed measures at designated intervals but did not receive the gender-specific drug abuse prevention program.
Schwinn, 2015^112^ | IG1 | Youth | The three-session intervention was guided by a social competency skill-building strategy and minority stress theory. An animated young adult narrator led youths through the tailored content and practice scenarios that included interactive games, role-playing, and writing activities. Session 1 focused on skills for identifying and managing stress; session 2 provided a five-step guide for making decisions; and session 3 addressed drug use rates and refusal skills. | 4 wks; 3; sessions 42 min | Home; Computer-based; Self-Admin | Assessment only | None
Schwinn, 2018^111^ | IG1 | Youth | RealTeen; Intervention sessions were held within the online program RealTeen, and focused on goal setting, decision making, puberty, body image, coping, drug knowledge, refusal skills (two sessions), and a review. Sessions were delivered sequentially and guided by an animated female narrator. Frequently, girls were also asked to generate a brief, written response to session content (i.e., a short- and long-term goal, feelings elicited from an ad for cigarettes, reframing a negative thought). Once responses were entered online, girls had the option to keep their responses private or to make them public. Private responses were stored in a girl’s online journal. Public responses, posted to the social feed, were accessible to all girls in the intervention condition. For Each session reinforced how to help girls make healthier decisions around drug use, and all sessions were structured similarly by being a skills-based lesson, followed by interactive exercises to enhance skills acquisition, and ending with a review and short quiz. Subsequent sessions were available 1 week after girls completed the previous session. | 14 wks; 9; sessions 165 min | Home; Computer-based; Self-Admin | Assessment only | Completed posttest measures 14 weeks after pretest date, and completed 1-year follow-up measures 12 months after posttest completion date
Walkup, 2009^113^ | IG1 | Youth | The curricular content for the Family Spirit intervention was based on recommendations and standards documented in the American Academy of Pediatrics’ Caring for Your Baby and Child: Birth to Age 5. The curriculum includes developmentally timed prenatal and infant-care parenting lessons, as well as family planning, substance abuse prevention, and problem solving and coping-skills lessons. Mothers were expected to receive 25 home visits, each lasting approximately 1 hour. The Family Spirit curriculum was carefully crafted to reflect local native practices but not community-specific traditions or spiritual beliefs. Tribal stakeholders emphasized that there is a broad spectrum of cultural beliefs and practices within and across tribal sites and supported that the Family Spirit curriculum address the shared needs of all of the participants. In addition, the interventionists were trained to interact in ways that respected the participants’ cultural orientation and living situation. For example, some participants preferred to do the lesson in their native language, whereas others preferred English. Some participants expressed interest in traditional ceremonies and practices covered in the curriculum, whereas others preferred more Western approaches. Intervention was delivered by trained Native paraprofessionals. | 38 wks; 25; sessions 1500 min | Home; Individual (in-person); Lay provider | Attention control | The control group’s curricular content included a previously developed breast-feeding/nutrition education program. Mothers were to receive 23 home visits, each lasting approximately 1 hour. The control condition was selected to provide participants a valuable home-visiting experience and hold constant the amount of supportive contact for mothers, so between-group differences could be linked to intervention content.
Walton, 2013^114^ | IG1 | Youth | The BIs incorporated MI, including tailored, parallel content: 1) goals/values; 2) feedback for cannabis, alcohol and other drug use, including consequences and DUI; 3) decisional balance exercise about cannabis; 4) tricky situations (e.g., role plays) including refusal skills for cannabis and other drug use, safe ways to get home/prevent driving high/drunk, dealing with peer pressure for delinquency (e.g., stealing a car/joy riding), coping with negative affect such as boredom, anger or sadness, and consequences (i.e., problem identification, getting help); and 5) the control brochure.; Research therapists who were trained in MI conducted the TBI, which was facilitated by a computer which displayed screens to prompt content. The therapist used an elicit-provide-elicit framework when reviewing tailored feedback, using summaries and open-ended questions to evoke change talk. For example, for those who did not want to stop using, therapists focused on reducing use and avoiding consequences. During role plays, therapists elicited tools to reduce use and avoid consequences. | 0.14 wks; 1; sessions 38 min | Primary Care; Individual (in-person); Educator or Counselor NOS | Minimal | Participants in the control were handed a tri-fold brochure containing warning signs of cannabis problems, resources (substance use treatment, suicide hotlines, employment services, leisure activities), and cannabis information websites. This “enhanced usual care” control (clinics did not routinely provide this information) was chosen for ethical reasons.
Walton, 2013^114^ | IG2 | Youth | The BIs incorporated MI, including tailored, parallel content: 1) goals/values; 2) feedback for cannabis, alcohol and other drug use, including consequences and DUI; 3) decisional balance exercise about cannabis; 4) tricky situations (e.g., role plays) including refusal skills for cannabis and other drug use, safe ways to get home/prevent driving high/drunk, dealing with peer pressure for delinquency (e.g., stealing a car/joy riding), coping with negative affect such as boredom, anger or sadness, and consequences (i.e., problem identification, getting help); and 5) the control brochure.; The CBI was a stand-alone interactive animated program, with touch screens. Research staff started the CBI, handed the tablet to participants, and showed them how to adjust the audio. A selected virtual buddy guided participants through the program and provided audio feedback (via headphones). For example, during the decisional balance exercise, the participant selected reasons to stay away from cannabis and the buddy provided affirmations and summaries. During the role-plays, participants watched animated situations and then were asked to make a behavioral choice. If a participant chose a negative option (e.g., smoking cannabis), they were asked to consider the consequences in relation to their goals. Once a positive choice was made, the animation resumed, modeling this selection. The tailored role-plays included six characters and showed the progression in medical, social, and legal consequences for characters that did and did not use cannabis over time. At the end, the computer instructed participants to return the tablet to staff. | 0.14 wks; 1; sessions 33 min | Primary Care; Computer-based; Self-Admin | Minimal | Participants in the control were handed a tri-fold brochure containing warning signs of cannabis problems, resources (substance use treatment, suicide hotlines, employment services, leisure activities), and cannabis information websites. This “enhanced usual care” control (clinics did not routinely provide this information) was chosen for ethical reasons.
Walton, 2014^115^ | IG1 | Youth | BIs were conducted in a private room and could be paused to allow for medical care. The BIs integrated motivational interviewing (MI) spirit and techniques, emphasizing personal responsibility, supporting self efficacy, eliciting commitment talk for avoiding cannabis use and change talk for reducing alcohol, other drugs and delinquency. The BIs also included normative resetting and role-play scenarios. Cultural relevance to address the study population (∼50% African American) was incorporated into the content based on feedback from focus testing, including providing diversity in language (key messages, scripts for CBI), item-listed checkboxes (e.g. goals, reasons to avoid using) and scenario topics.; Therapists were trained in MI, including the use of rulers to increase self-efficacy and commitment talk for abstinence/reduction of other risk behaviors (average length = 38 minutes, standard deviation = 14). A computer displayed tailored feedback and prompt content. Fidelity was monitored by audio-taping and providing feedback via regular individual and group supervision.; Also given a brochure containing warning signs of problems with cannabis and community resources (e.g. substance use, mental health and leisure activities). | 0.14 wks; 1; sessions 38 min | Primary Care; Individual (in-person); Educator or Counselor NOS | Minimal | Participants were given a brochure containing warning signs of problems with cannabis and community resources (e.g. substance use, mental health and leisure activities).
| IG2 | Youth | BIs were conducted in a private room and could be paused to allow for medical care. The BIs integrated motivational interviewing (MI) spirit and techniques, emphasizing personal responsibility, supporting self efficacy, eliciting commitment talk for avoiding cannabis use and change talk for reducing alcohol, other drugs and delinquency. The BIs also included normative resetting and role-play scenarios. Cultural relevance to address the study population (∼50% African American) was incorporated into the content based on feedback from focus testing, including providing diversity in language (key messages, scripts for CBI), item-listed checkboxes (e.g. goals, reasons to avoid using) and scenario topics.; Using touch-screens and headphones for audio, the CBI was an animated, interactive program (average length = 33 minutes, standard deviation = 13) delivered by a virtual therapist, who provided affirmations and summaries. Guided by a buddy chosen by participants, the role-play scenarios showed characters in risky situations, with progression over time in various consequences, eliciting participant interaction and role-modeling positive choices.; Also given a brochure containing warning signs of problems with cannabis and community resources (e.g. substance use, mental health and leisure activities). | 0.14 wks; 1; sessions 33 min | Primary Care; Computer-based; Self-Admin | Minimal | Given a brochure containing warning signs of problems with cannabis and community resources (e.g. substance use, mental health and leisure activities).

Abbreviations: BI = Brief Intervention; CBI = Computer brief intervention; CG = Control group; IG = Intervention group; IHS = Indian Health Service; MDCPS = Miami-Dade County Public School; MI = Motivational interviewing; NOS = Not otherwise specified; NR = Not reported; PCP = Primary care physician; PFI = Individual personalized feedback; PHAT = Promoting Health Among Teens.

Appendix D Table 4 Health, Social, and Legal Outcomes (KQ1)

Outcome | Author year | Outcome description; range (direction of better outcome) | Recall period | Group | FU, mo | IG n/n (%) or Mean (SD), n | CG n/n (%) or Mean (SD), n | Effect | p^*^
Depression symptoms | Barlow, 2006^835^ | 20-item self-report scored on a 4-point scale with a possible score from 0-60; 0-60 (Low) | NR | IG1 (Overall) | 5 | 11.6 (10), 19^†^ | 15.2 (8), 22^†^ | MeanDiff: −3.10 (−8.80 to 2.50)^†^ | 0.27
Depression symptoms | Barlow, 2006^835^ | 20-item self-report scored on a 4-point scale with a possible score from 0-60; 0-60 (Low) | NR | IG1 (Overall) | 9 | 8.4 (10), 19^†^ | 14.2 (11), 22^†^ | MeanDiff: −6.10 (−13.00 to 0.85)^†^ | 0.08
Depression symptoms | Barlow, 2013^83^ | CES-D score; 0-60 (Low) | 1 week | IG1 (Overall) | 4 | -.3 (.), 159 | 0 (.), 163 | MeanDiff: −0.34 (−1.19 to 0.51) | 0.44
Depression symptoms | Barlow, 2013^83^ | CES-D score; 0-60 (Low) | 1 week | IG1 (Overall) | 8 | -.9 (.), 159 | 0 (.), 163 | MeanDiff: −0.95 (−2.09 to 0.19) | 0.10
Depression symptoms | Barlow, 2013^83^ | CES-D score; 0-60 (Low) | 1 week | IG1 (Overall) | 14 | −1.8 (.), 159 | 0 (.), 163 | MeanDiff: −1.89 (−3.80 to 0.06) | 0.06
Depression symptoms | Barlow, 2013^83^ | CES-D score; 0-60 (Low) | 1 week | IG1 (Overall) | 38 | -.9 (.), 159 | .3 (.), 163 | MeanDiff: −1.17 (−2.05 to −0.28) | 0.01
Depression symptoms | Fang, 2010^92^ | Depression; 0-2 (Low) | 2 weeks | IG1 (Overall) | 6 | -.1 (.8), 54 | 0 (.7), 50 | CalcMeanDiffChg: −0.12 (−0.40 to 0.16) | 0.045
Depression symptoms | Fang, 2010^92^ | Depression; 0-2 (Low) | 2 weeks | IG1 (Overall) | 12 | -.1 (.8), 54 | .1 (.7), 50 | CalcMeanDiffChg: −0.18 (−0.46 to 0.10) | 0.315
Depression symptoms | Fang, 2010^92^ | Depression; 0-2 (Low) | 2 weeks | IG1 (Overall) | 24 | -.1 (.9), 50 | 0 (.6), 43 | CalcMeanDiffChg: −0.14 (−0.44 to 0.16) | 0.315
Depression symptoms | Schinke, 2009a^107^ | 1-5 (Low) | NA | IG1 (Overall) | 12 | -.1 (.8), 205 | .1 (.8), 327 | TxtEffectEst: −0.18 (−0.32 to −0.04) | NR, NS
Depression symptoms | Schinke, 2009b^108^ | Adolescent-reported depression; 1-5 (Low) | 2 weeks | IG1 (Overall) | 12 | 0 (.8), 434 | 0 (.8), 430 | CalcMeanDiffChg: 0.01 (−0.09 to 0.11) | NR, NS
Depression symptoms | Schinke, 2009b^108^ | Adolescent-reported depression; 1-5 (Low) | 2 weeks | IG1 (Overall) | 24 | .1 (.8), 415 | 0 (.8), 413 | CalcMeanDiffChg: 0.11 (0.00 to 0.22) | NR, NS
Depression symptoms | Schwinn, 2018^111^ | 5-point Likert-scaled items that asks girls to rate the extent to which they were bothered (not at all = 0, All the time = 4) by various symptoms in the past month.; 0-20 (Low) | 1 month | IG1 (Overall) | 3 | 1.8 (1), 376^†^ | 1.9 (1), 380^†^ | Bweight: −0.10 (−0.22 to 0.02)^†^ | 0.109
Depression symptoms | Schwinn, 2018^111^ | 5-point Likert-scaled items that asks girls to rate the extent to which they were bothered (not at all = 0, All the time = 4) by various symptoms in the past month.; 0-20 (Low) | 1 month | IG1 (Overall) | 15 | 1.8 (1), 370^†^ | 1.9 (1), 382^†^ | Bweight: −0.14 (−0.28 to 0.00)^†^ | 0.051
Depression symptoms | Walkup, 2009^113^ | 0-60 (Low) | NR | IG1 (Overall) | 5 | -2 (11.8), 54^†^ | −3.3 (10.7), 71^†^ | Beta: 0.05 (−3.99 to 4.09)^†^ | NR, NS
Depression symptoms | Walkup, 2009^113^ | 0-60 (Low) | NR | IG1 (Overall) | 9 | -4 (12.2), 47^†^ | -4 (10.7), 68^†^ | Beta: −0.58 (−4.71 to 3.55)^†^ | NR, NS
Anxiety symptoms | Schwinn, 2018^111^ | 5-point Likert-scaled items that asks girls to rate the extent to which they were bothered (not at all = 0, All the time = 4) by various symptoms in the past month.; 0-20 (Low) | 1 month | IG1 (Overall) | 3 | 1.5 (1), 376^†^ | 1.6 (1), 380^†^ | Bweight: −0.06 (−0.20 to 0.08)^†^ | 0.436
Anxiety symptoms | Schwinn, 2018^111^ | 5-point Likert-scaled items that asks girls to rate the extent to which they were bothered (not at all = 0, All the time = 4) by various symptoms in the past month.; 0-20 (Low) | 1 month | IG1 (Overall) | 15 | 1.6 (1), 370^†^ | 1.7 (1), 382^†^ | Bweight: −0.08 (−0.24 to 0.08)^†^ | 0.288
Other symptoms | Baldus, 2016^81^ | Parent-reported problem behavior (SDQ subscale); NR (Low) | NR | IG1 (Overall) | 8 | -.4 (2.5), 147 | -.3 (2.1), 145 | MeanDiffinChange: 0.08 (−0.30 to 0.46) | 0.550
Other symptoms | Baldus, 2016^81^ | Parent-reported problem behavior (SDQ subscale); NR (Low) | NR | IG1 (Overall) | 20 | -.4 (2.2), 147 | -.3 (2.8), 145 | MeanDiffinChange: 0.17 (−0.21 to 0.57) | 0.412
Other symptoms | Baldus, 2016^81^ | Self-reported problem behavior (RAASI); NR (Low) | NR | IG1 (Overall) | 8 | .3 (3.7), 147 | .4 (3.9), 145 | MeanDiffinChange: 0.05 (−0.61 to 0.71) | 0.748
Other symptoms | Baldus, 2016^81^ | Self-reported problem behavior (RAASI); NR (Low) | NR | IG1 (Overall) | 20 | .5 (4.4), 147 | .7 (4.9), 145 | MeanDiffinChange: 0.23 (−0.43 to 0.89) | 0.503
Other symptoms | Bannink, 2014^82^ | Total difficulties score (SDQ); 0-40 (Low) | NR | IG1 (Overall) | 4 | −1.3 (5.1), 430 | -.8 (5.4), 434 | Beta: −0.60 (−1.17 to −0.04) | 0.04
Other symptoms | Bannink, 2014^82^ | Total difficulties score (SDQ); 0-40 (Low) | NR | IG2 (Overall) | 4 | −1.1 (5.4), 392 | -.8 (5.4), 434 | Beta: −0.24 (−0.78 to 0.29) | 0.37
Other symptoms | Bannink, 2014^82^ | Total emotional and behavior problems, youth report (Achenbach system); 0-210 (Low) | NR | IG1 (Overall) | 4 | 31.6 (22.6), 430^†^ | 34.8 (25.3), 434^†^ | Beta: −2.74 (−5.92 to 0.44)^†^ | 0.09
Other symptoms | Bannink, 2014^82^ | Total emotional and behavior problems, youth report (Achenbach system); 0-210 (Low) | NR | IG2 (Overall) | 4 | 33.9 (23), 392^†^ | 34.8 (25.3), 434^†^ | Beta: −0.89 (−4.18 to 2.40)^†^ | 0.60
Other symptoms | Barlow, 2013^83^ | Externalizing T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 8 | −1.9 (.), 159 | -.7 (.), 163 | MeanDiff: −1.37 (−3.12 to 0.39) | 0.13
Other symptoms | Barlow, 2013^83^ | Externalizing T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 14 | −3.8 (.), 159 | −1.5 (.), 163 | MeanDiff: −2.50 (−4.89 to −0.12) | 0.04
Other symptoms | Barlow, 2013^83^ | Externalizing T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 38 | -.6 (.), 159 | .4 (.), 163 | MeanDiff: −1.23 (−2.45 to −0.02) | <0.05
Other symptoms | Barlow, 2013^83^ | Internalizing T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 8 | −2.3 (.), 159 | −1.1 (.), 163 | MeanDiff: −1.32 (−3.17 to 0.53) | 0.16
Other symptoms | Barlow, 2013^83^ | Internalizing T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 14 | −4.7 (.), 159 | −2.3 (.), 163 | MeanDiff: −2.51 (−5.12 to 0.09) | 0.06
Other symptoms | Barlow, 2013^83^ | Internalizing T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 38 | −3.2 (.), 159 | −2.5 (.), 163 | MeanDiff: −0.83 (−2.17 to 0.50) | 0.23
Other symptoms | Barlow, 2013^83^ | Mental Health score (POSIT); NR (Low) | NR | IG1 (Overall) | 4 | -.1 (.), 159 | -.1 (.), 163 | MeanDiff: −0.33 (−0.77 to 0.11) | 0.14
Other symptoms | Barlow, 2013^83^ | Mental Health score (POSIT); NR (Low) | NR | IG1 (Overall) | 8 | -.3 (.), 159 | -.4 (.), 163 | MeanDiff: −0.25 (−0.73 to 0.23) | 0.30
Other symptoms | Barlow, 2013^83^ | Mental Health score (POSIT); NR (Low) | NR | IG1 (Overall) | 14 | -.5 (.), 159 | -.8 (.), 163 | MeanDiff: −0.14 (0.81 to 0.54) | 0.70
Other symptoms | Barlow, 2013^83^ | Total emotional and behavior problems T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 8 | −2.3 (.), 159 | −1.3 (.), 163 | MeanDiff: −1.38 (−3.22 to 0.45) | 0.14
Other symptoms | Barlow, 2013^83^ | Total emotional and behavior problems T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 14 | −4.5 (.), 159 | −2.6 (.), 163 | MeanDiff: −2.36 (−4.90 to 0.19) | 0.07
Other symptoms | Barlow, 2013^83^ | Total emotional and behavior problems T-score (Achenbach system); 0-100 (Low) | NR | IG1 (Overall) | 38 | -2 (.), 159 | −1.6 (.), 163 | MeanDiff: −0.86 (−2.10 to 0.39) | 0.18
Other symptoms | Foxcroft, 2017^93^ | Externalizing behaviors (SDQ subscale); 0-10 (Low) | NR | IG1 (Overall) | 12 | . (.), 233 | . (.), 194 | Mean Ratio: −0.10 (−0.23 to 0.03) | NR, NS
Other symptoms | Foxcroft, 2017^93^ | Externalizing behaviors (SDQ subscale); 0-10 (Low) | NR | IG1 (Overall) | 24 | . (.), 174 | . (.), 154 | Mean Ratio: −0.06 (−0.23 to 0.11) | NR, NS
Other symptoms | Jalling, 2016^95^ | Externalizing score, youth report (Achenbach system); 0-64 (Low) | 6 months | IG1 (Overall) | 6 | -.7 (10), 70 | -.1 (9.6), 81 | CalcMeanDiffChg: −0.56 (−3.70 to 2.58) | NR, NS
Other symptoms | Jalling, 2016^95^ | Externalizing score, youth report (Achenbach system); 0-64 (Low) | 6 months | IG2 (Overall) | 6 | 0 (10.9), 86 | -.1 (9.6), 81 | CalcMeanDiffChg: 0.18 (−2.93 to 3.29) | NR, NS
Other symptoms | Jalling, 2016^95^ | Internalizing + Externalizing, youth report (Achenbach system); NR (Low) | 6 months | IG1 (Overall) | 6 | −1.3 (24.9), 70 | -.3 (26.3), 81 | CalcMeanDiffChg: −1.02 (−9.19 to 7.15) | NR, NS
Other symptoms | Jalling, 2016^95^ | Internalizing + Externalizing, youth report (Achenbach system); NR (Low) | 6 months | IG2 (Overall) | 6 | . (.), 86 | -.3 (26.3), 81 | – | NR, NS
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, parent report (Y-OQ total score); -16-240 (Low) | NR | IG1 (Overall) | 6 | −9.5 (31.6), 71 | −9.2 (30.3), 82 | CalcMeanDiffChg: −0.21 (−10.07 to 9.65) | NR, NS
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, parent report (Y-OQ total score); -16-240 (Low) | NR | IG2 | 6 | −12.3 (27.1), 71 | −14.2 (27.4), 82 | CalcMeanDiffChg: 1.99 (−6.66 to 10.64)
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, parent report (Y-OQ total score); -16-240 (Low) | NR | IG2 (Overall) | 6 | −10.5 (29.5), 88 | −9.2 (30.3), 82 | CalcMeanDiffChg: −1.26 (−10.26 to 7.74) | NR, NS
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, parent report (Y-OQ total score); -16-240 (Low) | NR | IG2 | 6 | −16.7 (22.4), 88 | −14.2 (27.4), 82 | CalcMeanDiffChg: −2.42 (−9.98 to 5.14)
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, youth report (Y-OQ total score); -16-240 (Low) | NR | IG1 (Overall) | 6 | −3.6 (32.6), 70 | −6.1 (32.3), 81 | CalcMeanDiffChg: 2.45 (−7.93 to 12.83) | NR, NS
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, youth report (Y-OQ total score); -16-240 (Low) | NR | IG1 | 6 | −12.5 (27.3), 70 | −13.4 (29.5), 81 | CalcMeanDiffChg: 0.87 (−8.19 to 9.93)
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, youth report (Y-OQ total score); -16-240 (Low) | NR | IG2 (Overall) | 6 | −4.1 (29.6), 86 | −6.1 (32.3), 81 | CalcMeanDiffChg: 2.01 (−7.40 to 11.42) | NR, NS
Other symptoms | Jalling, 2016^95^ | Psychosocial functioning, youth report (Y-OQ total score); -16-240 (Low) | NR | IG2 | 6 | −9.9 (26.5), 86 | −13.4 (29.5), 81 | CalcMeanDiffChg: 3.48 (−5.05 to 12.01)
Other symptoms | Jalling, 2016^95^ | Total emotional and behavioral problems score (Achenbach system); 0-210 (Low) | 6 months | IG2 (Overall) | 6 | −20.9 (22.8), 88 | −15.7 (24), 82 | CalcMeanDiffChg: −5.24 (−12.29 to 1.81) | NR, NS
Other symptoms | Jalling, 2016^95^ | Total emotional and behavioral problems score (Achenbach system); 0-210 (Low) | 6 months | IG1 (Overall) | 6 | −16.4 (27.1), 71 | −15.7 (24), 82 | CalcMeanDiffChg: −0.68 (−8.84 to 7.48) | NR, NS
Other symptoms | Kim, 2011^98^ | Internalizing + Externalizing, youth report (Achenbach system); NR (Low) | NR | IG1 (Overall) | 24 | 12.8 (8.5), 48^†^ | 12.5 (8.3), 52^†^ | CohensD: 0.27 (−3.03 to 3.57)^†^ | NS
Other symptoms | Sanci, 2015^106^ | Emotional distress in last month | 1 month | IG1 (Overall) | 0 | 121/377 (32.1) | 143/524 (27.4) | OR: 1.26 (0.83 to 1.91) | NSD
Other symptoms | Sanci, 2015^106^ | Emotional distress in last month | 1 month | IG1 (Overall) | 3 | 67/377 (17.9) | 91/524 (17.3) | OR: 1.00 (0.70 to 1.41) | 0.99
Other symptoms | Sanci, 2015^106^ | Emotional distress in last month | 1 month | IG1 (Overall) | 12 | 68/377 (18.1) | 90/524 (17.1) | OR: 1.04 (0.70 to 1.57) | 0.83
Other symptoms | Sanci, 2015^106^ | Fear or abuse in relationships in last 12 months | 1 year | IG1 (17+) | 0 | 69/316 (21.8) | 92/411 (22.4) | OR: 0.97 (0.58 to 1.62) | NSD
Other symptoms | Schwinn, 2018^111^ | Perceived stress; girls rated degree to which their life situations were unpredictable, uncontrollable, and stressful during the past month (Never = 0, All the time = 3); 0-12 (Low) | 1 month | IG1 (Overall) | 3 | 1.5 (.8), 376^†^ | 1.6 (.8), 380^†^ | Bweight: −0.06 (−0.16 to 0.04)^†^ | 0.244
Other symptoms | Schwinn, 2018^111^ | Perceived stress; girls rated degree to which their life situations were unpredictable, uncontrollable, and stressful during the past month (Never = 0, All the time = 3); 0-12 (Low) | 1 month | IG1 (Overall) | 15 | 1.5 (.8), 370^†^ | 1.6 (.8), 382^†^ | Bweight: −0.08 (−0.18 to 0.02)^†^ | 0.111
Other symptoms | Schwinn, 2018^111^ | Self-esteem; Ten, 4-point Likert-scaled items combined to form a self-esteem index with lower scores indicating higher self-esteem; 0-30 (Low) | NR | IG1 (Overall) | 3 | 2.3 (.6), 376^†^ | 2.4 (.6), 380^†^ | Bweight: −0.11 (−0.21 to −0.01)^†^ | 0.013
Other symptoms | Schwinn, 2018^111^ | Self-esteem; Ten, 4-point Likert-scaled items combined to form a self-esteem index with lower scores indicating higher self-esteem; 0-30 (Low) | NR | IG1 (Overall) | 15 | 2.3 (.6), 370^†^ | 2.4 (.6), 382^†^ | Bweight: −0.08 (−0.18 to 0.02)^†^ | 0.074
Global functioning | Bannink, 2014^82^ | Health-related QOL (CHQ-CF-GH4 score); 0-100 (High) | NR | IG1 (Overall) | 4 | 2.4 (18.5), 430 | .1 (18), 434 | Beta: 1.03 (−1.12 to 3.19) | 0.35
Global functioning | Bannink, 2014^82^ | Health-related QOL (CHQ-CF-GH4 score); 0-100 (High) | NR | IG2 (Overall) | 4 | 3.9 (17.3), 392 | .1 (18), 434 | Beta: 2.79 (0.72 to 4.87) | 0.008
Family cohesion - adolescent report | Schinke, 2009a^107^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 12 | .1 (1.1), 205 | -.2 (1.2), 327 | TxtEffectEst: 0.32 (0.13 to 0.51) | <0.01
Family cohesion - adolescent report | Schinke, 2009a^107^ | Parental monitoring; 1-5 (High) | NA | IG1 (Overall) | 12 | .1 (.8), 205 | -.2 (.9), 327 | TxtEffectEst: 0.30 (0.16 to 0.44) | <0.05
Family cohesion - adolescent report | Schinke, 2009b^108^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 12 | .4 (2.4), 434 | -.2 (2.2), 430 | CalcMeanDiffChg: 0.62 (0.32 to 0.92) | <0.004
Family cohesion - adolescent report | Schinke, 2009b^108^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 24 | 0 (2.4), 415 | -.2 (2.2), 413 | CalcMeanDiffChg: 0.25 (−0.06 to 0.56) | <0.004
Family cohesion - adolescent report | Schinke, 2009b^108^ | Mother-daughter closeness; 1-5 (High) | NA | IG1 (Overall) | 12 | -.7 (1.4), 434 | -1 (1.4), 430 | CalcMeanDiffChg: 0.34 (0.15 to 0.53) | <0.002
Family cohesion - adolescent report | Schinke, 2009b^108^ | Mother-daughter closeness; 1-5 (High) | NA | IG1 (Overall) | 24 | -.8 (1.4), 415 | −1.1 (1.4), 413 | CalcMeanDiffChg: 0.37 (0.18 to 0.56) | <0.002
Family cohesion - adolescent report | Schinke, 2009b^108^ | Parental monitoring (“I tell my mom what I plan to do with my friends.”); 1-5 (High) | NA | IG1 (Overall) | 12 | .1 (.8), 434 | -.1 (.9), 430 | CalcMeanDiffChg: 0.22 (0.11 to 0.33) | <0.0001
Family cohesion - adolescent report | Schinke, 2009b^108^ | Parental monitoring (“I tell my mom what I plan to do with my friends.”); 1-5 (High) | NA | IG1 (Overall) | 24 | 0 (.8), 415 | -.2 (.9), 413 | CalcMeanDiffChg: 0.29 (0.17 to 0.41) | <0.0001
Family cohesion - parent report | Estrada, 2018^90^ | Communication, parent-adolescent (Barnes and Olson, 1985); “I can discuss my beliefs with my child without feeling restrained or embarrassed.”; scale 1 (Strongly disagree) to 5 (Strongly agree); 1-5 (High) | NA | IG1 (Overall) | 3 | . (.), 84 | . (.), 101 | Beta: 1.65 (−0.45 to 3.84) | 0.12
Family cohesion - parent report | Estrada, 2018^90^ | Parental monitoring of peers (Pantin 1996); “How well do you personally know your child’s friends?”; scale 1 (Not at all) to 5 (Extremely well); 1-5 (High) | NA | IG1 (Overall) | 3 | . (.), 84 | . (.), 101 | Beta: 0.85 (−0.09 to 1.81) | 0.07
Family cohesion - parent report | Estrada, 2018^90^ | Positive parenting (Tolan et al., 1997); When your child has done something that you like or approve of, do you say something nice about it; praise or give approval?"; scale 0 (Never) to 4 (Always); 0-4 (High) | NA | IG1 (Overall) | 3 | . (.), 84 | . (.), 101 | Beta: 0.13 (−0.94 to 1.22) | 0.80
Family cohesion - parent report | Foxcroft, 2017^93^ | Communication, aggressive and hostile behavior and in interactions; 0-5 (Low) | NR | IG1 (Overall) | 12 | . (.), 233 | . (.), 194 | Mean Ratio: 0.02 (−0.06 to 0.11) | NR, NS
Family cohesion - parent report | Foxcroft, 2017^93^ | Communication, aggressive and hostile behavior and in interactions; 0-5 (Low) | NR | IG1 (Overall) | 24 | . (.), 174 | . (.), 154 | Mean Ratio: 0.01 (−0.07 to 0.10) | NR, NS
Family cohesion - mother report | Fang, 2010^92^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 6 | .2 (2.1), 54 | -.4 (2.1), 50 | CalcMeanDiffChg: 0.55 (−0.25 to 1.35) | 0.03
Family cohesion - mother report | Fang, 2010^92^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 12 | .2 (2), 54 | -.3 (2.1), 50 | CalcMeanDiffChg: 0.52 (−0.28 to 1.32) | 0.049
Family cohesion - mother report | Fang, 2010^92^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 24 | .3 (2), 50 | -.4 (2.2), 43 | CalcMeanDiffChg: 0.63 (−0.23 to 1.49) | 0.049
Family cohesion - mother report | Fang, 2010^92^ | Mother-daughter closeness; 1-5 (High) | NA | IG1 (Overall) | 6 | .4 (1), 54 | -.2 (1.1), 50 | CalcMeanDiffChg: 0.56 (0.15 to 0.97) | 0.0001
Family cohesion - mother report | Fang, 2010^92^ | Mother-daughter closeness; 1-5 (High) | NA | IG1 (Overall) | 12 | .4 (1), 54 | -.2 (1.2), 50 | CalcMeanDiffChg: 0.57 (0.16 to 0.98) | 0.0002
Family cohesion - mother report | Fang, 2010^92^ | Mother-daughter closeness; 1-5 (High) | NA | IG1 (Overall) | 24 | .3 (.9), 50 | -.2 (1.1), 43 | CalcMeanDiffChg: 0.53 (0.12 to 0.94) | 0.0002
Family cohesion - mother report | Fang, 2010^92^ | Parental monitoring; 1-5 (High) | NA | IG1 (Overall) | 6 | .2 (.6), 54 | -.2 (.9), 50 | CalcMeanDiffChg: 0.35 (0.06 to 0.64) | 0.0003
Family cohesion - mother report | Fang, 2010^92^ | Parental monitoring; 1-5 (High) | NA | IG1 (Overall) | 12 | .1 (.6), 54 | -.2 (.9), 50 | CalcMeanDiffChg: 0.33 (0.03 to 0.63) | 0.019
Family cohesion - mother report | Fang, 2010^92^ | Parental monitoring; 1-5 (High) | NA | IG1 (Overall) | 24 | 0 (.7), 50 | -.2 (.9), 43 | CalcMeanDiffChg: 0.25 (−0.08 to 0.58) | 0.019
Family cohesion - mother report | Schinke, 2009a^107^ | Communication; 1-5 (High) | 1 week | IG1 (Overall) | 12 | 0 (1.9), 205 | -.3 (1.9), 327 | TxtEffectEst: 0.33 (0.00 to 0.66) | <0.01
Family cohesion - mother report | Schinke, 2009a^107^ | Parental monitoring; 1-5 (High) | NA | IG1 (Overall) | 12 | -.4 (1), 205 | −1.1 (1.1), 327 | TxtEffectEst: 0.62 (0.44 to 0.80) | <0.0001
Family cohesion - mother report | Schinke, 2009b^108^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 12 | .3 (2.3), 434 | .2 (2.2), 430 | CalcMeanDiffChg: 0.03 (−0.26 to 0.32) | <0.0001
| Schinke, 2009b^108^ | Communication, mother-daughter; 1-5 (High) | 1 week | IG1 (Overall) | 24 | 0 (2.2), 415 | -1 (1.9), 413 | CalcMeanDiffChg: 0.99 (0.71 to 1.27) | <0.0001
| Schinke, 2009b^108^ | Mother-daughter closeness; 1-5 (High) | NA | IG1 (Overall) | 12 | -.2 (1.6), 434 | -.2 (1.6), 430 | CalcMeanDiffChg: 0.09 (−0.12 to 0.30) | <0.0001
| Schinke, 2009b^108^ | Mother-daughter closeness; 1-5 (High) | NA | IG1 (Overall) | 24 | -.4 (1.6), 415 | −2.2 (1.4), 413 | CalcMeanDiffChg: 1.86 (1.66 to 2.06) | <0.0001
| Schinke, 2009b^108^ | Parental monitoring; 1-5 (High) | NA | IG1 (Overall) | 12 | 0 (.6), 434 | -.1 (.7), 430 | CalcMeanDiffChg: 0.04 (−0.04 to 0.12) | <0.0001
| Schinke, 2009b^108^ | Parental monitoring; 1-5 (High) | NA | IG1 (Overall) | 24 | -.1 (.6), 415 | -.7 (1.6), 413 | CalcMeanDiffChg: 0.53 (0.37 to 0.69) | <0.0001
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG1 (Overall) | 4 | – | – | TxtEffectEst: −0.08 (−0.21 to 0.05) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG1 (Overall) | 7 | – | – | TxtEffectEst: 0.07 (−0.05 to 0.20) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG1 (Overall) | 13 | – | – | TxtEffectEst: −0.02 (−0.17 to 0.14) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG1 (Overall) | 19 | – | – | TxtEffectEst: 0.09 (−0.07 to 0.24) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG1 (Overall) | 25 | – | – | TxtEffectEst: −0.08 (−0.19 to 0.03) | 0.069
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG2 (Overall) | 4 | – | – | TxtEffectEst: −0.08 (−0.19 to 0.03) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG2 (Overall) | 7 | – | – | TxtEffectEst: 0.00 (−0.11 to 0.11) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG2 (Overall) | 13 | – | – | TxtEffectEst: −0.06 (−0.21 to 0.08) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG2 (Overall) | 19 | – | – | TxtEffectEst: 0.10 (−0.05 to 0.25) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Official arrest charges | NA | IG2 (Overall) | 25 | – | – | TxtEffectEst: −0.23 (−0.36 to −0.11) | <0.001
Other Delinquent Behavior | Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG1 (Overall) | 4 | – | – | TxtEffectEst: −0.26 (−0.51 to −0.02) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG1 (Overall) | 7 | – | – | TxtEffectEst: 0.26 (0.02 to 0.51) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG1 (Overall) | 13 | – | – | TxtEffectEst: 0.16 (−0.07 to 0.39) | NR, NS
Other Delinquent Behavior | Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG1 (Overall) | 19 | – | – | TxtEffectEst: 0.09 (−0.17 to 0.35) | NR, NS
| Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG2 (Overall) | 4 | – | – | TxtEffectEst: −0.20 (−0.44 to 0.05) | NR, NS
| Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG2 (Overall) | 7 | – | – | TxtEffectEst: 0.03 (−0.23 to 0.29) | NR, NS
| Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG2 (Overall) | 13 | – | – | TxtEffectEst: −0.09 (−0.34 to 0.16) | NR, NS
| Dembo, 2016^88^ | Self-reported delinquency; Range NR (Low) | NA | IG2 (Overall) | 19 | – | – | TxtEffectEst: 0.08 (−0.17 to 0.32) | NR, NS
| Foxcroft, 2017^93^ | Index of aggressive and destructive conduct; 0-4 (Low) | NR | IG1 (Overall) | 12 | . (.), 233 | . (.), 194 | Mean Ratio: 0.00 (−0.09 to 0.09) | NR, NS
| Foxcroft, 2017^93^ | Index of aggressive and destructive conduct; 0-4 (Low) | NR | IG1 (Overall) | 24 | . (.), 174 | . (.), 154 | Mean Ratio: 0.00 (−0.12 to 0.11) | NR, NS
| Jalling, 2016^95^ | Total self-reported delinquency score (SRD); 0-360 (Low) | 6 months | IG1 (Overall) | 6 | 2.3 (36.1), 70 | −2.1 (36.1), 81 | CalcMeanDiffChg: 4.41 (−7.13 to 15.95) | NR, NS
| Jalling, 2016^95^ | SRD, total score; 0-360 (Low) | 6 months | IG2 (Overall) | 6 | 2.2 (50.1), 86 | −2.1 (36.1), 81 | CalcMeanDiffChg: 4.31 (−8.89 to 17.51) | NR, NS
| Kim, 2011^98^ | Self-reported delinquent behavior in past year; NR | 1 year | IG1 (Overall) | 36 | .3 (.9), 48† | .9 (2.7), 52† | CohensD: −0.65 (−1.43 to 0.13)† | 0.098
| Walton, 2014^115^ | Ten items assessing frequency of violent and non-violent delinquency (e.g. physical fighting, stealing, selling drugs) were summed, range 0-10 where lower is better; 0-10 (Low) | 3 months | IG1 (Overall) | 3 | . (.), 199 | . (.), 216 | IRRnegbin: 0.53 (0.36 to 0.79) | <0.01
| Walton, 2014^115^ | Ten items assessing frequency of violent and non-violent delinquency (e.g. physical fighting, stealing, selling drugs) were summed, range 0-10 where lower is better; 0-10 (Low) | 3 months | IG1 (Overall) | 6 | . (.), 200 | . (.), 211 | IRRnegbin: 0.81 (0.51 to 1.30) | NR, NS
| Walton, 2014^115^ | Ten items assessing frequency of violent and non-violent delinquency (e.g. physical fighting, stealing, selling drugs) were summed, range 0-10 where lower is better; 0-10 (Low) | 3 months | IG1 (Overall) | 12 | . (.), 201 | . (.), 207 | IRRnegbin: 1.03 (0.64 to 1.65) | NR, NS
| Walton, 2014^115^ | Ten items assessing frequency of violent and non-violent delinquency (e.g. physical fighting, stealing, selling drugs) were summed, range 0-10 where lower is better; 0-10 (Low) | 3 months | IG2 (Overall) | 3 | . (.), 220 | . (.), 216 | IRRnegbin: 0.90 (0.62 to 1.31) | NR, NS
| Walton, 2014^115^ | Ten items assessing frequency of violent and non-violent delinquency (e.g. physical fighting, stealing, selling drugs) were summed, range 0-10 where lower is better; 0-10 (Low) | 3 months | IG2 (Overall) | 6 | . (.), 218 | . (.), 211 | IRRnegbin: 0.94 (0.60 to 1.48) | NR, NS
| Walton, 2014^115^ | Ten items assessing frequency of violent and non-violent delinquency (e.g. physical fighting, stealing, selling drugs) were summed, range 0-10 where lower is better; 0-10 (Low) | 3 months | IG2 (Overall) | 12 | . (.), 220 | . (.), 207 | IRRnegbin: 0.85 (0.53 to 1.36) | NR, NS
Consequences of Drug Use | D’Amico, 2018^116^ | Number of negative consequences experienced - marijuana | 3 months | IG1 (Overall) | 3 | 1.7 (5.2), 113^†^ | 1.9 (7.2), 86^†^ | CalcMeanDiffChg: 0.06 (−1.33 to 1.45)^†^ | 0.93
Consequences of Drug Use | D’Amico, 2018^116^ | Number of negative consequences experienced - marijuana | 3 months | IG1 (Overall) | 6 | 0.7 (1.5), 127^†^ | 1.5 (5.7), 111^†^ | CalcMeanDiffChg: −0.72 (−1.72 to 0.28)^†^ | 0.16
Consequences of Drug Use | D’Amico, 2018^116^ | Number of negative consequences experienced - marijuana | 3 months | IG1 (Overall) | 12 | 0.9 (3.3), 122^†^ | 2.4 (9.3), 114^†^ | CalcMeanDiffChg: −1.75 (−3.38 to −0.12)^†^ | 0.04
Consequences of Drug Use | D’Amico, 2018^116^ | No. of negative consequences experienced - alcohol | 3 months | IG1 (Overall) | 3 | 2.2 (5.1), 113^†^ | 3.4 (9), 86^†^ | CalcMeanDiffChg: −1.16 (−2.81 to 0.49)^†^ | 0.17
Consequences of Drug Use | D’Amico, 2018^116^ | No. of negative consequences experienced - alcohol | 3 months | IG1 (Overall) | 6 | 2.2 (3.5), 127^†^ | 3.6 (8.5), 111^†^ | CalcMeanDiffChg: −1.34 (−2.85 to 0.17)^†^ | 0.08
Consequences of Drug Use | D’Amico, 2018^116^ | No. of negative consequences experienced - alcohol | 3 months | IG1 (Overall) | 12 | 2 (4.5), 122^†^ | 4.3 (12.4), 114^†^ | CalcMeanDiffChg: −2.33 (−4.49 to −0.17)^†^ | 0.03
Consequences of Drug Use | Lee, 2010^100^ | Rutgers Marijuana Problem Index. Respondents indicate how many times, from 0 (never) to 4 (more than 10 times), they experienced each of 18 negative consequences due to marijuana use in the past 3 months. Items include: “Not able to do your homework or study for a test” and “Missed out on other things because you spent too much money on marijuana.” Items were summed to assess number of different problems experienced; 0-72 (Low) | 3 months | IG1 (Overall) | 3 | .4 (3.4), 162 | .1 (2.5), 162 | CalcMeanDiffChg: 0.23 (−0.42 to 0.88) | NR, NS
Consequences of Drug Use | Lee, 2010^100^ | | 3 months | IG1 (Overall) | 6 | .5 (3.5), 160 | .3 (2.7), 160 | CalcMeanDiffChg: 0.15 (−0.53 to 0.83) | NR, NS
Consequences of Drug Use | Walton, 2013^114^ | Cannabis related consequences in the past 3 months, consisting of 23 items adapted from the Rutgers Alcohol Problems Index and 5 items from the Severity of Dependence Scale (interpersonal, intrapersonal, and substance use disorder problems); NR (Low) | 3 months | IG1 (Overall) | 3 | −1.7 (14.1), 101 | -.4 (15.1), 96 | TxtEffectEst: −0.18 (−0.42 to 0.06) | 0.15
Consequences of Drug Use | Walton, 2013^114^ | | 3 months | IG1 (Overall) | 6 | −2.9 (14.3), 102 | -3 (14.4), 97 | TxtEffectEst: −0.08 (−0.37 to 0.21) | 0.60
Consequences of Drug Use | Walton, 2013^114^ | | 3 months | IG1 (Overall) | 12 | −3.1 (14.3), 104 | −2.5 (14.7), 94 | TxtEffectEst: −0.07 (−0.36 to 0.22) | 0.62
Consequences of Drug Use | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 3 | −2.8 (15.3), 82 | -.4 (15.1), 96 | TxtEffectEst: −0.24 (−0.48 to 0.00) | <0.05
Consequences of Drug Use | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 6 | −3.8 (14.6), 79 | -3 (14.4), 97 | TxtEffectEst: −0.15 (−0.46 to 0.16) | 0.37
Consequences of Drug Use | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 12 | −1.6 (14.7), 77 | −2.5 (14.7), 94 | TxtEffectEst: 0.08 (−0.25 to 0.41) | 0.62

* Author reported.

† Mean value at followup, rather than change from baseline.

Abbreviations: Beta = Beta coefficient; Bweight = Beta weight; CalcMeanDiffChg = Calculated Mean Difference in Change; CES-D = Center for Epidemiologic Studies Depression Scale; CG = Control group; CHQ-CF-GH4 = Child Health Questionnaire-Child Form-General Health; CohensD = Cohen’s d; FU = Followup; IG = Intervention group; IRRnegbin = Incident rate ratio (negative binomial); MeanDiff = Mean Difference; MeanDiffinChange = Mean Difference in Change; NA = Not applicable; NR = Not reported; NS = Not significant; OR = Odds Ratio; POSIT = Problem Oriented Screening Instrument for Teenagers; RAASI = Reynolds Adolescent Adjustment Screening Inventory; SD = Standard deviation; SDQ = Strengths and Difficulties Questionnaire; TxtEffectEst = Treatment effect estimate; Y-OQ = Youth Outcome Questionnaire.

Appendix D. Table 5 Drug Use Outcomes (KQ2)

Outcome | Author, year | Outcome description; range (direction of better outcome) | Recall period | Group | FU, mo | IG n/n (%) or Mean (SD), n | CG n/n (%) or Mean (SD), n | Effect | p^*^
Cannabis abstinence | Harris, 2012^80^ | Cessation of use | 1 year | IG1 (Prague - Any BL cannabis use) | 12 | 15/38 (39.5) | 7/36 (19.4) | OR: 2.70 (0.94 to 7.73) | <0.05
Cannabis abstinence | Harris, 2012^80^ | Cessation of use | 1 year | IG1 (New England - Any BL cannabis use) | 12 | 28/95 (29.5) | 27/101 (26.7) | OR: 1.15 (0.61 to 2.14) | NR, NS
Cannabis any use | Baldus, 2016^81^ | Self-reported lifetime use | Lifetime | IG1 (Overall) | 0 | 3/147 (2.1) | 2/145 (1.4) | OR: 1.49 (0.25 to 9.05) | 0.686
Cannabis any use | Baldus, 2016^81^ | Self-reported lifetime use | Lifetime | IG1 (Overall) | 20 | 13/126 (10.3) | 14/121 (11.6) | OR: 0.86 (0.41 to 1.81) | 0.696
Cannabis any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 0 | 4/147 (2.8) | 1/145 (0.7) | OR: 4.03 (0.44 to 36.48) | NSD
Cannabis any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 8 | 5/147 (3.7) | 3/145 (2.3) | OR: 0.93 (0.33 to 2.66) | 0.897
Cannabis any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 20 | 8/147 (5.6) | 10/145 (6.7) | OR: 0.74 (0.28 to 1.96) | 0.537
Cannabis any use | Barlow, 2013^83^ | Any marijuana use in past month | 1 month | IG1 (Overall) | 0 | 13/159 (8.2) | 10/163 (6.1) | OR: 1.18 (0.49 to 2.83) | 0.71
Cannabis any use | Barlow, 2013^83^ | Any marijuana use in past month | 1 month | IG1 (Overall) | 4 | 33/159 (20.6) | 34/163 (21.0) | OR: 0.87 (0.44 to 1.70) | 0.68
Cannabis any use | Barlow, 2013^83^ | Any marijuana use in past month | 1 month | IG1 (Overall) | 8 | 20/159 (12.4) | 31/163 (18.8) | OR: 0.57 (0.29 to 1.11) | 0.10
Cannabis any use | Barlow, 2013^83^ | Any marijuana use in past month | 1 month | IG1 (Overall) | 14 | 30/159 (18.9) | 32/163 (19.6) | OR: 0.83 (0.44 to 1.58) | 0.57
Cannabis any use | Barlow, 2013^83^ | Any marijuana use in past month | 1 month | IG1 (Overall) | 38 | 17/159 (10.7) | 25/163 (15.6) | OR: 0.65 (0.48 to 0.89) | 0.007
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG1 (Overall) | 7 | . (.), 98 | . (.), 101 | TxtEffectEst: −0.03 (−0.71 to 0.65) | NR, NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG1 (Overall) | 13 | . (.), 98 | . (.), 101 | TxtEffectEst: 0.05 (−0.59 to 0.70) | NR, NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG1 (Overall) | 19 | . (.), 98 | . (.), 101 | TxtEffectEst: 0.01 (−0.75 to 0.78) | NR, NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG1 (Female) | 4 | – | – | TxtEffectEst: −0.67 (NR) | NR, NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG1 (Male) | 4 | – | – | TxtEffectEst: 0.31 (NR) | NR, NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG2 (Overall) | 7 | . (.), 101 | . (.), 101 | TxtEffectEst: 0.10 (−0.41 to 0.61) | NR. NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG2 (Overall) | 13 | . (.), 101 | . (.), 101 | TxtEffectEst: −0.07 (−0.71 to 0.56) | NR, NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG2 (Overall) | 19 | . (.), 101 | . (.), 101 | TxtEffectEst: −0.84 (−1.47 to −0.21) | <0.01
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG2 (Female) | 4 | – | – | TxtEffectEst: −0.01 (NR) | NR, NS
Cannabis any use | Dembo, 2016^88^ | Marijuana use; 0-6 (Low) | NR | IG2 (Male) | 4 | – | – | TxtEffectEst: 0.00 (NR) | NR, NS
Cannabis any use | Gmel, 2013^94^ | 6 months cannabis use | 6 months | IG1 (Overall) | 0 | 181/392 (46.2) | 205/461 (44.5) | OR: 1.07 (0.82 to 1.40) | NSD
Cannabis any use | Gmel, 2013^94^ | 6 months cannabis use | 6 months | IG1 (Overall) | | 97/288 (33.7) | 148/384 (38.6) | OR: 0.81 (0.59 to 1.11) | 0.013
Cannabis any use | Gmel, 2013^94^ | More than weekly use | 6 months | IG1 (Overall) | 0 | 54/392 (13.9) | 87/461 (18.8) | OR: 0.69 (0.47 to 0.99) | <0.05
Cannabis any use | Gmel, 2013^94^ | More than weekly use | 6 months | IG1 (Overall) | 6 | 42/288 (14.6) | 76/384 (19.8) | OR: 0.69 (0.46 to 1.05) | 0.493
Cannabis any use | Harris, 2012^80^ | Any past 12-month use | 1 year | IG1 (New England) | 0 | 95/765 (12.4) | 101/758 (13.3) | OR: 0.92 (0.68 to 1.25) | NR, NS
Cannabis any use | Harris, 2012^80^ | Any past 12-month use | 1 year | IG1 (Prague) | 0 | 38/264 (14.4) | 36/266 (13.6) | OR: 1.07 (0.66 to 1.76) | NR, NS
Cannabis any use | Harris, 2012^80^ | Any past 12-month use | 1 year | IG1 (New England) | 12 | 119/765 (15.6) | 133/758 (17.5) | OR: 0.87 (0.66 to 1.13) | NR, NS
Cannabis any use | Harris, 2012^80^ | Any past 12-month use | 1 year | IG1 (Prague) | 12 | 45/264 (17.0) | 76/266 (28.7) | OR: 0.51 (0.34 to 0.78) | <0.05
Cannabis any use | Harris, 2012^80^ | Any past 90-day use | 3 months | IG1 (New England) | 3 | 56/761 (7.4) | 72/755 (9.5) | OR: 0.75 (0.52 to 1.09) | NR, NS
Cannabis any use | Harris, 2012^80^ | Any past 90-day use | 3 months | IG1 (Prague) | 3 | 15/271 (5.5) | 24/245 (9.8) | OR: 0.54 (0.28 to 1.05) | <0.05
Cannabis any use | Harris, 2012^80^ | Initiation of marijuana use | 1 year | IG1 (Prague - No BL cannabis use) | 12 | 22/226 (9.7) | 47/230 (20.4) | OR: 0.42 (0.24 to 0.72) | <0.05
Cannabis any use | Harris, 2012^80^ | Initiation of marijuana use | 1 year | IG1 (New England - No BL cannabis use) | 12 | 52/670 (7.8) | 58/657 (8.8) | OR: 0.87 (0.59 to 1.28) | NR, NS
Cannabis any use | Kerr, 2013^97^ | Lifetime marijuana use | Lifetime | IG1 (Overall) | 12 | ./834 (.) | ./820 (.) | Regression coefficient: 0.56 | <0.001 (favors CG)
Cannabis any use | Kerr, 2013^97^ | Past month marijuana use; continuous measure to determine frequency of use | 1 month | IG1 (Overall) | 12 | ./834 (.) | ./820 (.) | Regression coefficient: −0.18 | NR, NS
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Overall) | 3 | 140/626 (22.4) | 69/243 (28.4) | OR: 0.73 (0.52 to 1.02) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Overall) | 6 | 172/626 (27.5) | 82/243 (33.7) | OR: 0.74 (0.54 to 1.02) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Overall) | 9 | 201/626 (32.1) | 91/243 (37.4) | OR: 0.79 (0.58 to 1.08) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Overall) | 12 | 232/626 (37.1) | 101/243 (41.6) | OR: 0.83 (0.61 to 1.12) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Alcohol or other drug use in past 12 months at baseline) | 3 | 113/148 (76.4) | 53/63 (84.1) | OR: 0.61 (0.28 to 1.32) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (No alcohol or other drug use in past 12 months at baseline) | 3 | 27/478 (5.6) | 16/180 (8.9) | OR: 0.61 (0.32 to 1.17) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Alcohol or other drug use in past 12 months at baseline) | 6 | 126/148 (85.1) | 59/63 (93.7) | OR: 0.39 (0.13 to 1.18) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (No alcohol or other drug use in past 12 months at baseline) | 6 | 46/478 (9.6) | 23/180 (12.8) | OR: 0.73 (0.43 to 1.24) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Alcohol or other drug use in past 12 months at baseline) | 9 | 136/148 (91.9) | 61/63 (96.8) | OR: 0.37 (0.08 to 1.71) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (No alcohol or other drug use in past 12 months at baseline) | 9 | 65/478 (13.6) | 30/180 (16.7) | OR: 0.79 (0.49 to 1.26) | NSD
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (Alcohol or other drug use in past 12 months at baseline) | 12 | 137/148 (92.6) | 63/63 (100.0) | HR: 0.62 (0.41 to 0.94) | <0.05
Cannabis any use | Knight, 2019^72^ | Number with any cannabis use | 12 months | IG1 (No alcohol or other drug use in past 12 months at baseline) | 12 | 95/478 (19.9) | 38/180 (21.1) | HR: 0.76 (0.44 to 1.32) | NR, NS
Cannabis any use | Malmberg, 2014^102^ | Lifetime use | Lifetime | IG1 (Overall) | 0 | 29/1225 (2.4) | 15/1191 (1.3) | OR: 2.46 (0.47 to 12.84) | NSD
Cannabis any use | Malmberg, 2014^102^ | Lifetime use | Lifetime | IG1 (Overall) | 8 | 68/1114 (6.1) | 58/1109 (5.2) | OR: 1.22 (0.49 to 3.03) | 0.517
Cannabis any use | Malmberg, 2014^102^ | Lifetime use | Lifetime | IG1 (Overall) | 20 | 122/1003 (12.2) | 92/982 (9.4) | OR: 1.34 (0.66 to 2.73) | 0.517
Cannabis any use | Malmberg, 2014^102^ | Lifetime use | Lifetime | IG1 (Overall) | 32 | 150/825 (18.2) | 109/692 (15.7) | OR: 1.15 (0.59 to 2.25) | 0.517
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 3 months | IG1 (Overall) | 3 | 13/199 (6.5) | 17/216 (7.9) | OR: 0.82 (0.39 to 1.73) | NSD
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 3 months | IG1 (Overall) | 6 | 18/200 (9.0) | 19/211 (9.0) | OR: 1.00 (0.51 to 1.96) | NSD
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 3 months | IG2 (Overall) | 3 | 11/220 (5.0) | 17/216 (7.9) | OR: 0.62 (0.28 to 1.35) | NSD
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 3 months | IG2 (Overall) | 6 | 13/218 (6.0) | 19/211 (9.0) | OR: 0.64 (0.31 to 1.33) | NSD
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 12 months | IG1 (Overall) | 12 | 22/201 (10.9) | 29/207 (14.0) | OR: 0.75 (0.42 to 1.36) | NSD
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 12 months | IG1 (Overall) | 12 | 42/201 (20.9) | 50/207 (24.2) | OR: 0.83 (0.52 to 1.32) | NSD
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 12 months | IG2 (Overall) | 12 | 37/220 (16.8) | 50/207 (24.2) | OR: 0.63 (0.39 to 1.02) | NSD
Cannabis any use | Walton, 2014^115^ | Any cannabis use | 12 months | IG2 (Overall) | 12 | 24/220 (10.9) | 29/207 (14.0) | OR: 0.75 (0.42 to 1.34) | NSD
Cannabis frequency/quantity - times used | D’Amico, 2018^116^ | Times used marijuana in past 90 days | 3 months | IG1 (Overall) | 3 | 6.4 (8.1), 113^†^ | 5.9 (7.6), 86^†^ | CalcMeanDiff: 0.43 (−1.75 to 2.61)^†^ | 0.99
Cannabis frequency/quantity - times used | D’Amico, 2018^116^ | Times used marijuana in past 90 days | 3 months | IG1 (Overall) | 6 | 6.1 (7.9), 127^†^ | 5.1 (6.8), 111^†^ | CalcMeanDiff: 1.06 (−0.81 to 2.93)^†^ | 0.35
Cannabis frequency/quantity - times used | D’Amico, 2018^116^ | Times used marijuana in past 90 days | 3 months | IG1 (Overall) | 12 | 6.8 (8.4), 127^†^ | 5.2 (7.3), 114^†^ | CalcMeanDiff: 1.55 (−0.43 to 3.53)^†^ | 0.23
Cannabis frequency/quantity - times used | Estrada, 2018^90^ | Times used marijuana in past 90 days | 3 months | IG1 (Overall) | 3 | −0.8 (7.9), 84 | 0.8 (6.4), 101 | CalcMeanDiffChg: −1.57 (−3.68 to 0.54) | <0.01
Cannabis frequency/quantity - times used | Estrada, 2018^90^ | Times used marijuana in past 90 days | 3 months | IG1 (Overall) | 12 | −0.8 (8), 82 | 2 (11.3), 98 | EffectSize: −2.74 (−5.56 to 0.08) | <0.01
Cannabis frequency/quantity - times used | Fang, 2010^92^ | Past 30-day use occasions | 3 months | IG1 (Overall) | 6 | −0.2 (1.3), 54 | −0.5 (2.6), 50 | CalcMeanDiffChg: 0.27 (−0.52 to 1.06) | 0.009
Cannabis frequency/quantity - times used | Fang, 2010^92^ | Past 30-day use occasions | 3 months | IG1 (Overall) | 12 | −0.2 (1.3), 54 | −0.2 (2.3), 50 | CalcMeanDiffChg: −0.06 (−0.78 to 0.66) | 0.043
Cannabis frequency/quantity - times used | Fang, 2010^92^ | Past 30-day use occasions | 3 months | IG1 (Overall) | 24 | −0.2 (1.3), 50 | 0 (2.3), 43 | CalcMeanDiffChg: −0.21 (−0.98 to 0.56) | 0.043
Cannabis frequency/quantity - times used | Johnson, 2015^96^ | Time used marijuana in the past 30 days | 3 months | IG1 (Overall) | 6 | 1.3 (21.5), 101 | 3.7 (34.7), 99 | RRnegbin: 1.83 (1.17 to 2.85) | ≤0.05
Cannabis frequency/quantity - times used | Schinke, 2009a^107^ | Reported use occasions in past 30 days | 3 months | IG1 (Overall) | 12 | 0.1 (.4), 205 | 0.4 (1.9), 327 | TxtEffectEst: −0.30 (−0.51 to −0.09) | <0.01
Cannabis frequency/quantity - times used | Schinke, 2009b^108^ | Times smoked marijuana in past month | 3 months | IG1 (Overall) | 12 | 0 (0), 434 | 0.1 (.6), 430 | CalcMeanDiffChg: −0.03 (−0.09 to 0.03) | <0.016
Cannabis frequency/quantity - times used | Schinke, 2009b^108^ | Times smoked marijuana in past month | 3 months | IG1 (Overall) | 24 | 0.1 (.3), 415 | 0.3 (2.1), 413 | CalcMeanDiffChg: −0.27 (−0.47 to −0.07) | <0.016
Cannabis frequency/quantity - times used | Schwinn, 2010^110^ | Report how many times in the past month any drug was used | 3 months | IG1 (Overall) | 6 | 0.1 (3.1), 108^†^ | 1.3 (3.3), 118^†^ | CalcMeanDiff: −1.14 (−1.97 to −0.31)^†^ | 0.02
Cannabis frequency/quantity - times used | Schwinn, 2015^112^ | 30-day marijuana use | 3 months | IG1 (Overall) | 3 | −0.3 (5.2), 97 | −0.4 (5.9), 103 | CalcMeanDiffChg: 0.15 (−1.39 to 1.69) | NR, NS
Cannabis frequency/quantity - times used | Schwinn, 2018^111^ | Times used in past month | 3 months | IG1 (Overall) | 3 | −1.5 (14.7), 376 | −0.9 (12.5), 380 | Bweight: −0.60 (−2.25 to 1.05) | NR, NS
Cannabis frequency/quantity - times used | Schwinn, 2018^111^ | Times used in past month | 3 months | IG1 (Overall) | 15 | 0.8 (15.3), 370 | −0.2 (12.5), 382 | Bweight: 1.47 (−0.29 to 3.23) | NR, NS
Cannabis frequency/quantity - days used | Gmel, 2013^94^ | Number of days with cannabis use per month | 3 months | IG1 (Overall) | 6 | 0.1 (.), 288 | 0.2 (.), 384 | Beta: −0.27 (−0.60 to 0.06) | 0.113
Cannabis frequency/quantity - days used | Gmel, 2013^94^ | Number of days with cannabis use per month, consistent users | 3 months | IG1 (Consistent users) | 6 | 0.4 (.), . | 0.7 (.), . | Beta: −0.45 (−1.38 to 0.48) | 0.342
Cannabis frequency/quantity - days used | Lee, 2010^100^ | On how many days did you use any kind of marijuana or hashish? | 3 months | IG1 (Overall) | 3 | −0.7 (15), 162 | −0.8 (16), 162 | CalcMeanDiffChg: 0.03 (−3.35 to 3.41) | NR, NS
Cannabis frequency/quantity - days used | Lee, 2010^100^ | On how many days did you use any kind of marijuana or hashish? | 3 months | IG1 (Overall) | 6 | 1.2 (17.5), 160 | 2.1 (17.9), 160 | CalcMeanDiffChg: −0.94 (−4.82 to 2.94) | NR, NS
Cannabis frequency/quantity - score | Kim, 2011^98^ | Marijuana use in past year (1=never, 9=daily); 1-9 (Low) | 1 year | IG1 (Overall) | 36 | 1.3 (.8), 48^†^ | 2.3 (2.4), 52^†^ | CohensD: −1.04 (−1.74 to −0.34)^†^ | 0.01
Cannabis frequency/quantity - score | Mason, 2015^103^ | Participants were asked the number of days they have used marijuana within the last month, coded as 0= 0 days, 1= 1 or 2 days, 3= 3 to 5 days, 4=6 to 9 days, 5=10 to 19 days, 6=20 to 29 days, and 7=all 30 days.; 0-7 (Low) | 1 month | IG1 (Overall) | 6 | . (.), 57 | . (.), 60 | TxtEffectEst: −0.08 (−0.18 to 0.02) | NR, NS
Cannabis frequency/quantity - score | Mason, 2015^103^ | Participants were asked the number of days they have used marijuana within the last month, coded as 0= 0 days, 1= 1 or 2 days, 3= 3 to 5 days, 4=6 to 9 days, 5=10 to 19 days, 6=20 to 29 days, and 7=all 30 days.; 0-7 (Low) | 1 month | IG1 (Female) | 3 | 0 (.), 44 | −0.3 (.), 40 | – | NR, NS
Cannabis frequency/quantity - score | Mason, 2015^103^ | | 1 month | IG1 (Male) | 3 | −0.2 (.), 15 | 0.1 (.), 20 | – | NR, NS
Cannabis frequency/quantity - score | Mason, 2015^103^ | | 1 month | IG1 (Female) | 6 | 0.1 (.), 44 | −0.5 (.), 40 | – | NR, NS
Cannabis frequency/quantity - score | Mason, 2015^103^ | | 1 month | IG1 (Male) | 6 | −0.3 (.), 15 | 0.3 (.), 20 | – | NR, NS
Cannabis frequency/quantity - score | Walton, 2013^114^ | Past 3 month frequency of cannabis. Response choices were: never = 0; 1–2 days = 1; once a month or less = 2; 2–3 days per month = 3; 1–2 days per week = 4; 3–5 days per week = 5; and every day or almost every day = 6.; 0-6 (Low) | 3 months | IG1 (Overall) | 3 | −0.8 (2), 101 | −1.2 (2), 96 | TxtEffectEst: −0.18 (−0.43 to 0.07) | 0.16
Cannabis frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG1 (Overall) | 6 | −0.7 (2), 102 | −1.2 (2), 97 | TxtEffectEst: 0.25 (−0.02 to 0.52) | 0.08
Cannabis frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG1 (Overall) | 12 | -.5 (2.1), 104 | −1.1 (2.1), 94 | TxtEffectEst: 0.15 (−0.12 to 0.42) | 0.28
Cannabis frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 3 | -1 (2.1), 82 | −1.2 (2), 96 | TxtEffectEst: −0.08 (−0.37 to 0.21) | 0.57
Cannabis frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 6 | −1.1 (2), 79 | −1.2 (2), 97 | TxtEffectEst: 0.08 (−0.23 to 0.39) | 0.62
Cannabis frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 12 | -1 (2.1), 77 | −1.1 (2.1), 94 | TxtEffectEst: −0.03 (−0.34 to 0.28) | 0.85
Cannabis frequency/quantity - score | Walton, 2014^115^ | Cannabis (e.g. marijuana, weed, pot) use frequency. Response choices were: never, 1–2 days, once a month or less, 2–3 days per month, 1–2 days per week, 3–5 days per week and every day or almost every day.; 0-6 (Low) | 3 months | IG1 (Overall) | 3 | . (.), 199 | . (.), 216 | IRRnegbin: 0.84 (0.49 to 1.42) | NR, NS
Cannabis frequency/quantity - score | Walton, 2014^115^ | Cannabis (e.g. marijuana, weed, pot) use frequency. Response choices were: never, 1–2 days, once a month or less, 2–3 days per month, 1–2 days per week, 3–5 days per week and every day or almost every day.; 0-6 (Low) | 3 months | IG1 (Overall) | 6 | . (.), 200 | . (.), 211 | IRRnegbin: 0.66 (0.41 to 1.06) | NR, NS
Cannabis frequency/quantity - score | Walton, 2014^115^ | | 3 months | | 12 | . (.), 201 | . (.), 207 | IRRnegbin: 0.94 (0.21 to 4.18) | NR, NS
Cannabis frequency/quantity - score | Walton, 2014^115^ | | 3 months | IG2 (Overall) | 3 | . (.), 220 | . (.), 216 | IRRnegbin: 0.53 (0.29 to 0.95) | <0.05
Cannabis frequency/quantity - score | Walton, 2014^115^ | | 3 months | IG2 (Overall) | 6 | . (.), 218 | . (.), 211 | IRRnegbin: 0.61 (0.37 to 0.99) | <0.05
Cannabis frequency/quantity - score | Walton, 2014^115^ | Cannabis (e.g. marijuana, weed, pot) use frequency. Response choices were: never, 1–2 days, once a month or less, 2–3 days per month, 1–2 days per week, 3–5 days per week and every day or almost every day.; 0-6 (Low) | 3 months | IG2 (Overall) | 12 | . (.), 220 | . (.), 207 | IRRnegbin: 0.86 (0.58 to 1.27) | NR, NS
Other drug any use | Estrada, 2018^90^ | Proportion with prescription drug (mis)use use over time | NR | IG1 (Overall) | 0 | 3/113 (2.7) | 1/117 (0.1) | OR: 3.16 (0.32 to 30.87) | NSD
Other drug any use | Estrada, 2018^90^ | Proportion with prescription drug (mis)use use over time | NR | IG1 (Overall) | 3 | 3/84 (3.6) | 4/101 (4.0) | OR: 0.90 (0.20 to 4.13) | NR, NS
Other drug any use | Estrada, 2018^90^ | Proportion with prescription drug (mis)use use over time | NR | IG1 (Overall) | 12 | 2/82 (2.4) | 5/98 (5.1) | OR: 0.47 (0.09 to 2.46) | NR, NS
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times (mis)used prescription drugs in past 90 days | 3 months | IG1 (Overall) | 3 | 0.2 (1.2), 84 | −0.1 (8.3), 101 | CalcMeanDiffChg: 0.33 (−1.31 to 1.97) | <0.01
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times (mis)used prescription drugs in past 90 days | 3 months | IG1 (Overall) | 12 | 0 (0.3), 82 | 0.1 (8.6), 98 | EffectSize: −0.15 (−1.85 to 1.55) | <0.01
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times used cocaine in past 90 days | 3 months | IG1 (Overall) | 3 | −0.7 (8), 84 | 0.6 (6.5), 101 | CalcMeanDiffChg: −1.31 (−3.43 to 0.81) | NR, NS
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times used cocaine in past 90 days | 3 months | IG1 (Overall) | 12 | −0.8 (8.4), 82 | 0.8 (7.3), 98 | EffectSize: −1.57 (−3.90 to 0.76) | NR, NS
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times used inhalants in past 90 days | 3 months | IG1 (Overall) | 3 | −0.7 (8), 84 | 0.6 (6.5), 101 | CalcMeanDiffChg: −1.35 (−3.47 to 0.77) | <0.001
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times used inhalants in past 90 days | 3 months | IG1 (Overall) | 12 | −0.8 (8.2), 82 | 0.8 (7.3), 98 | EffectSize: −1.53 (−3.83 to 0.77) | <0.001
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times used other (NOS) drug in past 90 days | 3 months | IG1 (Overall) | 3 | −0.6 (7.9), 84 | 0.7 (6.9), 101 | CalcMeanDiffChg: −1.34 (−3.50 to 0.82) | NR, NS
Other drug frequency/quantity - times used | Estrada, 2018^90^ | Times used other (NOS) drug in past 90 days | 3 months | IG1 (Overall) | 12 | −0.8 (8.4), 82 | 0.8 (7.7), 98 | EffectSize: −1.64 (−4.01 to 0.73) | NR, NS
Other drug frequency/quantity - times used | Fang, 2010^92^ | Past 30-day prescription drug use occasions | 3 months | IG1 (Overall) | 6 | −1.9 (8.9), 54 | -1 (4.3), 50 | CalcMeanDiffChg: −0.93 (−3.59 to 1.73) | 0.017
Other drug frequency/quantity - times used | Fang, 2010^92^ | Past 30-day prescription drug use occasions | 3 months | IG1 (Overall) | 12 | −1.7 (8.5), 54 | 3.4 (19.5), 50 | CalcMeanDiffChg: −5.13 (−10.98 to 0.72) | 0.047
Other drug frequency/quantity - times used | Fang, 2010^92^ | Past 30-day prescription drug use occasions | 3 months | IG1 (Overall) | 24 | −1.9 (8.9), 50 | 9.4 (36.8), 43 | CalcMeanDiffChg: −11.34 (−22.60 to −0.08) | 0.047
Other drug frequency/quantity - times used | Schinke, 2009a^107^ | Reported prescription use occasions in past 30 days | 3 months | IG1 (Overall) | 12 | −0.4 (2.5), 205 | 0.2 (4.2), 327 | TxtEffectEst: −0.66 (−1.23 to −0.09) | <0.0001
Other drug frequency/quantity - times used | Schinke, 2009b^108^ | Times used illicit prescriptions in past 30 days | 3 months | IG1 (Overall) | 12 | −0.1 (.6), 434 | 0 (0.3), 430 | CalcMeanDiffChg: −0.12 (−0.18 to −0.06) | <0.03
Other drug frequency/quantity - times used | Schinke, 2009b^108^ | Times used illicit prescriptions in past 30 days | 3 months | IG1 (Overall) | 24 | −0.1 (.5), 415 | 0.1 (0.5), 413 | CalcMeanDiffChg: −0.15 (−0.22 to −0.08) | <0.03
Other drug frequency/quantity - times used | Schinke, 2009b^108^ | Times used inhalants in past 30 days | 3 months | IG1 (Overall) | 12 | −0.1 (.8), 434 | 0.1 (0.8), 430 | CalcMeanDiffChg: −0.15 (−0.26 to −0.04) | <0.024
Other drug frequency/quantity - times used | Schinke, 2009b^108^ | Times used inhalants in past 30 days | 3 months | IG1 (Overall) | 24 | −0.1 (0.8), 415 | 0.1 (0.5), 413 | CalcMeanDiffChg: −0.12 (−0.21 to −0.03) | <0.024
Other drug frequency/quantity - times used | Schwinn, 2015^112^ | 30-day inhalants, club drugs, steroids, cocaine, methamphetamines, prescription drugs, and heroin use | 3 months | IG1 (Overall) | 3 | −0.4 (1.1), 97 | −0.4 (2.6), 103 | CalcMeanDiffChg: 0.06 (−0.48 to 0.60) | <0.05
Other drug frequency/quantity - times used | Schwinn, 2018^111^ | Times used club drugs, cocaine, ecstasy, hallucinogens, heroin, inhalants, methamphetamines, steroids, and prescription drugs in past month | 3 months | IG1 (Overall) | 3 | −2.2 (14.3), 376 | −1.8 (11), 380 | Bweight: −1.47 (−3.00 to 0.06) | NR, NS
Other drug frequency/quantity - times used | Schwinn, 2018^111^ | Times used club drugs, cocaine, ecstasy, hallucinogens, heroin, inhalants, methamphetamines, steroids, and prescription drugs in past month | 3 months | IG1 (Overall) | 15 | −2.2 (14.3), 370 | -2 (11), 382 | Bweight: −1.08 (−2.79 to 0.63) | NR, NS
Other drug frequency/quantity - score | Walton, 2013^114^ | Past 3 month frequency of inhalants, cocaine, heroin, other hallucinogens, nonmedical use of painkillers/opioids, stimulants, and sedatives. Response choices were: never = 0; 1–2 days = 1; once a month or less = 2; 2–3 days per month = 3; 1–2 days per week; 0-6 (Low) | 3 months | IG1 (Overall) | 3 | −0.2 (1.2), 101 | 0 (3.6), 96 | TxtEffectEst: 0.61 (−0.15 to 1.37) | 0.12
Other drug frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG1 (Overall) | 6 | −0.2 (1.2), 102 | 0 (4), 97 | TxtEffectEst: −0.48 (−1.30 to 0.34) | 0.255
Other drug frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG1 (Overall) | 12 | −0.1 (1.5), 104 | −0.5 (2.5), 94 | TxtEffectEst: 0.33 (−0.67 to 1.33) | 0.52
Other drug frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 3 | −0.7 (2.8), 82 | 0 (3.6), 96 | TxtEffectEst: 1.82 (0.49 to 3.15) | <0.01
Other drug frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 6 | −0.7 (2.8), 79 | 0 (4), 97 | TxtEffectEst: −1.41 (−2.43 to −0.39) | <0.01
Other drug frequency/quantity - score | Walton, 2013^114^ | | 3 months | IG2 (Overall) | 12 | −0.4 (2.7), 77 | −0.5 (2.5), 94 | TxtEffectEst: 0.21 (−0.73 to 1.15) | 0.66
Other drug frequency/quantity - score | Walton, 2014^115^ | Illicit (inhalants, cocaine, heroin and other hallucinogens) and non-medical prescription drug use (painkillers/opiates, stimulants, and sedatives) (on your own without a doctor telling you to take them). Response options ranged from 0–6: never, 1–2 day; 0-42 (Low) | 3 months | IG2 (Overall) | 3 | . (.), 220 | . (.), 216 | IRRnegbin: 0.52 (0.31 to 0.86) | <0.05
Other drug frequency/quantity - score | Walton, 2014^115^ | Illicit (inhalants, cocaine, heroin and other hallucinogens) and non-medical prescription drug use (painkillers/opiates, stimulants, and sedatives) (on your own without a doctor telling you to take them). Response options ranged from 0–6: never, 1–2 day; 0-42 (Low) | 3 months | IG2 (Overall) | 6 | . (.), 218 | . (.), 211 | IRRnegbin: 0.97 (0.61 to 1.55) | NR, NS
Other drug frequency/quantity - score | Walton, 2014^115^ | | 3 months | IG2 (Overall) | 12 | . (.), 220 | . (.), 207 | IRRnegbin: 0.78 (0.38 to 1.58) | NR, NS
Other drug frequency/quantity - score | Walton, 2014^115^ | Illicit and non-medical prescription drug use (on your own without a doctor telling you to take them). Response options ranged from 0–6: never, 1–2 days, once a month or less, 2–3 days per month, 1–2 days per week, 3–5 days per week, every day.; 0-42 (Low) | 3 months | IG1 (Overall) | 3 | . (.), 199 | . (.), 216 | IRRnegbin: 0.65 (0.39 to 1.08) | NR, NS
Other drug frequency/quantity - score | Walton, 2014^115^ | | 3 months | IG1 (Overall) | 6 | . (.), 200 | . (.), 211 | IRRnegbin: 0.63 (0.37 to 1.07) | NR, NS
Other drug frequency/quantity - score | Walton, 2014^115^ | | 3 months | IG1 (Overall) | 12 | . (.), 201 | . (.), 207 | IRRnegbin: 0.90 (0.39 to 2.04) | NR, NS
Any drug any use | Bannink, 2014^82^ | Drug use in past 4 weeks | 1 month | IG1 (Overall) | 0 | 27/430 (6.3) | 35/434 (8.1) | OR: 0.77 (0.37 to 1.59) | 0.31
Any drug any use | Bannink, 2014^82^ | Drug use in past 4 weeks | 1 month | IG1 (Overall) | 4 | 44/430 (10.4) | 36/434 (8.3) | OR: 1.54 (0.63 to 3.85) | 0.34
Any drug any use | Bannink, 2014^82^ | Drug use in past 4 weeks | 1 month | IG2 (Overall) | 0 | 18/392 (4.6) | 35/434 (8.1) | OR: 0.53 (0.23 to 1.22) | 0.04
Any drug any use | Bannink, 2014^82^ | Drug use in past 4 weeks | 1 month | IG2 (Overall) | 4 | 23/392 (5.9) | 36/434 (8.3) | OR: 0.94 (0.38 to 2.33) | 0.90
Any drug any use | Barlow, 2013^83^ | Any illegal drug use in past month | 1 month | IG1 (Overall) | 0 | 16/159 (10.1) | 13/163 (8.0) | OR: 1.06 (0.48 to 2.35) | 0.88
Any drug any use | Barlow, 2013^83^ | Any illegal drug use in past month | 1 month | IG1 (Overall) | 4 | 36/159 (22.9) | 36/163 (21.9) | OR: 1.03 (0.61 to 1.74) | 0.84
Any drug any use | Barlow, 2013^83^ | Any illegal drug use in past month | 1 month | IG1 (Overall) | 8 | 22/159 (13.8) | 33/163 (20.2) | OR: 0.58 (0.31 to 1.10) | 0.09
Any drug any use | Barlow, 2013^83^ | Any illegal drug use in past month | 1 month | IG1 (Overall) | 14 | 34/159 (21.3) | 36/163 (21.9) | OR: 0.83 (0.44 to 1.55) | 0.55
Any drug any use | Barlow, 2013^83^ | Any illegal drug use in past month | 1 month | IG1 (Overall) | 38 | 20/159 (12.3) | 28/163 (17.3) | OR: 0.67 (0.50 to 0.91) | 0.01
Any drug any use | Estrada, 2018^90^ | Proportion of overall drug use over time | NR | IG1 (Overall) | 0 | 6/113 (5.3) | 4/117 (4.5) | OR: 1.58 (0.43 to 5.77) | NSD
Any drug any use | Estrada, 2018^90^ | Proportion of overall drug use over time | NR | IG1 (Overall) | 3 | 5/84 (6.0) | 9/101 (8.9) | OR: 0.65 (0.21 to 2.01) | NSD
Any drug any use | Estrada, 2018^90^ | Proportion of overall drug use over time | NR | IG1 (Overall) | 12 | 6/82 (7.3) | 14/98 (14.3) | OR: 0.47 (0.17 to 1.29) | NSD
Any drug any use | Foxcroft, 2017^93^ | – | 1 year | IG1 (Overall) | 0 | 17/324 (5.3) | 7/235 (3.0) | OR: 1.80 (0.74 to 4.42) | NSD
Any drug any use | Foxcroft, 2017^93^ | – | 1 year | IG1 (Overall) | 12 | 14/222 (6.3) | 6/193 (3.1) | OR: 1.25 (0.46 to 3.38) | NSD
Any drug any use | Foxcroft, 2017^93^ | – | 1 year | IG1 (Overall) | 24 | 6/169 (3.6) | 7/149 (4.7) | OR: 0.96 (0.40 to 2.24) | NSD
Any drug any use | Jalling, 2016^95^ | Self-report of any drug use | 6 months | IG1 (Overall) | 0 | 5/70 (7.1) | 17/81 (21.0) | OR: 0.29 (0.10 to 0.83) | <0.01
Any drug any use | Jalling, 2016^95^ | Self-report of any drug use | 6 months | IG1 (Overall) | 6 | 12/70 (17.1) | 9/81 (11.1) | OR: 3.23 (1.06 to 9.08) | <0.05
Any drug any use | Jalling, 2016^95^ | Self-report of any drug use | 6 months | IG2 (Overall) | 0 | 18/85 (21.2) | 17/81 (21.0) | OR: 1.01 (0.48 to 2.13) | NSD
Any drug any use | Jalling, 2016^95^ | Self-report of any drug use | 6 months | IG2 (Overall) | 6 | 22/85 (25.9) | 9/81 (11.1) | OR: 3.52 (1.23 to 10.10) | <0.05
Any drug any use | Sanci, 2015^106^ | Any illicit drug use in last 12 months | 1 year | IG1 (Overall) | 0 | 95/377 (25.2) | 144/524 (27.5) | OR: 0.90 (0.58 to 1.38) | NSD
Any drug any use | Sanci, 2015^106^ | Any illicit drug use in last 12 months | 1 year | IG1 (Overall) | 3 | 35/377 (9.3) | 80/524 (15.3) | OR: 0.55 (0.33 to 0.90) | 0.02
Any drug any use | Sanci, 2015^106^ | Any illicit drug use in last 12 months | 1 year | IG1 (Overall) | 12 | 38/377 (10.1) | 82/524 (15.7) | OR: 0.61 (0.38 to 0.97) | 0.04
Any drug any use | Walkup, 2009^113^ | Illegal substance use in the past month | 1 month | IG1 (Overall) | 5 | 7/54 (13.0) | 5/71 (7.0) | OR: 2.02 (0.51 to 7.92) | NR, NS
Any drug any use | Walkup, 2009^113^ | Illegal substance use in the past month | 1 month | IG1 (Overall) | 9 | 3/47 (7.0) | 2/68 (3.0) | OR: 2.57 (0.37 to 18.00) | NR, NS
Any drug severity | Barlow, 2013^83^ | POSIT substance abuse score; 0-17 (Low) | NR | IG1 (Overall) | 4 | −0.1 (.), 159 | 0 (.), 163 | MeanDiff: −0.05 (−0.37 to 0.27) | 0.78
Any drug severity | Barlow, 2013^83^ | POSIT substance abuse score; 0-17 (Low) | NR | IG1 (Overall) | 8 | −0.3 (.), 159 | −0.1 (.), 163 | MeanDiff: −0.16 (−0.48 to 0.17) | 0.34
Any drug severity | Barlow, 2013^83^ | POSIT substance abuse score; 0-17 (Low) | NR | IG1 (Overall) | 38 | −0.5 (.), 159 | −0.2 (.), 163 | MeanDiff: −0.32 (−0.80 to 0.16) | 0.19
Any drug frequency/quantity - times used | Estrada, 2018^90^ | Assume # times used in past 90 days | 3 months | IG1 (Overall) | 3 | −2.8 (31.7), 84 | 2.7 (26.2), 101 | CalcMeanDiffChg: −5.54 (−14.04 to 2.96)
Any drug frequency/quantity - times used | Estrada, 2018^90^ | Assume # times used in past 90 days | 3 months | IG1 (Overall) | 12 | −3.1 (33.1), 82 | 4.3 (30.7), 98 | EffectSize: −7.47 (−16.86 to 1.92)
Any drug frequency/quantity - times used | Rhee, 2008^105^ | Number episodes of drug use in past year | 3 months | IG1 (Overall) | 2 | −0.4 (2.2), 17 | −0.7 (2.3), 18 | CalcMeanDiffChg: 0.23 (−1.28 to 1.73) | NR, NS
Any drug frequency/quantity - times used | Rhee, 2008^105^ | Number episodes of drug use in past year | 3 months | IG1 (Overall) | 4 | −0.5 (2.3), 17 | 0 (2.5), 18 | CalcMeanDiffChg: −0.47 (−2.05 to 1.11) | NR, NS
Any drug frequency/quantity - times used | Rhee, 2008^105^ | Number episodes of drug use in past year | 3 months | IG1 (Overall) | 6 | −0.4 (2.1), 17 | −0.2 (2.5), 18 | CalcMeanDiffChg: −0.18 (−1.73 to 1.36) | NR, NS
Any drug frequency/quantity - score | Barlow, 2006^85^ | Drug use, 8 self-reported items on a 4-point scale; 8-32 (NR) | NR | IG1 (Overall) | 5 | 23.9 (8), 19^†^ | 22.5 (7), 22^†^ | MeanDiff: 1.10 (−3.90 to 6.00)^†^ | 0.67
Any drug frequency/quantity - score | Barlow, 2006^85^ | Drug use, 8 self-reported items on a 4-point scale; 8-32 (NR) | NR | IG1 (Overall) | 9 | 25.1 (6), 19^†^ | 22.4 (8), 22^†^ | MeanDiff: 2.60 (−2.20 to 7.40)^†^ | 0.27

* Author reported.

† Mean value at followup, rather than change from baseline.

Abbreviations: Beta = Beta coefficient; BL = Baseline; Bweight = Beta weight; CalcMeanDiff = Calculated Mean Difference; CalcMeanDiffChg = Calculated Mean Difference in Change; CG = Control group; CohensD = Cohen’s d; EffectSize = Effect size; FU = Followup; IG = Intervention group; IRRnegbin = Incident rate ratio (negative binomial); MeanDiff = Mean Difference; NR = Not reported; NS = Not significant; NSD = No significant difference; OR = Odds ratio; RRnegbin = Risk Ratio (negative binomial); SD = Standard deviation; TxtEffectEst = Treatment effect estimate.

Appendix D. Table 6 Other Substance Use Outcomes (KQ2)

Outcome | Author, year | Outcome description; range (direction of better outcome) | Recall period | Group | FU, mo | IG n/n (%) or Mean (SD), n | CG n/n (%) or Mean (SD), n | Effect | p^*^
Composite any use | Barlow, 2013^83^ | Any alcohol or illegal drug use in past month | 1 month | IG1 (Overall) | 0 | 20/159 (12.6) | 17/163 (10.4) | OR: 0.93 (0.44 to 1.98) | 0.86
Composite any use | Barlow, 2013^83^ | Any alcohol or illegal drug use in past month | 1 month | IG1 (Overall) | 4 | 52/159 (32.9) | 47/163 (29.1) | OR: 1.04 (0.59 to 1.84) | 0.89
Composite any use | Barlow, 2013^83^ | Any alcohol or illegal drug use in past month | 1 month | IG1 (Overall) | 8 | 44/159 (27.7) | 50/163 (30.8) | OR: 0.76 (0.44 to 1.32) | 0.33
Composite any use | Barlow, 2013^83^ | Any alcohol or illegal drug use in past month | 1 month | IG1 (Overall) | 14 | 62/159 (38.9) | 56/163 (34.6) | OR: 1.07 (0.65 to 1.77) | 0.79
Composite frequency/quantity - times used | Kim, 2011^98^ | Composite use (instances) in past year; 1-9 (Low) | 3 months | IG1 (Overall) | 36 | 0.4 (.2), 48^†^ | 0.5 (0.5), 52^†^ | CohensD: −0.19 (−0.33 to −0.04)^†^ | 0.03
Composite frequency/quantity - times used | Schwinn, 2010^110^ | Report how many times in the past month any drug was used.; 0-7 (Low) | 3 months | IG1 (Overall) | 6 | 1 (2.5), 108^†^ | 2 (2.6), 118^†^ | CalcMeanDiff: −1.05 (−1.72 to −0.38)^†^ | 0.01
Alcohol abstinence | Harris, 2012^80^ | Cessation of use | 1 year | IG1 (Prague - Any BL alcohol use) | 12 | 5/153 (3.3) | 9/163 (5.5) | OR: 0.58 (0.19 to 1.77) | NR, NS
Alcohol abstinence | Harris, 2012^80^ | Cessation of use | 1 year | IG1 (New England - Any BL alcohol use) | 12 | 38/194 (19.6) | 48/240 (20.0) | OR: 0.97 (0.61 to 1.57) | NR, NS
Alcohol any use | Baldus, 2016^81^ | Self-reported lifetime use | Lifetime | IG1 (Overall) | 0 | 34/147 (23.3) | 29/145 (20.4) | OR: 1.20 (0.69 to 2.11) | 0.557
Alcohol any use | Baldus, 2016^81^ | Self-reported lifetime use | Lifetime | IG1 (Overall) | 20 | 72/135 (53.3) | 67/127 (52.8) | OR: 0.82 (0.45 to 1.52) | 0.531
Alcohol any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 0 | 10/147 (7.1) | 9/145 (6.1) | OR: 1.10 (0.43 to 2.80) | NSD
Alcohol any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 8 | 14/147 (9.6) | 9/145 (6.2) | OR: 1.16 (0.44 to 3.09) | 0.759
Alcohol any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 20 | 30/147 (20.5) | 26/145 (17.6) | OR: 1.07 (0.56 to 2.06) | 0.41
Alcohol any use | Barlow, 2013^83^ | Any alcohol use in past month | 1 month | IG1 (Overall) | 0 | 7/159 (4.4) | 5/163 (3.1) | OR: 0.77 (0.19 to 3.14) | 0.71
Alcohol any use | Barlow, 2013^83^ | Any alcohol use in past month | 1 month | IG1 (Overall) | 4 | 28/159 (17.9) | 29/163 (17.8) | OR: 0.80 (0.35 to 1.83) | 0.60
Alcohol any use | Barlow, 2013^83^ | Any alcohol use in past month | 1 month | IG1 (Overall) | 8 | 27/159 (16.9) | 33/163 (20.0) | OR: 0.71 (0.36 to 1.40) | 0.33
Alcohol any use | Barlow, 2013^83^ | Any alcohol use in past month | 1 month | IG1 (Overall) | 14 | 41/159 (25.8) | 35/163 (21.6) | OR: 1.14 (0.63 to 2.05) | 0.67
Alcohol any use | Barlow, 2013^83^ | Any alcohol use in past month | 1 month | IG1 (Overall) | 38 | 26/159 (16.5) | 26/163 (15.7) | OR: 1.06 (0.80 to 1.41) | 0.68
Alcohol any use | Foxcroft, 2017^93^ | Lifetime alcohol use, lifetime prevalence | Lifetime | IG1 (Overall) | 0 | 86/338 (25.4) | 48/241 (19.9) | OR: 1.37 (0.92 to 2.05) | NSD
Alcohol any use | Foxcroft, 2017^93^ | Lifetime alcohol use, lifetime prevalence | Lifetime | IG1 (Overall) | 12 | 67/233 (28.8) | 36/194 (18.6) | OR: 1.36 (0.77 to 2.44) | NSD
Alcohol any use | Foxcroft, 2017^93^ | Lifetime alcohol use, lifetime prevalence | Lifetime | IG1 (Overall) | 24 | 61/174 (35.1) | 45/154 (29.2) | OR: 0.93 (0.56 to 1.55) | NSD
Alcohol any use | Foxcroft, 2017^93^ | Past month alcohol use, 30-day prevalence | 1 month | IG1 (Overall) | 0 | 22/329 (6.7) | 8/241 (3.3) | OR: 2.09 (0.91 to 4.77) | NSD
Alcohol any use | Foxcroft, 2017^93^ | Past month alcohol use, 30-day prevalence | 1 month | IG1 (Overall) | 12 | 16/225 (7.1) | 12/192 (6.3) | OR: 0.98 (0.41 to 2.24) | NSD
Alcohol any use | Foxcroft, 2017^93^ | Past month alcohol use, 30-day prevalence | 1 month | IG1 (Overall) | 24 | 20/169 (11.8) | 16/150 (10.7) | OR: 0.98 (0.50 to 1.93) | NSD
Alcohol any use | Harris, 2012^80^ | Alcohol initiation | 1 year | IG1 (New England - No BL alcohol use) | 12 | 68/571 (11.9) | 92/518 (17.8) | OR: 0.63 (0.45 to 0.88) | <0.05
Alcohol any use | Harris, 2012^80^ | Alcohol initiation | 1 year | IG1 (Prague - No BL alcohol use) | 12 | 37/111 (33.3) | 35/103 (43.7) | OR: 0.97 (0.55 to 1.71) | NR, NS
Alcohol any use | Harris, 2012^80^ | Any past-12-month use | 1 year | IG1 (Prague) | 0 | 153/264 (58.0) | 163/266 (61.3) | OR: 0.87 (0.62 to 1.23) | NR, NS
Alcohol any use | Harris, 2012^80^ | Any past-12-month use | 1 year | IG1 (New England) | 0 | 194/765 (25.4) | 240/758 (31.7) | OR: 0.73 (0.59 to 0.92) | NR, NS
Alcohol any use | Harris, 2012^80^ | Any past-12-month use | 1 year | IG1 (Prague) | 12 | 185/264 (70.1) | 199/266 (74.8) | OR: 0.79 (0.54 to 1.16) | NR, NS
Alcohol any use | Harris, 2012^80^ | Any past-12-month use | 1 year | IG1 (New England) | 12 | 224/765 (29.3) | 284/758 (37.5) | OR: 0.69 (0.56 to 0.86) | <0.05
Alcohol any use | Harris, 2012^80^ | Any past 90-day use | 3 months | IG1 (New England) | 3 | 118/761 (15.5) | 173/755 (22.9) | OR: 0.62 (0.48 to 0.80) | <0.05
Alcohol any use | Harris, 2012^80^ | Any past 90-day use | 3 months | IG1 (Prague) | 3 | 126/271 (46.5) | 127/245 (51.8) | OR: 0.81 (0.57 to 1.14) | NR, NS
Alcohol any use | Kerr, 2013^97^ | Lifetime alcohol | Lifetime | IG1 (Overall) | 12 | ./834 (.) | ./820 (.) | Regression coefficient: 0.00 | NR, NS
Alcohol any use | Kerr, 2013^97^ | Past month alcohol; continuous item asking the number of days the participant consumed alcohol | 1 month | IG1 (Overall) | 12 | ./834 (.) | ./820 (.) | Regression coefficient: 0.03 | NR, NS
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Overall) | 3 | 115/626 (18.4) | 70/243 (28.8) | 70/243 (0.3) | <0.05
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Overall) | 6 | 191/626 (30.5) | 84/243 (34.6) | OR: 0.83 (0.61 to 1.14) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Overall) | 9 | 230/626 (36.7) | 102/243 (42.0) | OR: 0.80 (0.59 to 1.09) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Overall) | 12 | 273/626 (43.6) | 118/243 (48.6) | OR: 0.82 (0.61 to 1.10) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 3 | 84/148 (56.8) | 47/63 (74.6) | OR: 0.45 (0.23 to 0.86) | <0.05
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (No alcohol or other drug use in past 12 months at baseline) | 3 | 31/478 (6.5) | 23/180 (12.8) | OR: 0.47 (0.27 to 0.84) | <0.05
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 6 | 116/148 (78.4) | 53/63 (84.1) | OR: 0.68 (0.31 to 1.49) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (No alcohol or other drug use in past 12 months at baseline) | 6 | 75/478 (15.7) | 31/180 (17.2) | OR: 0.89 (0.57 to 1.42) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 9 | 125/148 (84.5) | 58/63 (92.1) | OR: 0.47 (0.17 to 1.29) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (No alcohol or other drug use in past 12 months at baseline) | 9 | 105/478 (22.0) | 44/180 (24.4) | OR: 0.87 (0.58 to 1.30) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 12 | 131/148 (88.5) | 59/63 (93.7) | HR: 0.69 (0.47 to 1.02) | NSD
Alcohol any use | Knight, 2019^72^ | Number with any alcohol use | 1 year | IG1 (No alcohol or other drug use in past 12 months at baseline) | 12 | 142/478 (29.7) | 59/180 (32.8) | HR: 0.87 (0.57 to 1.31) | NSD
Alcohol any use | Malmberg, 2014^102^ | Any alcohol use in the past month Positive response for “I drank alcohol 1-2 in the past month” or more use. | 1 month | IG1 (Overall) | 0 | 126/1225 (10.3) | 119/1191 (10.0) | OR: 1.03 (0.53 to 1.99) | NSD
Alcohol any use | Malmberg, 2014^102^ | Any alcohol use in the past month Positive response for “I drank alcohol 1-2 in the past month” or more use. | 1 month | IG1 (Overall) | 8 | 186/1114 (16.7) | 171/1109 (15.4) | OR: 1.08 (0.61 to 1.89) | 0.136
Alcohol any use | Malmberg, 2014^102^ | Any alcohol use in the past month Positive response for “I drank alcohol 1-2 in the past month” or more use. | 1 month | IG1 (Overall) | 20 | 315/1003 (31.4) | 251/982 (25.6) | OR: 1.36 (0.83 to 2.21) | 0.136
Alcohol any use | Malmberg, 2014^102^ | Any alcohol use in the past month Positive response for “I drank alcohol 1-2 in the past month” or more use. | 1 month | IG1 (Overall) | 32 | 491/825 (59.5) | 365/692 (52.7) | OR: 1.31 (0.79 to 2.18) | 0.136
Alcohol any use | Malmberg, 2014^102^ | Lifetime prevalence Ever consumed a glass of alcohol in their life | Lifetime | IG1 (Overall) | 0 | 348/1225 (28.4) | 303/1191 (25.4) | OR: 1.16 (0.74 to 1.81) | NSD
Alcohol any use | Malmberg, 2014^102^ | Lifetime prevalence Ever consumed a glass of alcohol in their life | Lifetime | IG1 (Overall) | 8 | 430/1114 (38.6) | 383/1109 (34.5) | OR: 1.18 (0.77 to 1.82) | 0.236
Alcohol any use | Malmberg, 2014^102^ | Lifetime prevalence Ever consumed a glass of alcohol in their life | Lifetime | IG1 (Overall) | 20 | 583/1003 (58.1) | 487/982 (49.6) | OR: 1.40 (0.90 to 2.17) | 0.236
Alcohol any use | Malmberg, 2014^102^ | Lifetime prevalence Ever consumed a glass of alcohol in their life | Lifetime | IG1 (Overall) | 32 | 650/825 (78.8) | 518/692 (74.9) | OR: 1.25 (0.69 to 2.27) | 0.236
Alcohol any use | Walkup, 2009^113^ | Alcohol in last month | 1 month | IG1 (Overall) | 5 | 6/54 (11.0) | 5/71 (7.0) | OR: 1.52 (0.42 to 5.46) | NR, NS
Alcohol any use | Walkup, 2009^113^ | Alcohol in last month | 1 month | IG1 (Overall) | 9 | 5/47 (12.0) | 4/68 (6.0) | OR: 2.19 (0.55 to 8.78) | NR, NS
Alcohol risky use | D’Amico, 2018^116^ | Heavy alcohol use in the past 90 days | 3 months | IG1 (Overall) | 3 | 2.8 (4.6), 113^†^ | 3 (4.8), 86^†^ | CalcMeanDiff: −0.28 (−1.60 to 1.04)^†^ | 0.48
Alcohol risky use | D’Amico, 2018^116^ | Heavy alcohol use in the past 90 days | 3 months | IG1 (Overall) | 6 | 2.7 (4.7), 127^†^ | 2.7 (4.7), 111^†^ | CalcMeanDiff: 0.01 (−1.19 to 1.21)^†^ | 0.90
Alcohol risky use | D’Amico, 2018^116^ | Heavy alcohol use in the past 90 days | 3 months | IG1 (Overall) | 12 | 2.4 (4.6), 122^†^ | 2.8 (5.2), 114^†^ | CalcMeanDiff: −0.41 (−1.66 to 0.84)^†^ | 0.28
Alcohol risky use | Bannink, 2014^82^ | 5 or more drinks on 1 or more occasions in past 4 weeks | 1 month | IG1 (Overall) | 0 | 157/430 (36.5) | 140/434 (32.3) | OR: 1.21 (0.82 to 1.79) | 0.20
Alcohol risky use | Bannink, 2014^82^ | 5 or more drinks on 1 or more occasions in past 4 weeks | 1 month | IG1 (Overall) | 4 | 145/430 (33.7) | 157/434 (36.2) | OR: 0.90 (0.61 to 1.33) | 0.35
Alcohol risky use | Bannink, 2014^82^ | 5 or more drinks on 1 or more occasions in past 4 weeks | 1 month | IG2 (Overall) | 0 | 137/392 (35.0) | 140/434 (32.3) | OR: 1.14 (0.77 to 1.71) | 0.48
Alcohol risky use | Bannink, 2014^82^ | 5 or more drinks on 1 or more occasions in past 4 weeks | 1 month | IG2 (Overall) | 4 | 160/392 (41.0) | 157/434 (36.2) | OR: 1.11 (0.75 to 1.64) | 0.62
Alcohol risky use | Foxcroft, 2017^93^ | Past month binge drinking | 1 month | IG1 (Overall) | 0 | 13/328 (4.0) | 8/239 (3.4) | OR: 1.19 (0.49 to 2.92) | NSD
Alcohol risky use | Foxcroft, 2017^93^ | Past month binge drinking | 1 month | IG1 (Overall) | 12 | 13/225 (5.8) | 9/193 (4.7) | OR: 0.88 (0.33 to 2.26) | NSD
Alcohol risky use | Foxcroft, 2017^93^ | Past month binge drinking | 1 month | IG1 (Overall) | 24 | 12/170 (7.1) | 10/151 (6.6) | OR: 0.89 (0.40 to 1.92) | NSD
Alcohol risky use | Gmel, 2013^94^ | Heavy use (binge) episodes >1/mo | 6 months | IG1 (Overall) | 0 | 203/392 (51.7) | 254/461 (55.2) | OR: 0.88 (0.67 to 1.15) | NSD
Alcohol risky use | Gmel, 2013^94^ | Heavy use (binge) episodes >1/mo | 6 months | IG1 (Overall) | 6 | 140/288 (48.6) | 189/384 (49.3) | OR: 0.98 (0.72 to 1.32) | 0.559
Alcohol risky use | Gmel, 2013^94^ | Risk volume, exceeds >21 drinks/week | 6 months | IG1 (Overall) | 0 | 37/392 (9.4) | ./461 (.) | –
Alcohol risky use | Gmel, 2013^94^ | Risk volume, exceeds >21 drinks/week | 6 months | IG1 (Overall) | 6 | 23/288 (8.0) | 33/384 (8.6) | OR: 0.92 (0.53 to 1.61) | 0.784
Alcohol risky use | Knight, 2019^72^ | Number with any heavy episodic drinking | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 3 | 56/148 (37.8) | 28/63 (44.4) | OR: 0.76 (0.42 to 1.38) | NSD
Alcohol risky use | Knight, 2019^72^ | Number with any heavy episodic drinking | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 6 | 70/148 (47.3) | 38/63 (60.3) | OR: 0.59 (0.32 to 1.07) | NSD
Alcohol risky use | Knight, 2019^72^ | Number with any heavy episodic drinking | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 9 | 82/148 (55.4) | 45/63 (71.4) | OR: 0.50 (0.26 to 0.94) | <0.05
Alcohol risky use | Knight, 2019^72^ | Number with any heavy episodic drinking | 1 year | IG1 (Alcohol or other drug use in past 12 months at baseline) | 12 | 86/148 (58.1) | 48/63 (76.2) | HR: 0.66 (0.40 to 1.10) | <0.05
Alcohol risky use | Malmberg, 2014^102^ | Binge drinking (5 or more drinks on 1 occasion), in past 30 days. | 1 month | IG1 (Overall) | 0 | 85/1225 (6.9) | 70/1191 (5.9) | OR: 1.25 (0.55 to 2.83) | NSD
Alcohol risky use | Malmberg, 2014^102^ | Binge drinking (5 or more drinks on 1 occasion), in past 30 days. | 1 month | IG1 (Overall) | 8 | 118/1114 (10.6) | 100/1109 (9.0) | OR: 1.20 (0.60 to 2.42) | 0.350
Alcohol risky use | Malmberg, 2014^102^ | Binge drinking (5 or more drinks on 1 occasion), in past 30 days. | 1 month | IG1 (Overall) | 20 | 264/1003 (26.3) | 196/982 (20.0) | OR: 1.43 (0.85 to 2.42) | 0.350
Alcohol risky use | Malmberg, 2014^102^ | Binge drinking (5 or more drinks on 1 occasion), in past 30 days. | 1 month | IG1 (Overall) | 32 | 381/825 (46.2) | 257/692 (37.1) | OR: 1.45 (0.86 to 2.42) | 0.350
Alcohol risky use | Sanci, 2015^106^ | ≥ month use or any binge use (age 14-15); ≥ 3x/week or ≥ monthly binge use (age 16-24) | 1 year | IG1 (Overall) | 0 | 154/377 (42.4) | 210/524 (41.8) | OR: 1.03 (0.70 to 1.53) | NSD
Alcohol risky use | Sanci, 2015^106^ | ≥ month use or any binge use (age 14-15); ≥ 3x/week or ≥ monthly binge use (age 16-24) | 1 month | IG1 (Overall) | 3 | 129/377 (34.1) | 204/524 (39.0) | OR: 0.77 (0.55 to 1.06) | 0.11
Alcohol risky use | Sanci, 2015^106^ | ≥ month use or any binge use (age 14-15); ≥ 3x/week or ≥ monthly binge use (age 16-24) | 1 month | IG1 (Overall) | 12 | 121/377 (32.1) | 182/524 (34.7) | OR: 0.84 (0.61 to 1.15) | 0.28
Alcohol severity | Jalling, 2016^95^ | AUDIT, total score; 0-44 (Low) | NR | IG1 (Overall) | 6 | −0.5 (7), 70 | 0.2 (6.5), 81 | CalcMeanDiffChg: −0.71 (−2.88 to 1.46) | NR, NS
Alcohol severity | Jalling, 2016^95^ | AUDIT, total score; 0-40 (Low) | NR | IG2 (Overall) | 6 | 1.4 (7), 86 | 0.2 (6.5), 81 | CalcMeanDiffChg: 1.17 (−0.89 to 3.23) | 0.06
Alcohol severity | Walton, 2014^115^ | Frequency, quantity, and heavy drinking; 0-13 (Low) | 3 months | IG1 (Overall) | 3 | . (.), 199 | . (.), 216 | IRRnegbin: 1.38 (0.78 to 2.43) | NR, NS
Alcohol severity | Walton, 2014^115^ | Frequency, quantity, and heavy drinking; 0-13 (Low) | 3 months | IG1 (Overall) | 6 | . (.), 200 | . (.), 211 | IRRnegbin: 0.57 (0.36 to 0.91) | <0.05
Alcohol severity | Walton, 2014^115^ | Frequency, quantity, and heavy drinking; 0-13 (Low) | 3 months | IG1 (Overall) | 12 | . (.), 201 | . (.), 207 | IRRnegbin: 1.36 (0.84 to 2.23) | NR, NS
Alcohol severity | Walton, 2014^115^ | Frequency, quantity, and heavy drinking; 0-13 (Low) | 3 months | IG2 (Overall) | 3 | . (.), 220 | . (.), 216 | IRRnegbin: 0.93 (0.52 to 1.68) | NR, NS
Alcohol severity | Walton, 2014^115^ | Frequency, quantity, and heavy drinking; 0-13 (Low) | 3 months | IG2 (Overall) | 6 | . (.), 218 | . (.), 211 | IRRnegbin: 0.66 (0.42 to 1.04) | NR, NS
Alcohol severity | Walton, 2014^115^ | Frequency, quantity, and heavy drinking; 0-13 (Low) | 3 months | IG2 (Overall) | 12 | . (.), 220 | . (.), 207 | IRRnegbin: 1.22 (0.75 to 1.99) | NR, NS
Alcohol frequency/quantity - times used | D’Amico, 2018^116^ | Times used alcohol in past 90 days | 3 months | IG1 (Overall) | 3 | 5.2 (5.6), 113^†^ | 5.6 (5.8), 86^†^ | CalcMeanDiff: −0.46 (−2.07 to 1.15)^†^ | 0.22
Alcohol frequency/quantity - times used | D’Amico, 2018^116^ | Times used alcohol in past 90 days | 3 months | IG1 (Overall) | 6 | 4.7 (5.9), 127^†^ | 5.4 (6.4), 111^†^ | CalcMeanDiff: −0.72 (−2.29 to 0.85)^†^ | 0.12
Alcohol frequency/quantity - times used | D’Amico, 2018^116^ | Times used alcohol in past 90 days | 3 months | IG1 (Overall) | 12 | 4.5 (5.7), 122^†^ | 5.1 (6.4), 114^†^ | CalcMeanDiff: −0.55 (−2.10 to 1.00)^†^ | 0.15
Alcohol frequency/quantity - times used | Estrada, 2018^90^ | Times used alcohol in past 90 days | 3 months | IG1 (Overall) | 3 | 0.1 (1.4), 84 | −0.1 (8.3), 101 | CalcMeanDiffChg: 0.24 (−1.41 to 1.89) | 0.623
Alcohol frequency/quantity - times used | Estrada, 2018^90^ | Times used alcohol in past 90 days | 3 months | IG1 (Overall) | 12 | 0.1 (1.5), 82 | −0.6 (8.7), 98 | EffectSize: 0.75 (−1.01 to 2.51) | 0.623
Alcohol frequency/quantity - times used | Fang, 2010^92^ | Number of drinks in past 30-days | 3 months | IG1 (Overall) | 6 | 0.1 (.9), 54 | 1.4 (5), 50 | CalcMeanDiffChg: −1.26 (−2.67 to 0.15) | 0.016
Alcohol frequency/quantity - times used | Fang, 2010^92^ | Number of drinks in past 30-days | 3 months | IG1 (Overall) | 12 | 0 (0.6), 54 | 0.8 (3.9), 50 | CalcMeanDiffChg: −0.75 (−1.85 to 0.35) | 0.038
Alcohol frequency/quantity - times used | Fang, 2010^92^ | Number of drinks in past 30-days | 3 months | IG1 (Overall) | 24 | 0 (0.8), 50 | −0.6 (7.9), 43 | CalcMeanDiffChg: 0.60 (−1.77 to 2.97) | 0.038
Alcohol frequency/quantity - times used | Gmel, 2013^94^ | Number of drinks per week | 3 months | IG1 (Overall) | 6 | −0.2 (.), 288 | −0.1 (.), 384 | Beta: −0.19 (−0.93 to 0.56) | 0.627
Alcohol frequency/quantity - times used | Johnson, 2015^96^ | Times used in the past 30 days (if age less than 21) | 3 months | IG1 (Overall) | 6 | −0.4 (5.2), 101 | 0.8 (8.5), 99 | RRnegbin: 4.26 (2.58 to 7.08) | NR, NS
Alcohol frequency/quantity - times used | Rhee, 2008^105^ | Estimated total number of alcoholic drinks consumed in the past year | 3 months | IG1 (Overall) | 2 | 1 (7.5), 17 | −2.8 (35), 18 | CalcMeanDiffChg: 3.79 (−12.76 to 20.33) | NR, NS
Alcohol frequency/quantity - times used | Rhee, 2008^105^ | Estimated total number of alcoholic drinks consumed in the past year | 3 months | IG1 (Overall) | 4 | 2.8 (11.4), 17 | -7 (36.2), 18 | CalcMeanDiffChg: 9.82 (−7.75 to 27.40) | NR, NS
Alcohol frequency/quantity - times used | Rhee, 2008^105^ | Estimated total number of alcoholic drinks consumed in the past year | 3 months | IG1 (Overall) | 6 | 2.5 (9.7), 17 | −8.6 (38), 18 | CalcMeanDiffChg: 11.13 (−7.04 to 29.29) | NR, NS
Alcohol frequency/quantity - times used | Schinke, 2009a^107^ | Reported use occasions in past 30 days | 3 months | IG1 (Overall) | 12 | 0.3 (0.9), 205 | 0.7 (1.8), 327 | TxtEffectEst: −0.42 (−0.65 to −0.19) | <0.05
Alcohol frequency/quantity - times used | Schinke, 2009b^108^ | Times used in past 30 days | 3 months | IG1 (Overall) | 12 | 0 (0.6), 434 | 0.2 (1.3), 430 | CalcMeanDiffChg: −0.18 (−0.32 to −0.04) | <0.006
Alcohol frequency/quantity - times used | Schinke, 2009b^108^ | Times used in past 30 days | 3 months | IG1 (Overall) | 24 | 0.1 (0.8), 415 | 0.4 (1.8), 413 | CalcMeanDiffChg: −0.36 (−0.55 to −0.17) | <0.006
Alcohol frequency/quantity - times used | Schwinn, 2010^110^ | Report how many times in the past month any drug was used. | 3 months | IG1 (Overall) | 6 | 1.3 (6.5), 108^†^ | 3.2 (6.8), 118^†^ | CalcMeanDiff: −1.89 (−3.64 to −0.14)^†^ | 0.05
Alcohol frequency/quantity - times used | Schwinn, 2015^112^ | 30-day alcohol use | 3 months | IG1 (Overall) | 3 | 0.5 (6.1), 97 | 1.1 (5.5), 103 | CalcMeanDiffChg: −0.57 (−2.19 to 1.05) | NR, NS
Alcohol frequency/quantity - times used | Schwinn, 2018^111^ | Times used in past month | 3 months | IG1 (Overall) | 3 | −1.3 (15.1), 376 | −0.8 (12.9), 380 | Bweight: −0.36 (−1.36 to 0.64) | NR, NS
Alcohol frequency/quantity - times used | Schwinn, 2018^111^ | Times used in past month | 3 months | IG1 (Overall) | 15 | −0.6 (14.7), 370 | 0.5 (12.4), 382 | Bweight: −0.84 (−1.78 to 0.10) | NR, NS
Alcohol frequency/quantity - times used | Kim, 2011^98^ | Alcohol use in past year (1=never, 9=daily); 1-9 (Low) | 1 year | IG1 (Overall) | 36 | 1.5 (0.9), 45^†^ | 1.8 (1.5), 52^†^ | CohensD: −0.31 (−0.79 to 0.17)^†^ | NS
Alcohol frequency/quantity - score | Mason, 2015^103^ | Participants were asked the number of days they have used alcohol within the last month, coded as 0= 0 days, 1= 1 or 2 days, 3= 3 to 5 days, 4=6 to 9 days, 5=10 to 19 days, 6=20 to 29 days, and 7=all 30 days.; 0-7 (Low) | 1 month | IG1 (Overall) | 6 | . (.), 57 | . (.), 60 | TxtEffectEst: −0.20 (−0.42 to 0.02) | <0.10
Alcohol frequency/quantity - score | Mason, 2015^103^ | Participants were asked the number of days they have used alcohol within the last month, coded as 0= 0 days, 1= 1 or 2 days, 3= 3 to 5 days, 4=6 to 9 days, 5=10 to 19 days, 6=20 to 29 days, and 7=all 30 days.; 0-7 (Low) | 1 month | IG1 (Male) | 3 | −0.1 (.), 15 | 0.1 (.), 20 | – | 0.08
Alcohol frequency/quantity - score | Mason, 2015^103^ | Participants were asked the number of days they have used alcohol within the last month, coded as 0= 0 days, 1= 1 or 2 days, 3= 3 to 5 days, 4=6 to 9 days, 5=10 to 19 days, 6=20 to 29 days, and 7=all 30 days.; 0-7 (Low) | 1 month | IG1 (Female) | 3 | 0 (.), 44 | −0.2 (.), 40 | – | 0.24
Alcohol frequency/quantity - score | Mason, 2015^103^ | Participants were asked the number of days they have used alcohol within the last month, coded as 0= 0 days, 1= 1 or 2 days, 3= 3 to 5 days, 4=6 to 9 days, 5=10 to 19 days, 6=20 to 29 days, and 7=all 30 days.; 0-7 (Low) | 1 month | IG1 (Male) | 6 | −0.3 (.), 15 | 0.3 (.), 20 | – | 0.08
Alcohol frequency/quantity - score | Mason, 2015^103^ | Participants were asked the number of days they have used alcohol within the last month, coded as 0= 0 days, 1= 1 or 2 days, 3= 3 to 5 days, 4=6 to 9 days, 5=10 to 19 days, 6=20 to 29 days, and 7=all 30 days.; 0-7 (Low) | 1 month | IG1 (Female) | 6 | 0.1 (.), 44 | −0.4 (.), 40 | – | 0.24
Alcohol frequency/quantity - score | Walton, 2013^114^ | Past 3-month alcohol frequency.; 0-4 (Low) | 3 months | IG1 (Overall) | 3 | 0 (0.9), 101 | −0.2 (1.1), 96 | TxtEffectEst: 0.16 (−0.21 to 0.53) | 0.39
Alcohol frequency/quantity - score | Walton, 2013^114^ | Past 3-month alcohol frequency.; 0-4 (Low) | 3 months | IG1 (Overall) | 6 | 0 (0.9), 102 | 0 (1.2), 97 | TxtEffectEst: −0.02 (−0.39 to 0.35) | 0.94
Alcohol frequency/quantity - score | Walton, 2013^114^ | Past 3-month alcohol frequency.; 0-4 (Low) | 3 months | IG1 (Overall) | 12 | 0.1 (1), 104 | −0.2 (1), 94 | TxtEffectEst: 0.37 (0.00 to 0.74) | 0.05
Alcohol frequency/quantity - score | Walton, 2013^114^ | Past 3-month alcohol frequency.; 0-4 (Low) | 3 months | IG2 (Overall) | 3 | −0.3 (1), 82 | −0.2 (1.1), 96 | TxtEffectEst: −0.19 (−0.58 to 0.20) | 0.34
Alcohol frequency/quantity - score | Walton, 2013^114^ | Past 3-month alcohol frequency.; 0-4 (Low) | 3 months | IG2 (Overall) | 6 | −0.2 (1), 79 | 0 (1.2), 97 | TxtEffectEst: −0.25 (−0.64 to 0.14) | 0.22
Alcohol frequency/quantity - score | Walton, 2013^114^ | Past 3-month alcohol frequency.; 0-4 (Low) | 3 months | IG2 (Overall) | 12 | −0.3 (1), 77 | −0.2 (1), 94 | TxtEffectEst: −0.16 (−0.55 to 0.23) | 0.44
Tobacco any use | Baldus, 2016^81^ | Self-reported lifetime use | Lifetime | IG1 (Overall) | 0 | 23/147 (15.8) | 24/145 (17.0) | OR: 0.94 (0.50 to 1.75) | 0.772
Tobacco any use | Baldus, 2016^81^ | Self-reported lifetime use | Lifetime | IG1 (Overall) | 20 | 46/132 (34.9) | 56/129 (43.4) | OR: 0.63 (0.37 to 1.07) | 0.085
Tobacco any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 0 | 10/147 (7.0) | 8/145 (5.7) | OR: 1.25 (0.48 to 3.26) | NSD
Tobacco any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 8 | 14/147 (9.6) | 13/145 (9.2) | OR: 1.09 (0.52 to 2.31) | 0.820
Tobacco any use | Baldus, 2016^81^ | Self-reported past 30-day use | 1 month | IG1 (Overall) | 20 | 25/147 (16.7) | 24/145 (16.5) | OR: 0.72 (0.37 to 1.39) | 0.324
Tobacco any use | Bannink, 2014^82^ | Regular smokers, smoking anywhere from less than once a week to every day. | NR | IG1 (Overall) | 0 | 77/430 (18.0) | 80/434 (18.4) | OR: 0.98 (0.61 to 1.59) | 0.92
Tobacco any use | Bannink, 2014^82^ | Regular smokers, smoking anywhere from less than once a week to every day. | NR | IG1 (Overall) | 4 | 74/430 (17.2) | 83/434 (19.1) | OR: 0.95 (0.58 to 1.57) | 0.84
Tobacco any use | Bannink, 2014^82^ | Regular smokers, smoking anywhere from less than once a week to every day. | NR | IG2 (Overall) | 0 | 63/392 (16.1) | 80/434 (18.4) | OR: 0.84 (0.51 to 1.40) | 0.39
Tobacco any use | Bannink, 2014^82^ | Regular smokers, smoking anywhere from less than once a week to every day. | NR | IG2 (Overall) | 4 | 67/392 (17.1) | 83/434 (19.1) | OR: 0.97 (0.61 to 1.56) | 0.90
Tobacco any use | Foxcroft, 2017^93^ | Past month cigarette use, prevalence | 1 month | IG1 (Overall) | 0 | 21/329 (6.4) | 6/240 (2.5) | OR: 2.66 (1.06 to 6.69) | <0.05
Tobacco any use | Foxcroft, 2017^93^ | Past month cigarette use, prevalence | 1 month | IG1 (Overall) | 12 | 21/229 (9.2) | 11/192 (5.7) | OR: 1.13 (0.47 to 2.77) | NR, NS
Tobacco any use | Foxcroft, 2017^93^ | Past month cigarette use, prevalence | 1 month | IG1 (Overall) | 24 | 22/173 (12.7) | 9/154 (5.8) | OR: 1.31 (0.56 to 2.99) | NR, NS
Tobacco any use | Gmel, 2013^94^ | Past 6 months smoking | 6 months | IG1 (Overall) | 0 | 208/392 (53.1) | 254/461 (55.2) | OR: 0.92 (0.70 to 1.21) | NSD
Tobacco any use | Gmel, 2013^94^ | Past 6 months smoking | 6 months | IG1 (Overall) | 6 | 142/288 (49.3) | 203/384 (52.9) | OR: 0.87 (0.64 to 1.18) | 0.486
Tobacco any use | Kerr, 2013^97^ | Lifetime tobacco | Lifetime | IG1 (Overall) | 12 | ./834 (.) | ./820 (.) | Regression coefficient: 0.01 | NR, NS
Tobacco any use | Kerr, 2013^97^ | Past month tobacco; continuous item assessing number of days that the participant smoked | 1 month | IG1 (Overall) | 12 | ./834 (.) | ./820 (.) | Regression coefficient: 0.06 | NR, NS
Tobacco any use | Malmberg, 2014^102^ | Any lifetime use | Lifetime | IG1 (Overall) | 0 | 277/1225 (22.6) | 206/1191 (17.3) | OR: 1.42 (0.86 to 2.34) | NSD
Tobacco any use | Malmberg, 2014^102^ | Any lifetime use | Lifetime | IG1 (Overall) | 8 | 342/1114 (30.7) | 283/1109 (25.5) | OR: 1.28 (0.81 to 2.04) | 0.842
Tobacco any use | Malmberg, 2014^102^ | Any lifetime use | Lifetime | IG1 (Overall) | 20 | 392/1003 (39.1) | 316/982 (32.2) | OR: 1.34 (0.84 to 2.11) | 0.842
Tobacco any use | Malmberg, 2014^102^ | Any lifetime use | Lifetime | IG1 (Overall) | 32 | 399/825 (48.4) | 274/692 (39.6) | OR: 1.41 (0.85 to 2.35) | 0.842
Tobacco any use | Malmberg, 2014^102^ | Regular tobacco users “I smoke occasionally, but not every day” and “I smoke at least once a day” | 1 month | IG1 (Overall) | 0 | 53/1225 (4.3) | 46/1191 (3.9) | OR: 1.26 (0.46 to 3.45) | NSD
Tobacco any use | Malmberg, 2014^102^ | Regular tobacco users “I smoke occasionally, but not every day” and “I smoke at least once a day” | 1 month | IG1 (Overall) | 8 | 128/1114 (11.5) | 82/1109 (7.4) | OR: 1.69 (0.82 to 3.48) | 0.959
Tobacco any use | Malmberg, 2014^102^ | Regular tobacco users “I smoke occasionally, but not every day” and “I smoke at least once a day” | 1 month | IG1 (Overall) | 20 | 155/1003 (15.5) | 141/982 (14.4) | OR: 1.08 (0.58 to 1.99) | 0.959
Tobacco any use | Malmberg, 2014^102^ | Regular tobacco users “I smoke occasionally, but not every day” and “I smoke at least once a day” | 1 month | IG1 (Overall) | 32 | 199/825 (24.1) | 120/692 (17.3) | OR: 1.53 (0.81 to 2.89) | 0.959
Tobacco any use | Sanci, 2015^106^ | Any use in last 12 months | 1 year | IG1 (Overall) | 0 | 140/377 (37.2) | 210/524 (40.4) | OR: 0.88 (0.59 to 1.30) | NSD
Tobacco any use | Sanci, 2015^106^ | Tobacco smoking use in last month | 1 month | IG1 (Overall) | 3 | 89/377 (23.5) | 135/524 (25.8) | OR: 0.90 (0.62 to 1.31) | 0.60
Tobacco any use | Sanci, 2015^106^ | Tobacco smoking use in last month | 1 month | IG1 (Overall) | 12 | 82/377 (21.8) | 142/524 (27.1) | OR: 0.78 (0.55 to 1.12) | 0.18
Tobacco any use | Walkup, 2009^113^ | Cigarette use in last month | 1 month | IG1 (Overall) | 5 | 7/54 (13.0) | 12/71 (17.0) | OR: 0.74 (0.24 to 2.30) | NR, NS
Tobacco any use | Walkup, 2009^113^ | Cigarette use in last month | 1 month | IG1 (Overall) | 9 | 9/47 (22.0) | 8/68 (13.0) | OR: 2.06 (0.64 to 6.62) | NR, NS
Tobacco frequency/quantity - times used | Estrada, 2018^90^ | Times used tobacco in past 90 days | 3 months | IG1 (Overall) | 3 | 0.7 (9.4), 84 | 0.8 (10.8), 101 | CalcMeanDiffChg: −0.16 (−3.07 to 2.75) | <0.01
Tobacco frequency/quantity - times used | Estrada, 2018^90^ | Times used tobacco in past 90 days | 3 months | IG1 (Overall) | 12 | −0.5 (4.7), 82 | −0.1 (8), 98 | EffectSize: −0.47 (−2.35 to 1.41) | <0.01
Tobacco frequency/quantity - times used | Fang, 2010^92^ | Past 30-day use occasions | 3 months | IG1 (Overall) | 6 | −0.2 (1.1), 54 | 5 (29.5), 50 | CalcMeanDiffChg: −5.16 (−13.33 to 3.01) | 0.06
Tobacco frequency/quantity - times used | Fang, 2010^92^ | Past 30-day use occasions | 3 months | IG1 (Overall) | 12 | −0.2 (1.1), 54 | 0.8 (4.1), 50 | CalcMeanDiffChg: −0.96 (−2.14 to 0.22) | 0.171
Tobacco frequency/quantity - times used | Fang, 2010^92^ | Past 30-day use occasions | 3 months | IG1 (Overall) | 24 | −0.2 (1.1), 50 | 5.3 (28.4), 43 | CalcMeanDiffChg: −5.49 (−13.98 to 3.00) | 0.171
Tobacco frequency/quantity - times used | Rhee, 2008^105^ | Average number of cigarettes per day in past 30 days | 3 months | IG1 (Overall) | 2 | 1.7 (13.1), 17 | 3.7 (17), 18 | CalcMeanDiffChg: −2.04 (−12.06 to 7.98) | NR, NS
Tobacco frequency/quantity - times used | Rhee, 2008^105^ | Average number of cigarettes per day in past 30 days | 3 months | IG1 (Overall) | 4 | −1.4 (8.3), 17 | 0.9 (12.2), 18 | CalcMeanDiffChg: −2.28 (−9.17 to 4.61) | NR, NS
Tobacco frequency/quantity - times used | Rhee, 2008^105^ | Average number of cigarettes per day in past 30 days | 3 months | IG1 (Overall) | 6 | 0.7 (13.1), 17 | 1.3 (12.4), 18 | CalcMeanDiffChg: −0.60 (−9.05 to 7.85) | NR, NS
Tobacco frequency/quantity - times used | Schinke, 2009a^107^ | 30-day use occasions of cigarettes | 3 months | IG1 (Overall) | 12 | 0.1 (1.3), 205 | 0.2 (2.9), 327 | TxtEffectEst: −0.18 (−0.54 to 0.18) | NR, NS
Tobacco frequency/quantity - times used | Schinke, 2009b^108^ | Times used in past 30 days | 3 months | IG1 (Overall) | 12 | 2.6 (1), 434 | 2.9 (3.2), 430 | CalcMeanDiffChg: −0.24 (−0.56 to 0.08) | NR, NS
Tobacco frequency/quantity - times used | Schinke, 2009b^108^ | Times used in past 30 days | 3 months | IG1 (Overall) | 24 | 2.7 (1.3), 415 | 3.6 (10.4), 413 | CalcMeanDiffChg: −0.90 (−1.91 to 0.11) | NR, NS
Tobacco frequency/quantity - times used | Schwinn, 2010^110^ | Report how many times in the past month any drug was used. | 3 months | IG1 (Overall) | 6 | 4.7 (15.3), 108^†^ | 4.2 (16), 118^†^ | CalcMeanDiff: 0.54 (−3.53 to 4.61)^†^ | 0.82
Tobacco frequency/quantity - times used | Schwinn, 2015^112^ | 30-day cigarette use | 3 months | IG1 (Overall) | 3 | −0.5 (6.3), 97 | −0.1 (6.7), 103 | CalcMeanDiffChg: −0.33 (−2.13 to 1.47) | NR, NS
Tobacco frequency/quantity - times used | Schwinn, 2018^111^ | Times used tobacco in past month | 3 months | IG1 (Overall) | 3 | −2.2 (16.5), 376 | −1.1 (14.7), 380 | Bweight: −2.61 (−4.32 to −0.90) | <0.01
Tobacco frequency/quantity - times used | Schwinn, 2018^111^ | Times used tobacco in past month | 3 months | IG1 (Overall) | 15 | −1.7 (15.7), 370 | 0.6 (15.5), 382 | Bweight: −3.36 (−5.36 to −1.36) | <0.01
Tobacco frequency/quantity - score | Kim, 2011^98^ | Tobacco use in past year (1=never, 9=daily); 1-9 (Low) | 1 year | IG1 (Overall) | 36 | 1.5 (1.6), 48^†^ | 2.4 (2.5), 52^†^ | CohensD: −0.87 (−1.69 to −0.05)^†^ | 0.04

* Author reported.

† Mean value at followup, rather than change from baseline.

Abbreviations: AUDIT = Alcohol Use Disorder Test; BL = Baseline; Bweight = Beta weight; CalcMeanDiff = Calculated Mean Difference; CalcMeanDiffChg = Calculated Mean Difference in Change; CG = Control group; CohensD = Cohen’s d; EffectSize = Effect size; FU = Followup; IG = Intervention group; ; IRRnegbin = Incident rate ratio (negative binomial); NR = Not reported; NS = Not significant; NSD = No significant difference; OR = Odds ratio; RRnegbin = Risk Ratio (negative binomial); SD = Standard deviation; TxtEffectEst = Treatment effect estimate.

Appendix D. Table 7 Other Behavioral Outcomes (KQ2)

Outcome | Author, year | Outcome description (direction of better outcome) | Recall period | Group | FU, mo | IG n/n (%) or Mean (SD), n | CG n/n (%) or Mean (SD), n | Effect | p^*^
Condom use | Bannink, 2014^82^ | Always use a condom during intercourse | NR | IG1 (Overall) | 0 | 68/130 (52.3) | 49/96 (51.0) | OR: 1.05 (0.50 to 2.19) | 0.55
Condom use | Bannink, 2014^82^ | Always use a condom during intercourse | NR | IG1 (Overall) | 4 | 66/151 (43.7) | 43/106 (40.6) | OR: 1.36 (0.76 to 2.44) | 0.31
Condom use | Bannink, 2014^82^ | Always use a condom during intercourse | NR | IG2 (Overall) | 0 | 52/98 (53.1) | 49/96 (51.0) | OR: 1.08 (0.49 to 2.37) | 0.50
Condom use | Bannink, 2014^82^ | Always use a condom during intercourse | NR | IG2 (Overall) | 4 | 62/119 (52.1) | 43/106 (40.6) | OR: 2.09 (1.04 to 4.22) | 0.04
Condom use | Estrada, 2018^90^ | Condomless sex; items asked whether participants had oral, vaginal, or anal sex in the previous 90 days, and if they responded yes, then whether they used a condom during their last sexual encounter, measured on a 5-point scale. Frequency of condom use was rated on a scale from 0 (Never) - 4 (Always); 0-4 (High) | 3 months | IG1 (Overall) | 3 | 0 (0.6), 20 | 0 (0.6), 19 | CalcMeanDiffChg: 0.01 (−0.38 to 0.40) | 0.89
Condom use | Estrada, 2018^90^ | Condomless sex; items asked whether participants had oral, vaginal, or anal sex in the previous 90 days, and if they responded yes, then whether they used a condom during their last sexual encounter, measured on a 5-point scale. Frequency of condom use was rated on a scale from 0 (Never) - 4 (Always); 0-4 (High) | 3 months | IG1 (Overall) | 12 | 0.2 (0.8), 21 | 0.1 (0.7), 18 | EffectSize: 0.06 (−0.40 to 0.52) | 0.89
Condom use | Sanci, 2015^106^ | Risk of STI | NR | IG1 (Overall) | 0 | 70/377 (18.7) | 92/524 (17.7) | OR: 1.09 (0.66 to 1.78) | NSD
Condom use | Sanci, 2015^106^ | Risk of STI in last 3 months | 3 months | IG1 (Overall) | 3 | 54/377 (14.3) | 101/524 (19.2) | OR: 0.70 (0.48 to 1.03) | 0.07
Condom use | Sanci, 2015^106^ | Risk of STI in last 3 months | 3 months | IG1 (Overall) | 12 | 39/377 (10.3) | 66/524 (12.6) | OR: 0.79 (0.51 to 1.24) | 0.31
Other | Sanci, 2015^106^ | Risk of unplanned pregnancy | NR | IG1 (Overall) | 0 | 53/377 (14.2) | 61/524 (11.9) | OR: 1.28 (0.73 to 2.26) | NSD
Other | Sanci, 2015^106^ | Risk of unplanned pregnancy in last 3 months | 3 months | IG1 (Overall) | 3 | 26/377 (7.0) | 43/524 (8.2) | OR: 0.85 (0.50 to 1.42) | 0.53
Other | Sanci, 2015^106^ | Risk of unplanned pregnancy in last 3 months | 3 months | IG1 (Overall) | 12 | 26/377 (6.9) | 53/524 (10.2) | OR: 0.53 (0.30 to 0.94) | 0.03
Other behavioral | Knight, 2019^72^ | Number riding in the past 3 months with a driver who had been drinking or using other drugs | 3 months | IG1 (Riding risk at baseline) | 6 | 20/44 (45.5) | 12/21 (57.1) | OR: 0.63 (0.22 to 1.78) | NSD
Other behavioral | Knight, 2019^72^ | Number riding in the past 3 months with a driver who had been drinking or using other drugs | 3 months | IG1 (No riding risk at baseline) | 6 | 35/429 (8.2) | 19/158 (12.0) | OR: 0.65 (0.36 to 1.17) | NSD
Other behavioral | Knight, 2019^72^ | Number riding in the past 3 months with a driver who had been drinking or using other drugs | 3 months | IG1 (Riding risk at baseline) | 9 | 16/39 (41.0) | 13/21 (61.9) | OR: 0.43 (0.14 to 1.27) | NSD
Other behavioral | Knight, 2019^72^ | Number riding in the past 3 months with a driver who had been drinking or using other drugs | 3 months | IG1 (No riding risk at baseline) | 9 | 33/419 (7.9) | 10/163 (6.1) | OR: 1.31 (0.63 to 2.72) | NSD
Other behavioral | Knight, 2019^72^ | Number riding in the past 3 months with a driver who had been drinking or using other drugs | 3 months | IG1 (Riding risk at baseline) | 12 | 18/47 (38.3) | 13/19 (68.4) | OR: 0.29 (0.09 to 0.89) | <0.05
Other behavioral | Knight, 2019^72^ | Number riding in the past 3 months with a driver who had been drinking or using other drugs | 3 months | IG1 (No riding risk at baseline) | 12 | 28/452 (6.2) | 11/168 (6.5) | OR: 0.94 (0.46 to 1.94) | NSD
Other behavioral | Sanci, 2015^106^ | One or more road safety risks | NR | IG1 (Overall) | 0 | 301/377 (79.8) | 408/524 (78.0) | OR: 1.11 (0.70 to 1.78) | NSD
Other behavioral | Sanci, 2015^106^ | One or more road safety risks | NR | IG1 (Overall) | 3 | 274/377 (72.6) | 372/524 (71.0) | OR: 1.08 (0.79 to 1.41) | 0.99
Other behavioral | Sanci, 2015^106^ | One or more road safety risks | NR | IG1 (Overall) | 12 | 269/377 (71.4) | 387/524 (73.9) | OR: 0.81 (0.59 to 1.11) | 0.19
Other behavioral | Walton, 2013^114^ | Driving under the influence of cannabis (cannabis DUI) in the past 3 months: never, 1-2 times, 3-5 times, 6-9 times, 10+ times; NR (Low) | 3 months | IG2 (Overall) | 3 | −0.1 (1), 82 | 0.1 (0.8), 96 | TxtEffectEst: −0.55 (−1.24 to 0.14) | 0.11
Other behavioral | Walton, 2013^114^ | Driving under the influence of cannabis (cannabis DUI) in the past 3 months: never, 1-2 times, 3-5 times, 6-9 times, 10+ times; NR (Low) | 3 months | IG2 (Overall) | 6 | 0 (1.1), 79 | 0.1 (0.8), 97 | TxtEffectEst: −0.34 (−1.07 to 0.39) | 0.36
Other behavioral | Walton, 2013^114^ | Driving under the influence of cannabis (cannabis DUI) in the past 3 months: never, 1-2 times, 3-5 times, 6-9 times, 10+ times; NR (Low) | 3 months | IG2 (Overall) | 12 | 0 (1), 77 | 0 (0.8), 94 | TxtEffectEst: −0.17 (−1.03 to 0.69) | 0.70
Other behavioral | Walton, 2013^114^ | Driving under the influence of cannabis (cannabis DUI) in the past 3 months: never, 1-2 times, 3-5 times, 6-9 times, 10+ times | 3 months | IG1 (Overall) | 3 | −0.2 (0.8), 101 | 0.1 (0.8), 96 | TxtEffectEst: −0.87 (−1.52 to −0.22) | <0.01
Other behavioral | Walton, 2013^114^ | Driving under the influence of cannabis (cannabis DUI) in the past 3 months: never, 1-2 times, 3-5 times, 6-9 times, 10+ times | 3 months | IG1 (Overall) | 6 | −0.1 (0.9), 102 | 0.1 (0.8), 97 | TxtEffectEst: −0.68 (−1.48 to 0.12) | 0.10
Other behavioral | Walton, 2013^114^ | Driving under the influence of cannabis (cannabis DUI) in the past 3 months: never, 1-2 times, 3-5 times, 6-9 times, 10+ times | 3 months | IG1 (Overall) | 12 | −0.1 (0.9), 104 | 0 (0.8), 94 | TxtEffectEst: −0.32 (−1.12 to 0.48) | 0.44

* Author reported.

† Mean value at followup, rather than change from baseline.

Abbreviations: CalcMeanDiffChg = Calculated Mean Difference in Change; CG = Control group; DUI = Driving Under the Influence; EffectSize = Effect size; FU = Followup; IG = Intervention group; NR = Not reported; NSD = No significant difference; OR = Odds ratio; SD = Standard deviation; STI = Sexually transmitted infection; TxtEffectEst: Treatment effect estimate.