# Appendix C Excluded Studies

Reason for Exclusion^*^
E1. Geography: Not a country with a very high HDI ranking
E2. Setting: Excluded on the basis of setting alone (e.g., substance abuse treatment centers, school classrooms, worksites, inpatient/residential, other institutions (e.g., juvenile detention facilities)
E3. Comparative Effectiveness (control group received active intervention)
E4. No relevant outcomes
E5. Population:; - E5a. Does not target youth or young adults, or average age of study sample >22 years old; - E5b. Youth with health conditions that limit generalizability (schizophrenia/psychosis, HIV), individuals in juvenile justice system, court-mandated
E6. Condition; - E6a. Non-psychoactive drugs; - E6b. >50% with regular drug use (weekly use, injection use, positive screener), harmful/hazardous use, or diagnosable disorder
E7. Intervention; - E7a. Not a primary care-relevant behavioral counseling intervention; - E7b. Drug misuse is not a primary target of the intervention
E8. Study Design: Not an RCT or CCT
E9. Followup: <3 months (12 weeks) followup post baseline (does not apply to harms)
E10. Study Relevance
E11. Poor Quality Rating
E12. Non-English
E13. Conference abstract

* Assigned at full-text phase.

Abbreviations: E = exclude

1 Alderson, H, McGovern, R, . Supporting Looked After Children and Care Leavers In Decreasing Drugs, and alcohol (SOLID): protocol for a pilot feasibility randomised controlled trial of interventions to decrease risky substance use (drugs and alcohol) and improve mental health of looked after children and care leavers aged 12-20 years. Pilot Feasibility Stud. 3. 25. 2017. PMID: 2853665528536655. 10.1186/s40814-017-0138-7 KQ1E13, KQ2E13, KQ3E13
2 Ali, R, Humeniuk, R, . Preliminary findings of the who assist phase III study in an australian setting: a five-minute brief intervention for ilicit drug linked to assist scores. 68th annual scientific meeting of the college on problems of drug dependence; 2006 jun 17-22. 2006. KQ1E13, KQ2E13, KQ3E13
3 Allen, ML, Garcia-Huidobro, D, . Immigrant family skills-building to prevent tobacco use in Latino youth: study protocol for a community-based participatory randomized controlled trial. Trials. 13. 242. PMID: 23253201. KQ1E4, KQ2E4, KQ3E423253201
4 Allen, ML, Hurtado, GA, . Feasibility of a parenting program to prevent substance use among Latino youth: a community-based participatory research study. Am J Health Promot. 27(4): 240–4. 2013. PMID: 23448413. 10.4278/ajhp.110204-ARB-52 KQ1E8, KQ2E8, KQ3E823448413
5 Anonymous. ED-based Counseling Sessions Reduce Risky Opioid Use Among Certain Patients. ED Management. 28(7): 81–3. 2016. KQ1E5a, KQ2E5a, KQ3E5a27439227
6 Arlt, VirginiaK. Clinician mindfulness, Motivational Interviewing and treatment outcomes for substance-using adolescents. Dissertation Abstracts International: Section B: The Sciences and Engineering. 78(2-B(E)). 2017. KQ1E6b, KQ2E6b, KQ3E6b
7 Arnaud, N, Baldus, C, . Effectiveness of a Web-Based Screening and Fully Automated Brief Motivational Intervention for Adolescent Substance Use: A Randomized Controlled Trial. J Med Internet Res. 18(5): e103. 2016. PMID: 27220276. 10.2196/jmir.4643 KQ1E11, KQ2E11, KQ3E1127220276
8 Asdigian, NL, Whitesell, NR, . Effects of the “Circle of Life” HIV-prevention program on marijuana use among American Indian middle school youths: a group randomized trial in a Northern Plains tribe. Am J Drug Alcohol Abuse. 44(1): 120–128. 2018. 10.1080/00952990.2016.1265122 KQ1E2, KQ2E2, KQ3E228032813
9 Averdijk, Margit, Zirk-Sadowski, Jan, . Long-term effects of two childhood psychosocial interventions on adolescent delinquency, substance use, and antisocial behavior: A cluster randomized controlled trial. J Exp Criminol. 12(1): 21–47. 2016. 10.1007/s11292-015-9249-4 KQ1E4, KQ2E4, KQ3E4
10 Baer, JS, Garrett, SB, . Brief motivational intervention with homeless adolescents: evaluating effects on substance use and service utilization. Psychol Addict Behav. 21(4): 582–586. 2007. 10.1037/0893-164X.21.4.582 KQ1E6b, KQ2E6b, KQ3E6b18072842
11 Bagoien, G, Bjorngaard, JH, . The effects of motivational interviewing on patients with comorbid substance use admitted to a psychiatric emergency unit - a randomised controlled trial with two year follow-up. BMC Psychiatry. 13. 93. 2013. 10.1186/1471-244X-13-93 KQ1E5a, KQ2E5a, KQ3E5a
12 Bahia, HarpreetK. Effects of the relationship check up on early adults’ romantic relationship adjustment and substance use: A pilot study. Dissertation Abstracts International: Section B: The Sciences and Engineering. 78(7-B(E)). 2018. KQ1E9, KQ2E9, KQ3E9
13 Baldus, C, Haevelmann, A, . [Internalizing problem behaviour and cannabis use: associations and variables of influence in a cross-sectional study of 14- to 23 year old cannabis users]. Prax Kinderpsychol Kinderpsychiatr. 63(3): 200–18. PMID: 24707768. KQ1E8, KQ2E8, KQ3E824707768
14 Bavarian, N, Duncan, R, . Adolescent Substance Use Following Participation in a Universal Drug Prevention Program: Examining Relationships With Program Recall and Baseline Use Status. Substance Abuse. 36(3): 359–67. 2015. 10.1080/08897077.2014.952364 KQ1E2, KQ2E2, KQ3E225148566
15 Beach, SR, Barton, AW, . Decreasing Substance use Risk among African American Youth: Parent-based Mechanisms of Change. Prevention Science. 17(5): 572–83. 2016. 10.1007/s11121-016-0651-6 KQ1E4, KQ2E4, KQ3E427129477
16 Bernstein, E, Edwards, E, . Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. 16(11): 1174–1185. 2009. 10.1111/j.1553-2712.2009.00490.x KQ1E6b, KQ2E6b, KQ3E6b20053238
17 Bernstein, E, Edwards, E, . Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. 16(11): 1174–85. 2009. PMID: 20053238. 10.1111/j.1553-2712.2009.00490.x KQ1E6b, KQ2E6b, KQ3E6b20053238
18 Berry, K, Gregg, L, . Therapeutic alliance in psychological therapy for people with recent onset psychosis who use cannabis. Compr Psychiatry. 67. 73–80. 2016. 10.1016/j.comppsych.2016.02.014 KQ1E5b, KQ2E5b, KQ3E5b27095338
19 Blevins, CE, Banes, KE, . Change in motives among frequent cannabis-using adolescents: Predicting treatment outcomes. Drug Alcohol Depend. 167. 175–81. 2016. PMID: 27577862. 10.1016/j.drugalcdep.2016.08.018 KQ1E6b, KQ2E6b, KQ3E6b27577862
20 Blow, F, Bohnert, As, . Efficacy of computer and therapist brief interventions for drug users. Drug and alcohol dependence. 156. e21. 2015. 10.1016/j.drugalcdep.2015.07.975 KQ1E5a, KQ2E5a, KQ3E5a
21 Bogenschutz, Mp, Donovan, Dm, . Brief intervention for patients with problematic drug use presenting in emergency departments: a randomized clinical trial. JAMA Intern Med. 174: 1736–1745. 2014. 10.1001/jamainternmed.2014.4052 KQ1E5a, KQ2E5a, KQ3E5a25179753
22 Bohnert, As, Blow, F, . A randomized clinical trial of a behavioral intervention to reduce opioid overdose risk behavior. Drug and alcohol dependence. 156. e22. 2015. 10.1016/j.drugalcdep.2015.07.978 KQ1E5a, KQ2E5a, KQ3E5a
23 Bohnert, KM, Walton, MA, . Three-month efficacy of a brief intervention for reducing marijuana use and consequences among adolescents presenting to indigent primary care clinics. 16. 2011. KQ1E13, KQ2E13, KQ3E13
24 Bonds, DD, Wolchik, SA, . Developmental cascade effects of the New Beginnings Program on adolescent adaptation outcomes. Dev. Psychopathol. 22. 771–784. 2010. 10.1017/S0954579410000453 KQ1E7b, KQ2E7b, KQ3E7b20883581
25 Botvin, GJ, Baker, E, . Long-term follow-up results of a randomized drug abuse prevention trial in a white middle-class population. JAMA. 273(14): 1106–12. 1995. KQ1E2, KQ2E2, KQ3E27707598
26 Botvin, GJ, Griffin, KW, . Preventing illicit drug use in adolescents: long-term follow-up data from a randomized control trial of a school population. Addict Behav. 25(5): 769–74. 2000. KQ1E2, KQ2E2, KQ3E211023017
27 Bradley, Elizabeth Gates. The effects of a school-based motivational intervention on adolescent substance abuse. Dissertation Abstracts International Section A: Humanities and Social Sciences. 70(6-A): 1917. 2009. KQ1E9, KQ2E9, KQ3E9
28 Brody, GeneH, Chen, Yi fu, . Participation in a family-centered prevention program decreases genetic risk for adolescents’ risky behaviors. Pediatrics. 124(3): 911–917. 2009. KQ1E4, KQ2E4, KQ3E419706565
29 Brody, GeneH, Yu, Tianyi, . The Adults in the Making program: Long-term protective stabilizing effects on alcohol use and substance use problems for rural African American emerging adults. J Consult Clin Psychol. 80(1): 17–28. 2012. 10.1037/a0026592 KQ1E7b, KQ2E7b, KQ3E7b22182263
30 Brody, GH, Chen, YF, . Family-centered program deters substance use, conduct problems, and depressive symptoms in black adolescents. Pediatrics. 129(1): 108–115. 2012. 10.1542/peds.2011-0623 KQ1E4, KQ2E4, KQ3E422157131
31 Brody, GH, Murry, VM, . The Strong African American Families Program: translating research into prevention programming. Child Dev. 75(3): 900–17. 2004. PMID: 15144493. 10.1111/j.1467-8624.2004.00713.x KQ1E4, KQ2E4, KQ3E415144493
32 Brody, GH, Yu, T, . Preventive parenting intervention during childhood and young black adults’ unhealthful behaviors: a randomized controlled trial. J Child Psychol Psychiatry. 60(1): 63–71. 2019. PMID: 30203840. 10.1111/jcpp.12968 KQ1E4, KQ2E4, KQ3E430203840
33 Bröning, S, Sack, Pm, . Children with Multiple Risk Factor Exposition Benefit from the German “Strengthening Families Program”. Prax Kinderpsychol Kinderpsychiatr. 65(7): 550–566. 2016. 10.13109/prkk.2016.65.7.550 KQ1E12, KQ2E12, KQ3E1227595812
34 Brown, Ec, Catalano, Rf, . Adolescent substance use outcomes in the Raising Healthy Children project: a two-part latent growth curve analysis. J Consult Clin Psychol. 73(4): 699–710. 2005. KQ1E7a, KQ2E7a, KQ3E7a16173857
35 Brown, RL, Moberg, PD, . A team approach to systematic behavioral screening and intervention. American Journal of Managed Care. 20(4): e113–21. 2014. KQ1E5a, KQ2E5a, KQ3E5a24884956
36 Brown, SamanthaM. A mindfulness-based intervention to improve family functioning among child welfare-involved families with substance use. Dissertation Abstracts International Section A: Humanities and Social Sciences. 77(11-A(E)). 2017. KQ1E4, KQ2E4, KQ3E4
37 Butzer, Bethany, LoRusso, Amanda, . Evaluation of yoga for preventing adolescent substance use risk factors in a middle school setting: A preliminary group-randomized controlled trial. J Youth Adolesc. 46(3): 603–632. 2017. 10.1007/s10964-016-0513-3 KQ1E2, KQ2E2, KQ3E227246653
38 Byrnes, HF, Miller, BA, . A comparison of maternal outcomes from an alcohol, tobacco, and other drug prevention program for mothers choosing an intervention versus being randomized. Health Education & Behavior. 40(2): 206–15. 2013. 10.1177/1090198112440576 KQ1E4, KQ2E4, KQ3E422505572
39 Carroll, KM, Martino, S, . A multisite randomized effectiveness trial of motivational enhancement therapy for Spanish-speaking substance users. J Consult Clin Psychol. 77(5): 993–9. 2009. 10.1037/a0016489 KQ1E5a, KQ2E5a, KQ3E5a19803579
40 Castellanos-Ryan, N, Seguin, JR, . Impact of a 2-year multimodal intervention for disruptive 6-year-olds on substance use in adolescence: randomised controlled trial. Br J Psychiatry. 203(3): 188–95. 2013. 10.1192/bjp.bp.112.123182 KQ1E7a, KQ2E7a, KQ3E7a23929441
41 Catalano, RF, Gainey, RR, . An experimental intervention with families of substance abusers: one-year follow-up of the focus on families project. Addiction. 94(2): 241–54. 1999. PMID: 10396792. KQ1E11, KQ2E11, KQ3E1110396792
42 Catalano, RF, Haggerty, KP, . Reducing parental risk factors for children’s substance misuse: preliminary outcomes with opiate-addicted parents. Subst Use Misuse. 32(6): 699–721. 1997. KQ1E4, KQ2E4, KQ3E49178437
43 Cervantes, R, Goldbach, J, . Familia adelante: a multi-risk prevention intervention for Latino families. J Prim Prev. 32(3-4): 225–34. 2011. PMID: 21822979. 10.1007/s10935-011-0251-y KQ1E8, KQ2E8, KQ3E821822979
44 Champion, KatrinaE, Newton, NicolaC, . A cross-validation trial of an Internet-based prevention program for alcohol and cannabis: Preliminary results from a cluster randomised controlled trial. Aust N Z J Psychiatry. 50(1): 64–73. 2016. 10.1177/0004867415577435 KQ1E2, KQ2E2, KQ3E225801662
45 Champion, KE, Newton, NC, . Cluster randomised controlled trial of an online intervention to prevent ecstasy and new psychoactive substance use among adolescents: final results and implications for implementation. BMJ Open. 8(11): e020433. 2018. PMID: 30478103. 10.1136/bmjopen-2017-020433 KQ1E2, KQ2E2, KQ3E230478103
46 Champion, KE, Newton, NC, . Effectiveness of a universal internet-based prevention program for ecstasy and new psychoactive substances: a cluster randomized controlled trial. Addiction. 111(8): 1396–405. 2016. 10.1111/add.13345 KQ1E2, KQ2E2, KQ3E226880476
47 Chandler, GE, Roberts, SJ, . Resilience Intervention for Young Adults With Adverse Childhood Experiences. J Am Psychiatr Nurses Assoc. 21(6): 406–16. 2015. 10.1177/1078390315620609 KQ1E6b, KQ2E6b, KQ3E6b26711904
48 Chilenski, SM, Welsh, JA, . Universal Prevention Exposure as a Moderator of the Community Context: Findings from the PROSPER Project. Am J Community Psychol. 57(1-2): 8–19. 2016. 10.1002/ajcp.12032 KQ1E4, KQ2E4, KQ3E427217308
49 Christopher, C, Wolchik, S, . Long-term effects of a parenting preventive intervention on young adults’ painful feelings about divorce. Journal of Family Psychology. 31(7): 799–809. 2017. 10.1037/fam0000325 KQ1E7b, KQ2E7b, KQ3E7b28471208
50 Clark, Heddy Kovach, Ringwalt, ChrisL, . Project success’ effects on substance use-related attitudes and behaviors: A randomized controlled trial in alternative high schools. J Drug Educ. 41(1): 17–44. 2011. 10.2190/DE.41.1.b KQ1E7a, KQ2E7a, KQ3E7a21675323
51 Connell, ArinM, Dishion, ThomasJ, . Variable- and Person-Centered Approaches to the Analysis of Early Adolescent Substance Use: Linking Peer, Family, and Intervention Effects with Developmental Trajectories. Merrill Palmer Q. 52(3): 421–448. 2006. 10.1353/mpq.2006.0025 KQ1E7a, KQ2E7a, KQ3E7a
52 Conrod, P. A selective drug and alcohol prevention programme that targets neurocognitive correlates of sensation seeking: focus on reward sensitivity. Neuropsychopharmacology. 40. S31. 2015. 10.1038/npp.2015.324 KQ1E13, KQ2E13, KQ3E13
53 Conrod, PJ, Castellanos-Ryan, N, . Brief, personality-targeted coping skills interventions and survival as a non-drug user over a 2-year period during adolescence. Arch Gen Psychiatry. 67(1): 85–93. 2010. PMID: 20048226. 10.1001/archgenpsychiatry.2009.173 KQ1E2, KQ2E2, KQ3E220048226
54 Conrod, PJ, Castellanos-Ryan, N, . Long-term effects of a personality-targeted intervention to reduce alcohol use in adolescents. J Consult Clin Psychol. 79(3): 296–306. 2011. PMID: 21500886. 10.1037/a0022997 KQ1E7b, KQ2E7b, KQ3E7b21500886
55 Copeland, J, Rooke, S, . Comparison of brief versus extended personalised feedback in an online intervention for cannabis users: Short-term findings of a randomised trial. J Subst Abuse Treat. 76. 43–48. 2017. 10.1016/j.jsat.2017.01.009 KQ1E5a, KQ2E5a, KQ3E5a28162849
56 Cordova, D, Huang, S, . Do the effects of a family intervention on alcohol and drug use vary by nativity status?. Psychol Addict Behav. 26(3): 655–660. 2012. 10.1037/a0026438 KQ1E2, KQ2E2, KQ3E222141423
57 Cote, J, Tessier, S, . Efficacy of a Web-Based Tailored Intervention to Reduce Cannabis Use Among Young People Attending Adult Education Centers in Quebec. Telemedicine Journal & E Health. 21. 21. 2018. 10.1089/tmj.2017.0144 KQ1E9, KQ2E9, KQ3E9
58 Crowley, DM, Jones, DE, . Can we build an efficient response to the prescription drug abuse epidemic? Assessing the cost effectiveness of universal prevention in the PROSPER trial. Prev Med. 62. 71–7. 2014. 10.1016/j.ypmed.2014.01.029 KQ1E7a, KQ2E7a, KQ3E7a24521531
59 Dagmar, M Haller, Anne, Meynard, . Prism-Ado: cluster Randomised Trial of a Brief Primary Care Intervention Addressing Excessive Substance Use in Young People. Turkish archives of pediatrics. Nil Arisoy (139 pages). 48. 34. 2013. KQ1E1, KQ2E1, KQ3E1
60 D’Amico, EJ, Miles, JN, . Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. J Subst Abuse Treat. 35(1): 53–61. 2008. 10.1016/j.jsat.2007.08.008 KQ1E11, KQ2E11, KQ3E1118037603
61 D’Amico, ElizabethJ, Fromme, Kim. Brief prevention for adolescent risk-taking behavior. Addiction. 97(5): 563–574. 2002. 10.1046/j.1360-0443.2002.00115.x KQ1E2, KQ2E2, KQ3E212033657
62 D’Amico, ElizabethJ, Fromme, Kim. Implementation of The Risk Skills Training Program: A brief intervention targeting adolescent participation in risk behaviors. Cogn Behav Pract. 7(1): 101–117. 2000. 10.1016/S1077-7229(00)80011-5 KQ1E2, KQ2E2, KQ3E2
63 Danielson, CK, McCart, MR, . Reducing substance use risk and mental health problems among sexually assaulted adolescents: a pilot randomized controlled trial. J Fam Psychol. 26(4): 628–635. 2012. 10.1037/a0028862 KQ1E4, KQ2E4, KQ3E422686269
64 Danielson, Ck. Reducing risk for substance use problems among adolescents with a child maltreatment history. Journal of the american academy of child and adolescent psychiatry. Conference: 63rd annual meeting of the american academy of child and adolescent psychiatry. United states. Conference start: 20161024. Conference end: 20161029. 55(10 Supplement 1): S293. 2016. 10.1016/j.jaac.2016.07.247 KQ1E13, KQ2E13, KQ3E13
65 Davis, JP, Houck, JM, . Brief Motivational Interviewing and Normative Feedback for Adolescents: Change Language and Alcohol Use Outcomes. J Subst Abuse Treat. 65. 66–73. 2016. PMID: 26710670. 10.1016/j.jsat.2015.10.004 KQ1E6b, KQ2E6b, KQ3E6b26710670
66 de Dios, MA, Herman, DS, . Motivational and mindfulness intervention for young adult female marijuana users. J Subst Abuse Treat. 42(1): 56–64. 2012. 10.1016/j.jsat.2011.08.001 KQ1E6b, KQ2E6b, KQ3E6b21940136
67 de Gee, EA, Verdurmen, JE, . A randomized controlled trial of a brief motivational enhancement for non-treatment-seeking adolescent cannabis users. J Subst Abuse Treat. 47(3): 181–8. 2014. 10.1016/j.jsat.2014.05.001 KQ1E6b, KQ2E6b, KQ3E6b24969735
68 de Vries, SanneL, Hoeve, Machteld, . A randomized controlled trial of the effectiveness of the youth crime prevention program ‘New Perspectives’ (NP): Post-treatment changes and moderator effects. Child Youth Serv Rev. 82. 413–426. 2017. 10.1016/j.childyouth.2017.10.011 KQ1E7b, KQ2E7b, KQ3E7b
69 DeGarmo, DS, Eddy, JM, . Evaluating mediators of the impact of the Linking the Interests of Families and Teachers (LIFT) multimodal preventive intervention on substance use initiation and growth across adolescence. Prev Sci. 10(3): 208–20. 2009. PMID: 19238545. 10.1007/s11121-009-0126-0 KQ1E7a, KQ2E7a, KQ3E7a19238545
70 Dennhardt, AshleyA. The role of affective and behavioral economic factors in predicting response to a brief intervention for alcohol and illicit drug use in college students. Dissertation Abstracts International: Section B: The Sciences and Engineering. 75(7-B(E)). 2015. KQ1E6b, KQ2E6b, KQ3E6b
71 Dishion, TJ, Andrews, DW. Preventing escalation in problem behaviors with high-risk young adolescents: immediate and 1-year outcomes. J Consult Clin Psychol. 63(4): 538–48. 1995. PMID: 7673531. KQ1E4, KQ2E4, KQ3E47673531
72 Dodge, KennethA, Bierman, KarenL, . “Impact of early intervention on psychopathology, crime, and well-being at age 25”: Correction. Am J Psychiatry. 172(1): 100. 2015. KQ1E8, KQ2E8, KQ3E8
73 Dodge, KennethA, Bierman, KarenL, . Impact of early intervention on psychopathology, crime, and well-being at age 25. Am J Psychiatry. 172(1): 59–70. 2015. KQ1E7a, KQ2E7a, KQ3E7a25219348
74 Duncan, LR, Hieftje, KD, . Preliminary investigation of a videogame prototype for cigarette and marijuana prevention in adolescents. Substance Abuse. 1–5. PMID: 2942548129425481. KQ1E4, KQ2E4, KQ3E4
75 Dupont, HB, Candel, MJ, . Assessing the Efficacy of MOTI-4 for Reducing the Use of Cannabis Among Youth in the Netherlands: A Randomized Controlled Trial. J Subst Abuse Treat. 65. 6–12. 2016. 10.1016/j.jsat.2015.11.012 KQ1E6b, KQ2E6b, KQ3E6b26780988
76 Elk, Ronith, Mangus, Lorna, . Cessation of cocaine use during pregnancy: Effects of contingency management interventions on maintaining abstinence and complying with prenatal care. Addict Behav. 23(1): 57–64. 1998. 10.1016/S0306-4603%2897%2900020-8 KQ1E6b, KQ2E6b, KQ3E6b9468743
77 Elliot, DianeL, Goldberg, Linn, . Long-term outcomes of the ATHENA (Athletes Targeting Healthy Exercise & Nutrition Alternatives) program for female high school athletes. J Alcohol Drug Educ. 52(2): 73–92. 2008. KQ1E2, KQ2E2, KQ3E219081833
78 Elliott, JC, Carey, KB, . A preliminary evaluation of a web-based intervention for college marijuana use. Psychol Addict Behav. 28(1): 288–93. 2014. PMID: 24731118. 10.1037/a0034995 KQ1E6b, KQ2E6b, KQ3E6b24731118
79 Estrada, Y, Lee, TK, . Parent-Centered Prevention of Risky Behaviors Among Hispanic Youths in Florida. Am J Public Health. 107(4): 607–613. 2017. PMID: 28207330. 10.2105/ajph.2017.303653 KQ1E2, KQ2E2, KQ3E228207330
80 Estrada, Y, Rosen, A, . Efficacy of a Brief Intervention to Reduce Substance Use and Human Immunodeficiency Virus Infection Risk Among Latino Youth. J Adolesc Health. 2015. PMID: 2654955126549551. 10.1016/j.jadohealth.2015.07.006 KQ1E2, KQ2E2, KQ3E2
81 Fang, Lin, Schinke, StevenP. Mediation effects of a culturally generic substance use prevention program for Asian American adolescents. Asian Am J Psychol. 5(2): 116–125. 2014. PMID: 25505939. 10.1037/a0035928 KQ1E4, KQ2E4, KQ3E425505939
82 Fishbein, Diana, Miller, Shari, . Behavioral and psychophysiological effects of a yoga intervention on high-risk adolescents: A randomized control trial. J Child Fam Stud. 25(2): 518–529. 2016. 10.1007/s10826-015-0231-6 KQ1E2, KQ2E2, KQ3E2
83 Forcehimes, Aa, Bogenschutz, M, . Race and ethnicity differences in a MI-based brief intervention delivered in an ED setting. Drug and alcohol dependence. 146. e280–e281. 2015. 10.1016/j.drugalcdep.2014.09.229 KQ1E5a, KQ2E5a, KQ3E5a
84 Forman, SusanG, Linney, JeanA, . Effects of coping skills training on adolescents at risk for substance use. Psychology of Addictive Behaviors. 4(2): 67–76. 1990. 10.1037/h0080585 KQ1E7a, KQ2E7a, KQ3E7a
85 Fosco, GM, Frank, JL, . Opening the “Black Box”: family check-up intervention effects on self-regulation that prevents growth in problem behavior and substance use. J Sch Psychol. 51(4): 455–68. 2013. 10.1016/j.jsp.2013.02.001 KQ1E4, KQ2E4, KQ3E423870441
86 Furr-Holden, CD, Ialongo, NS, . Developmentally inspired drug prevention: middle school outcomes in a school-based randomized prevention trial. Drug Alcohol Depend. 73(2): 149–58. 2004. PMID: 14725954. KQ1E7a, KQ2E7a, KQ3E7a14725954
87 Fuster, D, Cheng, DM, . Brief intervention for daily marijuana users identified by screening in primary care: A subgroup analysis of the ASPIRE randomized clinical trial. Substance Abuse. 37(2): 336–42. 2016. 10.1080/08897077.2015.1075932 KQ1E5a, KQ2E5a, KQ3E5a26453188
88 Geisner, Im, Rhew, Ic, . 4.70 Personalized Normative Feedback Intervention for Prescription Stimulant Medication: preliminary Evidence in College Students. Journal of the american academy of child and adolescent psychiatry. Conference: aacap’s 65th annual meeting. United states. 57(10 Supplement): S226. 2018. 10.1016/j.jaac.2018.09.295 KQ1E13, KQ2E13, KQ3E13
89 Giannotta, F, Vigna-Taglianti, F, . Short-term mediating factors of a school-based intervention to prevent youth substance use in Europe. J Adolesc Health. 54(5): 565–73. 2014. 10.1016/j.jadohealth.2013.10.009 KQ1E2, KQ2E2, KQ3E224332392
90 Golonka, MM, Peairs, KF, . Natural Peer Leaders as Substance Use Prevention Agents: the Teens’ Life Choice Project. Prevention Science. 18(5): 555–566. 2017. 10.1007/s11121-017-0790-4 KQ1E7a, KQ2E7a, KQ3E7a28500558
91 Gonzales, NA, Dumka, LE, . Randomized trial of a broad preventive intervention for Mexican American adolescents. J Consult Clin Psychol. 80(1): 1–16. 2012. 10.1037/a0026063 KQ1E4, KQ2E4, KQ3E422103956
92 Gonzales, NA, Jensen, M, . Effect of Middle School Interventions on Alcohol Misuse and Abuse in Mexican American High School Adolescents: Five-Year Follow-up of a Randomized Clinical Trial. JAMA Psychiatry. 75(5): 429–437. 2018. 10.1001/jamapsychiatry.2018.0058 KQ1E4, KQ2E4, KQ3E429562080
93 Griffin, JamesP, Jr, Holliday, . The brave (building resiliency and vocational excellence) program: Evaluation findings for a career-oriented substance abuse and violence preventive intervention. J Health Care Poor Underserved. 20(3): 798–816. 2009. 10.1353/hpu.0.0174 KQ1E7a, KQ2E7a, KQ3E7a19648706
94 Griffin, KennethW, Botvin, GilbertJ, . Long-term follow-up effects of a School-Based Drug Abuse Prevention Program on Adolescent Risky Driving. Prevention Science. 5(3): 207–212. 2004. 10.1023/B:PREV.0000037643.78420.74 KQ1E2, KQ2E2, KQ3E215470940
95 Griffin, KW, Botvin, GJ, . Effects of a school-based drug abuse prevention program for adolescents on HIV risk behavior in young adulthood. Prevention Science. 7(1): 103–12. 2006. KQ1E7a, KQ2E7a, KQ3E7a16604429
96 Grossbard, JR, Mastroleo, NR, . Substance use patterns among first-year college students: secondary effects of a combined alcohol intervention. J Subst Abuse Treat. 39(4): 384–90. 2010. 10.1016/j.jsat.2010.07.001 KQ1E7b, KQ2E7b, KQ3E7b20817383
97 Guo, Jong-Long, Lee, Tzu-Chi, . Prevention of illicit drug use through a school-based program: Results of a longitudinal, cluster-randomized controlled trial. J Adolesc Health. 56(3): 314–322. 2015. 10.1016/j.jadohealth.2014.12.003 KQ1E1, KQ2E1, KQ3E125703320
98 Guo, S, Wu, Q, . A Longitudinal Evaluation of the Positive Action Program in a Low-Income, Racially Diverse, Rural County: Effects on Self-Esteem, School Hassles, Aggression, and Internalizing Symptoms. J Youth Adolesc. 44(12): 2337–58. 2015. 10.1007/s10964-015-0358-1 KQ1E2, KQ2E2, KQ3E226411991
99 Guo, Xiamei, Slesnick, Natasha. Reductions in hard drug use among homeless youth receiving a strength-based outreach intervention: Comparing the long-term effects of shelter linkage versus drop-in center linkage. Subst Use Misuse. 52(7): 905–915. 2017. 10.1080/10826084.2016.1267219 KQ1E3, KQ2E3, KQ3E328426359
100 Haggerty, KevinP, Klima, Tali, . Staying Connected With Your Teen and the promise of self-directed prevention programs. Family-based prevention programs for children and adolescents: Theory, research, and large-scale dissemination. 209–228. 2016. KQ1E4, KQ2E4, KQ3E4
101 Haggerty, KP, Barkan, SE, . Feasibility of Connecting, a Substance-Abuse Prevention Program for Foster Teens and their Caregivers. J Soc Social Work Res. 7(4): 639–659. 2016. PMID: 27891209. 10.1086/686986 KQ1E4, KQ2E4, KQ3E427891209
102 Haggerty, KP, Skinner, M, . Long-term effects of the Focus on Families project on substance use disorders among children of parents in methadone treatment. Addiction. 103(12): 2008–16. 2008. PMID: 18855808. 10.1111/j.1360-0443.2008.02360.x KQ1E4, KQ2E4, KQ3E418855808
103 Haggerty, KP, Skinner, ML, . A randomized trial of Parents Who Care: effects on key outcomes at 24-month follow-up. Prev Sci. 8(4): 249–60. 2007. PMID: 17987388. 10.1007/s11121-007-0077-2 KQ1E2, KQ2E2, KQ3E217987388
104 Haggerty, KP, Skinner, ML, . Long-term effects of staying connected with your teen on drug use frequency at age 20. Prevention Science. 16(4): 538–49. 2015. 10.1007/s11121-014-0525-8 KQ1E2, KQ2E2, KQ3E225428694
105 Hall, BW, Bacon, TP, . Randomized controlled evaluation of the Too Good for Drugs prevention program: impact on adolescents at different risk levels for drug use. J Drug Educ. 43(3): 277–300. 2013. 10.2190/DE.43.3.e KQ1E2, KQ2E2, KQ3E225445508
106 Haller, DM, Meynard, A, . Brief intervention addressing excessive cannabis use in young people consulting their GP: a pilot study. Br J Gen Pract. 59(560): 166–72. 2009. 10.3399/bjgp09X419529 KQ1E9, KQ2E9, KQ3E919275832
107 Haller, DM, Meynard, A, . Effectiveness of training family physicians to deliver a brief intervention to address excessive substance use among young patients: a cluster randomized controlled trial. CMAJ Canadian Medical Association Journal. 186(8): E263–72. 2014. PMID: 24616136. 10.1503/cmaj.131301 KQ1E5a, KQ2E5a, KQ3E5a24616136
108 Harris, Sk, Sherritt, L, . Practical tools to support adolescent substance abuse prevention in primary care: a multi-site randomized controlled trial of computer-facilitated screening and provider brief advice in the medical office. Journal of adolescent health. Conference: society for adolescent health and medicine annual meeting 2018. United states. 62(2 Supplement 1): S13. 2018. KQ1E13, KQ2E13, KQ3E13
109 Hecht, MichaelL, Marsiglia, Flavio Francisco, . Culturally grounded substance use prevention: An evaluation of the keepin’ it R.E.A.L curriculum. Prevention Science. 4(4): 233–248. 2003. 10.1023/A:1026016131401 KQ1E2, KQ2E2, KQ3E214598996
110 Helmer, SM, Muellmann, S, . Development and evaluation of the efficacy of a web-based ‘social norms’-intervention for the prevention and reduction of substance use in a cluster-controlled trial conducted at eight German universities. BMC Public Health. 16. 252. 2016. 10.1186/s12889-016-2898-z KQ1E4, KQ2E4, KQ3E426969585
111 Herman, PM, Mahrer, NE, . Cost-benefit analysis of a preventive intervention for divorced families: reduction in mental health and justice system service use costs 15 years later. Prevention Science. 16(4): 586–96. 2015. 10.1007/s11121-014-0527-6 KQ1E7b, KQ2E7b, KQ3E7b25382415
112 Hernandez-Serrano, O, Griffin, KW, . Public commitment, resistance to advertising, and leisure promotion in a school-based drug abuse prevention program: a component dismantling study. J Drug Educ. 43(4): 331–51. 2013. 10.2190/DE.43.4.c KQ1E2, KQ2E2, KQ3E225445808
113 Hides, L, Carroll, S, . Quik Fix: a randomized controlled trial of an enhanced brief motivational interviewing intervention for alcohol/cannabis and psychological distress in young people. Psychother Psychosom. 82(2): 122–4. 2013. 10.1159/000341921 KQ1E3, KQ2E3, KQ3E323295899
114 Hides, LM, Elkins, KS, . Does the addition of integrated cognitive behaviour therapy and motivational interviewing improve the outcomes of standard care for young people with comorbid depression and substance misuse?. Med J Aust. 195(3): S31–7. 2011. PMID: 21806516. KQ1E6b, KQ2E6b, KQ3E6b21806516
115 Hodder, RK, Freund, M, . Effectiveness of a pragmatic school-based universal resilience intervention in reducing tobacco, alcohol and illicit substance use in a population of adolescents: cluster-randomised controlled trial. BMJ Open. 7(8): e016060. 2017. 10.1136/bmjopen-2017-016060 KQ1E7a, KQ2E7a, KQ3E7a
116 Hoffman, LJ, Guerry, JD, . Launching Anxious Young Adults: A Specialized Cognitive-Behavioral Intervention for Transitional Aged Youth. Curr Psychiatry Rep. 20(4): 25. PMID: 29589127. KQ1E10, KQ2E10, KQ3E1029589127
117 Horigian, VE, Feaster, DJ, . The effects of Brief Strategic Family Therapy (BSFT) on parent substance use and the association between parent and adolescent substance use. Addict Behav. 42. 44–50. 2015. 10.1016/j.addbeh.2014.10.024 KQ1E6b, KQ2E6b, KQ3E6b25462653
118 Huang, S, Cordova, D, . An application of the Complier Average Causal Effect analysis to examine the effects of a family intervention in reducing illicit drug use among high-risk Hispanic adolescents. Fam Process. 53(2): 336–47. 2014. 10.1111/famp.12068 KQ1E2, KQ2E2, KQ3E224611528
119 Humeniuk, R, Ali, R, . A randomized controlled trial of a brief intervention for illicit drugs linked to the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) in clients recruited from primary health-care settings in four countries. Addiction. 107(5): 957–966. 2012. 10.1111/j.1360-0443.2011.03740.x KQ1E5a, KQ2E5a, KQ3E5a22126102
120 Humeniuk, R, Newcombe, Dal, . A randomised controlled trial of a brief intervention for illicit drug use linked to ASSIST screening in a primary healthcare setting: results from the Australian component of the World Health Organization Phase III ASSIST studies. Aust J Prim Health. 24(2): 149–154. 2018. 10.1071/PY17056 KQ1E5a, KQ2E5a, KQ3E5a29481765
121 Ingels, JustinB, Corso, PhaedraS, . Cost-effectiveness of the strong African American families-teen program: 1-year follow-up. Drug Alcohol Depend. 133(2): 556–561. 2013. 10.1016/j.drugalcdep.2013.07.036 KQ1E4, KQ2E4, KQ3E423998376
122 Isensee, B, Maruska, K, . Long-term effects of the prevention program klasse2000 on substance use: results of a controlled study in students in Hesse. Sucht. 61(3): 127–137. 2015. 10.1024/0939-5911.a000365 KQ1E12, KQ2E12, KQ3E12
123 Jacobus, J, Taylor, CT, . A multi-site proof-of-concept investigation of computerized approach-avoidance training in adolescent cannabis users. Drug Alcohol Depend. 187. 195–204. 2018. 10.1016/j.drugalcdep.2018.03.007 KQ1E6b, KQ2E6b, KQ3E6b29679914
124 Jensen, MR, Wong, JJ, . Long-term effects of a universal family intervention: mediation through parent-adolescent conflict. Journal of Clinical Child & Adolescent Psychology. 43(3): 415–27. 2014. 10.1080/15374416.2014.891228 KQ1E4, KQ2E4, KQ3E424730357
125 Johnson, CA, Pentz, MA, . Relative effectiveness of comprehensive community programming for drug abuse prevention with high-risk and low-risk adolescents. J Consult Clin Psychol. 58(4): 447–56. 1990. PMID: 2212182. KQ1E7a, KQ2E7a, KQ3E7a2212182
126 Kay-Lambkin, FJ, Baker, AL, . Computer-based psychological treatment for comorbid depression and problematic alcohol and/or cannabis use: a randomized controlled trial of clinical efficacy. Addiction. 104(3): 378–88. 2009. 10.1111/j.1360-0443.2008.02444.x KQ1E5a, KQ2E5a, KQ3E5a19207345
127 Kiewik, M, VanDerNagel, JE, . Substance use prevention program for adolescents with intellectual disabilities on special education schools: a cluster randomised control trial. J Intellectual Disabil Res. 60(3): 191–200. 2016. 10.1111/jir.12235 KQ1E7b, KQ2E7b, KQ3E7b
128 Kim, BK, Gloppen, KM, . Effects of the communities that care prevention system on youth reports of protective factors. Prevention Science. 16(5): 652–62. 2015. 10.1007/s11121-014-0524-9 KQ1E7a, KQ2E7a, KQ3E7a25366931
129 Kim, HK, Buchanan, R, . Pathways to Preventing Substance Use Among Youth in Foster Care. Prevention Science. 18(5): 567–576. 2017. 10.1007/s11121-017-0800-6 KQ1E4, KQ2E4, KQ3E428523585
130 Kozloff, N. Housing first “junior”: testing a complex psychosocial intervention designed for homeless adults with mental illness in homeless youth. Journal of the american academy of child and adolescent psychiatry. Conference: 63rd annual meeting of the american academy of child and adolescent psychiatry. United states. Conference start: 20161024. Conference end: 20161029. 55(10 Supplement 1): S74. 2016. 10.1016/j.jaac.2016.07.728 KQ1E4, KQ2E4, KQ3E4
131 Krupski, La. Promoting mindfulness and readiness to change: a comparison of teaching strategies for college students mandated to alcohol and drug education. New york: state university of new york at buffalo. 106. 2005. KQ1E5b, KQ2E5b, KQ3E5b
132 Kumpfer, KarolL, Whiteside, HenryO, . Effectiveness outcomes of four age versions of the Strengthening Families Program in statewide field sites. Group Dynamics: Theory, Research, and Practice. 14(3): 211–229. 2010. 10.1037/a0020602 KQ1E8, KQ2E8, KQ3E8
133 Kumpfer, KarolL, Xie, Jing, . Effectiveness of a Culturally Adapted Strengthening Families Program 12–16 Years for High-Risk Irish Families. Child Youth Care Forum. 41(2): 173–195. 2012. 10.1007/s10566-011-9168-0 KQ1E8, KQ2E8, KQ3E8
134 Kurtz, SP, Buttram, ME, . A randomized trial of brief assessment interventions for young adults who use drugs in the club scene. J Subst Abuse Treat. 78. 64–73. 2017. 10.1016/j.jsat.2017.05.008 KQ1E6b, KQ2E6b, KQ3E6b28554606
135 Laporte, C, Vaillant-Roussel, H, . CANABIC: CANnabis and Adolescents: effect of a Brief Intervention on their Consumption-study protocol for a randomized controlled trial. Trials. 15. 40. 2014. PMID: 24479702. 10.1186/1745-6215-15-40 KQ1E6b, KQ2E6b, KQ3E6b24479702
136 Laporte, Catherine, Vaillant-Roussel, Helene, . Cannabis and young users-A brief intervention to reduce their consumption (CANABIC): A cluster randomized controlled trial in primary care. Ann Fam Med. 15(2): 131–139. 2017. 10.1370/afm.2003 KQ1E6b, KQ2E6b, KQ3E6b28289112
137 Lee, CM, Kilmer, JR, . Indicated prevention for college student marijuana use: a randomized controlled trial. J Consult Clin Psychol. 81(4): 702–9. 2013. PMID: 23750464. 10.1037/a0033285 KQ1E6b, KQ2E6b, KQ3E6b23750464
138 Lee, TK, Estrada, Y, . Efficacy of a Family-Based Intervention on Parent-Adolescent Discrepancies in Positive Parenting and Substance Use among Hispanic Youth. J Adolesc Health. 2018. PMID: 3051465230514652. 10.1016/j.jadohealth.2018.10.002 KQ1E2, KQ2E2, KQ3E2
139 Lennox, RichardD, Cecchini, MarieA. The NARCONONTM drug education curriculum for high school students: A non-randomized, controlled prevention trial. Substance Abuse Treatment, Prevention, and Policy Vol 3 2008, ArtID 8. 3 2008. 10.1186/1747-597X-3-8 KQ1E2, KQ2E2, KQ3E2
140 Lindenberg, CS, Solorzano, RM, . Reducing substance use and risky sexual behavior among young, low-income, Mexican-American women: comparison of two interventions. Appl Nurs Res. 15(3): 137–48. 2002. PMID: 12173165. KQ1E11, KQ2E11, KQ3E1112173165
141 Lisha, NadraE, Sun, Ping, . An evaluation of immediate outcomes and fidelity of a drug abuse prevention program in continuation high schools: Project Towards No Drug Abuse (TND). J Drug Educ. 42(1): 33–57. 2012. 10.2190/DE.42.1.c KQ1E2, KQ2E2, KQ3E222873013
142 Lochman, JE, Wells, KC. The Coping Power program at the middle-school transition: universal and indicated prevention effects. Psychol Addict Behav. 16(4s): S40–54. 2002. PMID: 12502276. KQ1E4, KQ2E4, KQ3E412502276
143 Looby, A, De Young, KP, . Challenging expectancies to prevent nonmedical prescription stimulant use: a randomized, controlled trial. Drug Alcohol Depend. 132(1-2): 362–8. 2013. 10.1016/j.drugalcdep.2013.03.003 KQ1E7a, KQ2E7a, KQ3E7a23570818
144 Madras, BK, Compton, WM, . Screening, brief interventions, referral to treatment (SBIRT) for illicit drug and alcohol use at multiple healthcare sites: Comparison at intake and 6 months later. Drug Alcohol Depend. 99(1-3): 280–295. 2009. KQ1E5a, KQ2E5a, KQ3E5a18929451
145 Mahu, IT, Doucet, C, . Can cannabis use be prevented by targeting personality risk in schools? Twenty-four-month outcome of the adventure trial on cannabis use: a cluster-randomized controlled trial. Addiction. 110(10): 1625–33. 2015. 10.1111/add.12991 KQ1E2, KQ2E2, KQ3E226011508
146 Markham, CM, Craig Rushing, S, . Internet-Based Delivery of Evidence-Based Health Promotion Programs Among American Indian and Alaska Native Youth: A Case Study. JMIR Res Protoc. 5(4): e225. 2016. KQ1E4, KQ2E4, KQ3E427872037
147 Marsden, J, Stillwell, G, . An evaluation of a brief motivational intervention among young ecstasy and cocaine users: no effect on substance and alcohol use outcomes. Addiction. 101(7): 1014–1026. 2006. 10.1111/j.1360-0443.2006.01290.x KQ1E6b, KQ2E6b, KQ3E6b16771893
148 Marsden, John, Stillwell, Garry, . An evaluation of a brief intervention model for use with young non-injecting stimulant users. Drugs. 12(Suppl1): 90–93. 2005. KQ1E6b, KQ2E6b, KQ3E6b
149 Marsiglia, FF, Ayers, SL, . Changing Latino Adolescents’ Substance Use Norms and Behaviors: the Effects of Synchronized Youth and Parent Drug Use Prevention Interventions. Prevention Science. 17(1): 1–12. 2016. 10.1007/s11121-015-0574-7 KQ1E7a, KQ2E7a, KQ3E7a26103920
150 Martin, G, Copeland, J, . The Adolescent Cannabis Check-up. Sixty-eight annual scientific meeting of the college on problems of drug dependence. 2005. KQ1E13, KQ2E13, KQ3E13
151 Martin, Greg, Copeland, Jan. The adolescent cannabis check-up: Randomized trial of a brief intervention for young cannabis users. J Subst Abuse Treat. 34(4): 407–414. 2008. 10.1016/j.jsat.2007.07.004 KQ1E6b, KQ2E6b, KQ3E6b17869051
152 Martinez, CR, Jr, Eddy, . Effects of culturally adapted parent management training on Latino youth behavioral health outcomes. J Consult Clin Psychol. 73(5): 841–51. 2005. PMID: 16287384. 10.1037/0022-006X.73.5.841 KQ1E4, KQ2E4, KQ3E416287384
153 Martz, Me, Waller, R, . Therapist and computer-based brief interventions within a randomized controlled trial: effects on parallel trajectories of alcohol use, marijuana use, and anxiety. Alcoholism: clinical and experimental research. 42. 198a‐. 2018. 10.1111/acer.13747 KQ1E5a, KQ2E5a, KQ3E5a
154 Mason, M, Pate, P, . Motivational interviewing integrated with social network counseling for female adolescents: a randomized pilot study in urban primary care. J Subst Abuse Treat. 41(2): 148–155. 2011. 10.1016/j.jsat.2011.02.009 KQ1E9, KQ2E9, KQ3E421489741
155 Mason, WA, Kosterman, R, . Reducing adolescents’ growth in substance use and delinquency: randomized trial effects of a parent-training prevention intervention. Prev Sci. 4(3): 203–12. 2003. KQ1E7a, KQ2E7a, KQ3E7a12940470
156 Mason, Alex W, Haggerty, KevinP, . Family intervention to prevent depression and substance use among adolescents of depressed parents. J Child Fam Stud. 21(6): 891–905. 2012. KQ1E4, KQ2E4, KQ3E423798891
157 Mason, Alex W, Kosterman, Rick, . Influence of a family-focused substance use preventive intervention on growth in adolescent depressive symptoms. J Res Adolesc. 17(3): 541–564. 2007. KQ1E7a, KQ2E7a, KQ3E7a
158 McCambridge, J, Day, M, . Fidelity to Motivational Interviewing and subsequent cannabis cessation among adolescents. Addict Behav. 36(7): 749–754. 2011. 10.1016/j.addbeh.2011.03.002 KQ1E6b, KQ2E6b, KQ3E6b21440994
159 McCambridge, J, Hunt, C, . Cluster randomised trial of the effectiveness of motivational interviewing for universal prevention. Drug Alcohol Depend. 114(2-3): 177–84. 2011. 10.1016/j.drugalcdep.2010.07.028 KQ1E2, KQ2E2, KQ3E221075562
160 McCambridge, J, Slym, RL, . Randomized controlled trial of motivational interviewing compared with drug information and advice for early intervention among young cannabis users. Addiction. 103(11): 1809–18. 2008. 10.1111/j.1360-0443.2008.02331.x KQ1E6b, KQ2E6b, KQ3E6b18778385
161 McCambridge, Jim, Strang, John. Deterioration over time in effect of Motivational Interviewing in reducing drug consumption and related risk among young people. Addiction. 100(4): 470–478. 2005. 10.1111/j.1360-0443.2005.01013.x KQ1E6b, KQ2E6b, KQ3E6b15784061
162 McCambridge, Jim, Strang, John. The efficacy of single-session motivational interviewing in reducing drug consumption and perceptions of drug-related risk and harm among young people: Results from a multi-site cluster randomized trial. Addiction. 99(1): 39–52. 2004. 10.1111/j.1360-0443.2004.00564.x KQ1E6b, KQ2E6b, KQ3E6b14678061
163 Medvin, Rb, Brooks, Ac, . Expanded brief intervention in primary care results in reduced self-reported substance use at six-month follow-up: preliminary results. Drug Alcohol Depend. 156. e148. 2015. 10.1016/j.drugalcdep.2015.07.404 KQ1E5a, KQ2E5a, KQ3E5a
164 Meli, S, Palfai, T, . Screening and brief intervention for low risk drug use in primary care: a pilot randomized trial. Drug Alcohol Depend. 156. e149–e150. 2015. 10.1016/j.drugalcdep.2015.07.407 KQ1E5a, KQ2E5a, KQ3E5a
165 Midford, R, Ramsden, R, . Alcohol Prevention and School Students: Findings From an Australian 2-Year Trial of Integrated Harm Minimization School Drug Education. J Drug Educ. 44(3-4): 71–94. 2014. 10.1177/0047237915579886 KQ1E7a, KQ2E7a, KQ3E7a25852045
166 Milburn, NG, Iribarren, FJ, . A family intervention to reduce sexual risk behavior, substance use, and delinquency among newly homeless youth. J Adolesc Health. 50(4): 358–364. 2012. 10.1016/j.jadohealth.2011.08.009 KQ1E11, KQ2E11, KQ3E1122443839
167 Miovsky, M, Vonkova, H, . Universality properties of school-based preventive intervention targeted at cannabis use. Prevention Science. 16(2): 189–99. 2015. 10.1007/s11121-013-0453-z KQ1E2, KQ2E2, KQ3E224420651
168 Mogro-Wilson, Cristina, Letendre, Joan, . Utilizing mutual aid in reducing adolescent substance use and developing group engagement. Res Soc Work Pract. 25(1): 129–138. 2015. 10.1177/1049731513518080 KQ1E2, KQ2E2, KQ3E2
169 Moitra, E, Anderson, BJ, . REDUCTIONS IN CANNABIS USE ARE ASSOCIATED WITH MOOD IMPROVEMENT IN FEMALE EMERGING ADULTS. Depress Anxiety. 33(4): 332–8. 2016. PMID: 26636547. 10.1002/da.22460 KQ1E6b, KQ2E6b, KQ3E6b26636547
170 Molina, Bsg. Stimulant treatment history, assigned and self-selected, as predictor of late adolescent substance abuse in ADHD. Neuropsychopharmacology. 35. S38–s39. 2010. 10.1038/npp.2010.215 KQ1E7b, KQ2E7b, KQ3E7b
171 Monney, Gregoire, Penzenstadler, Louise, . mHealth app for cannabis users: Satisfaction and perceived usefulness. Frontiers in Psychiatry Vol 6 2015, ArtID 120. 6 2015. KQ1E5a, KQ2E5a, KQ3E5a
172 Moore, MJ, Werch, CE, . Pilot of a computer-based brief multiple-health behavior intervention for college students. Journal of American College Health. 60(1): 74–80. 2012. 10.1080/07448481.2011.574765 KQ1E4, KQ2E4, KQ3E422171732
173 Morgenstern, Jon, Bux, DonaldA, . Randomized trial to reduce club drug use and HIV risk behaviors among men who have sex with men. J Consult Clin Psychol. 77(4): 645–656. 2009. 10.1037/a0015588 KQ1E5a, KQ2E5a, KQ3E5a19634958
174 Morley, KirstenC, Sitharthan, Gomathi, . The efficacy of an opportunistic cognitive behavioral intervention package (OCB) on substance use and comorbid suicide risk: A multisite randomized controlled trial. J Consult Clin Psychol. 82(1): 130–140. 2014. 10.1037/a0035310 KQ1E5a, KQ2E5a, KQ3E5a24364795
175 Murry, Velma McBride, Berkel, Cady, . Intervention induced changes on parenting practices, youth self-pride and sexual norms to reduce HIV-related behaviors among rural African American youths. J Youth Adolesc. 40(9): 1147–1163. 2011. 10.1007/s10964-011-9642-x KQ1E4, KQ2E4, KQ3E421373904
176 Musiat, P, Potterton, R, . Web-based indicated prevention of common mental disorders in university students in four European countries - Study protocol for a randomised controlled trial. Internet interventions. 2018. 10.1016/j.invent.2018.02.004 KQ1E4, KQ2E4, KQ3E4
177 Newton, NC, Andrews, G, . Universal Internet-based prevention for alcohol and cannabis use reduces truancy, psychological distress and moral disengagement: a cluster randomised controlled trial. Prev Med. 65. 109–15. 2014. 10.1016/j.ypmed.2014.05.003 KQ1E2, KQ2E2, KQ3E224823906
178 Newton, NC, Teesson, M, . Universal cannabis outcomes from the Climate and Preventure (CAP) study: a cluster randomised controlled trial. Subst Abuse Treat Prev Policy. 13(1): 34. PMID: 30253790. KQ1E7a, KQ2E7a, KQ3E7a30253790
179 Nieri, T, Apkarian, J, . Effects of a youth substance use prevention program on stealing, fighting, and weapon use. Journal of Primary Prevention. 36(1): 41–9. 2015. 10.1007/s10935-014-0373-0 KQ1E2, KQ2E2, KQ3E225352527
180 Norberg, MM, Hides, L, . Brief interventions to reduce Ecstasy use: a multi-site randomized controlled trial. Behav Ther. 45(6): 745–59. 2014. 10.1016/j.beth.2014.05.006 KQ1E5a, KQ2E5a, KQ3E5a25311285
181 Nyamathi, A, Branson, C, . Impact of nursing intervention on decreasing substances among homeless youth. American Journal on Addictions. 21(6): 558–565. 2012. 10.1111/j.1521-0391.2012.00288.x KQ1E6b, KQ2E6b, KQ3E6b23082836
182 Oesterle, S, Hawkins, JD, . Effects of Communities That Care on Males’ and Females’ Drug Use and Delinquency 9 Years After Baseline in a Community-Randomized Trial. Am J Community Psychol. 56(3-4): 217–28. 2015. 10.1007/s10464-015-9749-4 KQ1E7a, KQ2E7a, KQ3E7a26377418
183 O’Leary-Barrett, M, Masse, B, . A cluster-randomized controlled trial evaluating the effects of delaying onset of adolescent substance abuse on cognitive development and addiction following a selective, personality-targeted intervention programme: the Co-Venture trial.[Erratum appears in Addiction. 2018 Mar;113(3):581; PMID: 29423989]. Addiction. 112(10): 1871–1881. 2017. 10.1111/add.13876 KQ1E2, KQ2E2, KQ3E228544009
184 Oliansky, DeniseM, Wildenhaus, KevinJ, . Effectiveness of brief interventions in reducing substance use among at-risk primary care patients in three community-based clinics. Subst Abuse. 18(3): 95–103. 1997. KQ1E11, KQ2E11, KQ3E11
185 Ondersma, SJ, Svikis, DS, . Computer-delivered screening and brief intervention (e-SBI) for postpartum drug use: a randomized trial. J Subst Abuse Treat. 46(1): 52–9. 2014. 10.1016/j.jsat.2013.07.013 KQ1E5a, KQ2E5a, KQ3E5a24051077
186 Osgood, DW, Feinberg, ME, . Effects of PROSPER on the influence potential of prosocial versus antisocial youth in adolescent friendship networks. J Adolesc Health. 53(2): 174–9. 2013. 10.1016/j.jadohealth.2013.02.013 KQ1E7a, KQ2E7a, KQ3E7a23885960
187 Osterman, R, Lewis, D, . Efficacy of motivational enhancement therapy to decrease alcohol and illicit-drug use in pregnant substance users reporting baseline alcohol use. J Subst Abuse Treat. 77. 150–155. 2017. 10.1016/j.jsat.2017.02.003 KQ1E5a, KQ2E5a, KQ3E5a28254158
188 Palfai, T, Saitz, R, . Moderators of electronic screening and brief intervention for marijuana among students in a health center: eCHECKUP TO GO bolsters efforts of those who are already trying to change. Drug Alcohol Depend. 156. e170. 2015. 10.1016/j.drugalcdep.2015.07.462 KQ1E13, KQ2E13, KQ3E13
189 Palfai, TP, Saitz, R, . Web-based screening and brief intervention for student marijuana use in a university health center: pilot study to examine the implementation of eCHECKUP TO GO in different contexts. Addict Behav. 39(9): 1346–52. 2014. 10.1016/j.addbeh.2014.04.025 KQ1E6b, KQ2E6b, KQ3E6b24845164
190 Palfai, TP, Tahaney, K, . Readiness-to-change as a moderator of a web-based brief intervention for marijuana among students identified by health center screening. Drug Alcohol Depend. 161. 368–71. 2016. 10.1016/j.drugalcdep.2016.01.027 KQ1E6b, KQ2E6b, KQ3E6b26948755
191 Palinkas, LA, Atkins, CJ, . Social skills training for drug prevention in high-risk female adolescents. Prev Med. 25(6): 692–701. 1996. PMID: 8936571. 10.1006/pmed.1996.0108 KQ1E3, KQ2E3, KQ3E38936571
192 Pantin, H, Coatsworth, JD, . Familias Unidas: the efficacy of an intervention to promote parental investment in Hispanic immigrant families. Prev Sci. 4(3): 189–201. 2003. PMID: 12940469. KQ1E4, KQ2E4, KQ3E412940469
193 Pantin, H, Prado, G, . A randomized controlled trial of Familias Unidas for Hispanic adolescents with behavior problems. Psychosom Med. 71(9): 987–995. 2009. 10.1097/PSY.0b013e3181bb2913 KQ1E2, KQ2E2, KQ3E219834053
194 Parsons, JT, Lelutiu-Weinberger, C, . A randomized controlled trial utilizing motivational interviewing to reduce HIV risk and drug use in young gay and bisexual men. J Consult Clin Psychol. 82(1): 9–18. 2014. 10.1037/a0035311 KQ1E4, KQ2E4, KQ3E424364800
195 Perrier-Menard, E, Castellanos-Ryan, N, . The impact of youth internalising and externalising symptom severity on the effectiveness of brief personality-targeted interventions for substance misuse: A cluster randomised trial. Addict Behav. 75. 138–144. 2017. 10.1016/j.addbeh.2017.07.015 KQ1E2, KQ2E2, KQ3E228734153
196 Perrino, T, Brincks, A, . Reducing Internalizing Symptoms Among High-Risk, Hispanic Adolescents: Mediators of a Preventive Family Intervention. Prevention Science. 17(5): 595–605. 2016. 10.1007/s11121-016-0655-2 KQ1E2, KQ2E2, KQ3E227154768
197 Perrino, T, Pantin, H, . Reducing the Risk of Internalizing Symptoms among High-risk Hispanic Youth through a Family Intervention: A Randomized Controlled Trial. Fam Process. 55(1): 91–106. 2016. 10.1111/famp.12132 KQ1E2, KQ2E2, KQ3E225683164
198 Peterson, PL, Baer, JS, . Short-term effects of a brief motivational intervention to reduce alcohol and drug risk among homeless adolescents. Psychol Addict Behav. 20(3): 254–264. 2006. 10.1037/0893-164X.20.3.254 KQ1E6b, KQ2E6b, KQ3E6b16938063
199 Piehler, TF, Winters, KC. Decision-making style and response to parental involvement in brief interventions for adolescent substance use. Journal of Family Psychology. 31(3): 336–346. 2017. 10.1037/fam0000266 KQ1E6b, KQ2E6b, KQ3E6b27929312
200 Piehler, TF, Winters, KC. Parental involvement in brief interventions for adolescent marijuana use. Psychology of Addictive Behaviors. 29(3): 512–21. 2015. 10.1037/adb0000106 KQ1E6b, KQ2E6b, KQ3E6b26415058
201 Pischke, CR, Zeeb, H, . A feasibility trial to examine the social norms approach for the prevention and reduction of licit and illicit drug use in European University and college students. BMC Public Health. 12. 882. 2012. 10.1186/1471-2458-12-882 KQ1E4, KQ2E4, KQ3E423075043
202 Prado, G, Pantin, H, . A randomized controlled trial of a parent-centered intervention in preventing substance use and HIV risk behaviors in Hispanic adolescents. J Consult Clin Psychol. 75(6): 914–926. 2007. 10.1037/0022-006X.75.6.914 KQ1E2, KQ2E2, KQ3E218085908
203 Prado, Guillermo, Huang, Shi, . Ecodevelopmental and intrapersonal moderators of a family based preventive intervention for Hispanic youth: A latent profile analysis. Prevention Science. 14(3): 290–299. 2013. 10.1007/s11121-012-0326-x KQ1E2, KQ2E2, KQ3E223408280
204 Redmond, C, Spoth, R, . Modeling long-term parent outcomes of two universal family-focused preventive interventions: one-year follow-up results. J Consult Clin Psychol. 67(6): 975–84. 1999. PMID: 10596519. KQ1E4, KQ2E4, KQ3E410596519
205 Rhew, IC, Hawkins, JD, . Evaluation of Community-Level Effects of Communities That Care on Adolescent Drug Use and Delinquency Using a Repeated Cross-Sectional Design. Prevention Science. 17(2): 177–87. 2016. KQ1E7a, KQ2E7a, KQ3E7a26462492
206 Rhew, IC, Oesterle, S, . Effects of Exposure to the Communities That Care Prevention System on Youth Problem Behaviors in a Community-Randomized Trial: Employing an Inverse Probability Weighting Approach. Eval Health Prof. 41(2): 270–289. 2018. 10.1177/0163278718759397 KQ1E7a, KQ2E7a, KQ3E7a29463119
207 Rhoades, KimberlyA, Leve, LeslieD, . Drug use trajectories after a randomized controlled trial of MTFC: Associations with partner drug use. Journal of Research on Adolescence. 24(1): 40–54. 2014. 10.1111/jora.12077 KQ1E7a, KQ2E7a, KQ3E7a24729667
208 Riesch, SK, Brown, RL, . Strengthening families program (10-14): effects on the family environment. West J Nurs Res. 34(3): 340–376. 2012. 10.1177/0193945911399108 KQ1E2, KQ2E2, KQ3E221403057
209 Riggs, NathanielR, Chou, Chih-Ping, . Preventing growth in amphetamine use: Long-term effects of the Midwestern Prevention Project (MPP) from early adolescence to early adulthood. Addiction. 104(10): 1691–1699. 2009. 10.1111/j.1360-0443.2009.02666.x KQ1E7a, KQ2E7a, KQ3E7a19681799
210 Riggs, NathanielR, Pentz, Mary Ann. Long term effects of adolescent marijuana use prevention on adult mental health services utilization: The Midwestern prevention project. Subst Use Misuse. 44(5): 616–631. 2009. 10.1080/10826080902809691 KQ1E7a, KQ2E7a, KQ3E7a19360536
211 Riggs, Nr, Elfenbaum, P, . Parent program component analysis in a drug abuse prevention trial. J Adolesc Health. 39(1): 66–72. 2006. KQ1E7a, KQ2E7a, KQ3E7a16781963
212 Riggs, NR, Pentz, MA. Long-term effects of adolescent marijuana use prevention on adult mental health services utilization: the midwestern prevention project. Subst Use Misuse. 44(5): 616–31. 2009. 10.1080/10826080902809691 KQ1E7a, KQ2E7a, KQ3E7a19360536
213 Rogers, Er, King, Sr. Intervention based on social cognitive theory: evaluating adolescents’ knowledge of OTC pain medications. J Am Pharm Assoc (2003). 53(1): 30–38. 2013. 10.1331/JAPhA.2013.11231 KQ1E4, KQ2E4, KQ3E423636153
214 Rohrbach, Louise Ann, Gunning, Melissa, . The Project Towards No Drug Abuse (TND) Dissemination Trial: Implementation fidelity and immediate outcomes. Prevention Science. 11(1): 77–88. 2010. 10.1007/s11121-009-0151-z KQ1E2, KQ2E2, KQ3E219757052
215 Romero, E, Rodriguez, C, . Intervention on early-onset conduct problems as indicated prevention for substance use: A seven-year follow up. Adicciones. 29(3): 150–162. 2017. 10.20882/adicciones.722 KQ1E12, KQ2E12, KQ3E1227749966
216 Santos, GM, Coffin, PO, . Substance use and drinking outcomes in Personalized Cognitive Counseling randomized trial for episodic substance-using men who have sex with men. Drug Alcohol Depend. 138. 234–9. 2014. 10.1016/j.drugalcdep.2014.02.015 KQ1E5a, KQ2E5a, KQ3E5a24641808
217 Sawant, M, Wagner, E. Motivational interviewing with at risk American Indian teens: results from a randomized clinical trial. Alcoholism: clinical and experimental research. Conference: 39th annual scientific meeting of the research society on alcoholism. New orleans, LA united states. Conference start: 20160625. Conference end: 20160629. Conference publication: (var.pagings). 40. 266a. 2016. 10.1111/acer.13085 KQ1E13, KQ2E13, KQ3E13
218 Schinke, S, Schwinn, T. Gender-specific computer-based intervention for preventing drug abuse among girls. Am J Drug Alcohol Abuse. 31(4): 609–616. 2005. 10.1081/ada-200068415 KQ1E4, KQ2E4, KQ3E416320437
219 Schinke, StevenP, Schwinn, TraciM, . Reducing the Risks of Alcohol Use among Urban Youth: Three-Year Effects of a Computer-Based Intervention with and without Parent Involvement. J Stud Alcohol. 65(4): 443–449. 2004. KQ1E7b, KQ2E7b, KQ3E7b15376818
220 Schwinn, TM, Schinke, S, . A web-based, health promotion program for adolescent girls and their mothers who reside in public housing. Addict Behav. 39(4): 757–60. 2014. PMID: 24447886. 10.1016/j.addbeh.2013.11.029 KQ1E4, KQ2E4, KQ3E424447886
221 Scull, TM, Kupersmidt, JB, . The effectiveness of online, family-based media literacy education for substance abuse prevention in elementary school children: Study of the Media Detective Family program. J Community Psychol. 45(6): 796–809. 2017. 10.1002/jcop.21893 KQ1E4, KQ2E4, KQ3E428989205
222 Shepherd, S. Motivational intervention integrated into care of facial injury patients may reduce illicit drug use behaviours. Evid Based Dent. 13(3): 87–8. 2012. 10.1038/sj.ebd.6400880 KQ1E8, KQ2E8, KQ3E823059926
223 Shetgiri, Rashmi, Kataoka, Sheryl, . A randomized, controlled trial of a school-based intervention to reduce violence and substance use in predominantly Latino high school students. J Natl Med Assoc. 103(9-10): 932–940. 2011. 10.1016/S0027-9684%2815%2930450-8 KQ1E2, KQ2E2, KQ3E222364063
224 Shin, Y, Miller-Day, M, . Entertainment-Education Videos as a Persuasive Tool in the Substance Use Prevention Intervention “keepin’ it REAL”. Health Commun. 33(7): 896–906. 2018. 10.1080/10410236.2017.1321163 KQ1E2, KQ2E2, KQ3E228586239
225 Sinadinovic, Kristina, Wennberg, Peter, . Targeting problematic users of illicit drugs with internet-based screening and brief intervention: A randomized controlled trial. Drug Alcohol Depend. 126(1-2): 42–50. 2012. 10.1016/j.drugalcdep.2012.04.016 KQ1E5a, KQ2E5a, KQ3E5a22613182
226 Skarstrand, Eva, Sundell, Knut, . Evaluation of a Swedish version of the Strengthening Families Programme. Eur J Public Health. 24(4): 578–584. 2014. 10.1093/eurpub/ckt146 KQ1E2, KQ2E2, KQ3E424078373
227 Skeer, MR, Yantsides, KE, . Testing a Brief Substance Misuse Preventive Intervention for Parents of Pre-Adolescents: Feasibility, Acceptability, Preliminary Efficacy. J Child Fam Stud. 25(12): 3739–3748. 2016. PMID: 28163563. 10.1007/s10826-016-0525-3 KQ1E4, KQ2E4, KQ3E428163563
228 Slesnick, Natasha, Prestopnik, JillianL, . Treatment outcome for street-living, homeless youth. Addict Behav. 32(6): 1237–1251. 2007. 10.1016/j.addbeh.2006.08.010 KQ1E6b, KQ2E6b, KQ3E6b16989957
229 Smith, DC, Davis, JP, . Normative Feedback and Adolescent Readiness to Change: A Small Randomized Trial. Res Soc Work Pract. 25(7): 801–814. 2015. PMID: 26877622. 10.1177/1049731514535851 KQ1E6b, KQ2E6b, KQ3E6b26877622
230 Smith, DC, Ureche, DJ, . Motivational Interviewing With and Without Normative Feedback for Adolescents With Substance Use Problems: A Preliminary Study. Subst Abus. 36(3): 350–8. 2015. PMID: 25551562. 10.1080/08897077.2014.988838 KQ1E6b, KQ2E6b, KQ3E6b25551562
231 Snyder, FJ, Acock, AC, . Preventing negative behaviors among elementary-school students through enhancing students’ social-emotional and character development. American Journal of Health Promotion. 28(1): 50–8. 2013. 10.4278/ajhp.120419-QUAN-207.2 KQ1E7a, KQ2E7a, KQ3E7a23470183
232 Spirito, A, Hernandez, L, . Effects of a brief, parent-focused intervention for substance using adolescents and their sibling. J Subst Abuse Treat. 77. 156–165. 2017. PMID: 28259500. 10.1016/j.jsat.2017.02.002 KQ1E3, KQ2E3, KQ3E328259500
233 Spirito, A, Hernandez, L, . Improving parenting and parent-teen communication to delay or prevent the onset of alcohol and drug use in young adolescents with emotional/behavioral disorders: A pilot trial. J Child Adolesc Subst Abuse. 24(5): 308–322. 2015. PMID: 26478690. 10.1080/1067828x.2013.829013 KQ1E3, KQ2E3, KQ3E326478690
234 Spirito, A, Hernandez, L, . Parent and Adolescent Motivational Enhancement Intervention for Substance-Using, Truant Adolescents: A Pilot Randomized Trial. J Clin Child Adolesc Psychol. 1–13. 2017. 10.1080/15374416.2017.1399402 KQ1E6b, KQ2E6b, KQ3E6b
235 Spoth, R, Lopez Reyes, M, . Assessing a public health approach to delay onset and progression of adolescent substance use: latent transition and log-linear analyses of longitudinal family preventive intervention outcomes. J Consult Clin Psychol. 67(5): 619–30. 1999. PMID: 10535229. KQ1E4, KQ2E4, KQ3E410535229
236 Spoth, R, Redmond, C, . Brief family intervention effects on adolescent substance initiation: school-level growth curve analyses 6 years following baseline. J Consult Clin Psychol. 72(3): 535–42. 2004. PMID: 15279537. 10.1037/0022-006X.72.3.535 KQ1E2, KQ2E2, KQ3E215279537
237 Spoth, R, Redmond, C, . Corrections: preventing substance misuse through community-university partnerships: randomized controlled trial outcomes 4.5 years past baseline (American Journal of Preventive Medicine (2011) 40, 4 (440-447)). Am J Prev Med. 48(1): 120. 2015. 10.1016/j.amepre.2014.09.023 KQ1E7a, KQ2E7a, KQ3E7a
238 Spoth, R, Redmond, C, . Corrigendum to “PROSPER community-university partnership delivery system effects on substance misuse through 6 1/2years past baseline from a cluster randomized controlled intervention trial”. Prev Med. 69. 1. 2013. 10.1016/j.ypmed.2014.07.011 KQ1E7a, KQ2E7a, KQ3E7a
239 Spoth, R, Redmond, C, . Preventing substance misuse through community-university partnerships: randomized controlled trial outcomes 41/2 years past baseline.[Erratum appears in Am J Prev Med. 2015 Jan;48(1):120]. Am J Prev Med. 40(4): 440–7. 2011. 10.1016/j.amepre.2010.12.012 KQ1E7a, KQ2E7a, KQ3E7a21406278
240 Spoth, R, Redmond, C, . PROSPER delivery of universal preventive interventions with young adolescents: long-term effects on emerging adult substance misuse and associated risk behaviors. Psychol Med. 47(13): 2246–2259. 2017. 10.1017/S0033291717000691 KQ1E7a, KQ2E7a, KQ3E7a28399955
241 Spoth, R, Redmond, C, . Substance-use outcomes at 18 months past baseline: the PROSPER Community-University Partnership Trial.[Erratum appears in Am J Prev Med. 2015 Jan;48(1):120]. Am J Prev Med. 32(5): 395–402. 2007. KQ1E7a, KQ2E7a, KQ3E7a17478265
242 Spoth, R, Trudeau, L, . Longitudinal effects of universal preventive intervention on prescription drug misuse: three randomized controlled trials with late adolescents and young adults. Am J Public Health. 103(4): 665–72. 2013. PMID: 23409883. 10.2105/ajph.2012.301209 KQ1E2, KQ2E2, KQ3E223409883
243 Spoth, R, Trudeau, L, . Long-term effects of universal preventive interventions on prescription drug misuse. Addiction. 103(7): 1160–8. 2008. PMID: 18557842. 10.1111/j.1360-0443.2008.02160.x KQ1E2, KQ2E2, KQ3E218557842
244 Spoth, R, Trudeau, L, . Replicating and extending a model of effects of universal preventive intervention during early adolescence on young adult substance misuse. J Consult Clin Psychol. 84(10): 913–21. 2016. PMID: 27548031. 10.1037/ccp0000131 KQ1E2, KQ2E2, KQ3E227548031
245 Spoth, R, Trudeau, L, . Replication RCT of early universal prevention effects on young adult substance misuse. J Consult Clin Psychol. 82(6): 949–63. 2014. PMID: 24821095. 10.1037/a0036840 KQ1E2, KQ2E2, KQ3E224821095
246 Spoth, Richard, Guyll, Max, . Universal intervention as a protective shield against exposure to substance use: Long-term outcomes and public health significance. Am J Public Health. 99(11): 2026–2033. 2009. 10.2105/AJPH.2007.133298 KQ1E2, KQ2E2, KQ3E219762678
247 Spoth, Richard, Randall, G, . Increasing school success through partnership-based family competency training: Experimental study of long-term outcomes. School Psychology Quarterly. 23(1): 70–89. 2008. 10.1037/1045-3830.23.1.70 KQ1E2, KQ2E2, KQ3E220376279
248 Spoth, Richard, Redmond, Cleve, . Preventing substance misuse through community-university partnerships: Randomized controlled trial outcomes 41/2 years past baseline. Am J Prev Med. 40(4): 440–447. 2011. 10.1016/j.amepre.2010.12.012 KQ1E7a, KQ2E7a, KQ3E7a21406278
249 Spoth, Richard, Redmond, Cleve, . PROSPER community-university partnership delivery system effects on substance misuse through 6 1/2 years past baseline from a cluster randomized controlled intervention trial. Preventive Medicine: An International Journal Devoted to Practice and Theory. 56(3-4): 190–196. 2013. 10.1016/j.ypmed.2012.12.013 KQ1E7a, KQ2E7a, KQ3E7a
250 Spoth, Richard, Redmond, Cleve, . Substance-use outcomes at 18 months past baseline: The PROSPER community-university partnership trial. Am J Prev Med. 32(5): 395–402. 2007. 10.1016/j.amepre.2007.01.014 KQ1E7a, KQ2E7a, KQ3E7a17478265
251 Spoth, Richard, Trudeau, Linda, . Universal intervention effects on substance use among young adults mediated by delayed adolescent substance initiation. J Consult Clin Psychol. 77(4): 620–632. 2009. 10.1037/a0016029 KQ1E2, KQ2E2, KQ3E219634956
252 Spoth, RichardL, Randall, G, . Substance use outcomes 5 1/2 years past baseline for partnership-based, family-school preventive interventions. Drug Alcohol Depend. 96(1-2): 57–68. 2008. 10.1016/j.drugalcdep.2008.01.023 KQ1E2, KQ2E2, KQ3E218434045
253 Spoth, RL, Redmond, C, . Longitudinal substance initiation outcomes for a universal preventive intervention combining family and school programs. Psychol Addict Behav. 16(2): 129–34. 2002. PMID: 12079251. KQ1E7a, KQ2E7a, KQ3E7a12079251
254 Spoth, RL, Redmond, C, . Randomized trial of brief family interventions for general populations: adolescent substance use outcomes 4 years following baseline. J Consult Clin Psychol. 69(4): 627–42. 2001. PMID: 11550729. KQ1E2, KQ2E2, KQ3E211550729
255 Spoth, RL, Trudeau, LS, . Benefits of universal intervention effects on a youth protective shield 10 years after baseline. J Adolesc Health. 50(4): 414–7. 2012. 10.1016/j.jadohealth.2011.06.010 KQ1E2, KQ2E2, KQ3E222443848
256 Stanton, B, Cole, M, . Randomized trial of a parent intervention: parents can make a difference in long-term adolescent risk behaviors, perceptions, and knowledge. Arch Pediatr Adolesc Med. 158(10): 947–55. 2004. PMID: 15466681. 10.1001/archpedi.158.10.947 KQ1E3, KQ2E3, KQ3E315466681
257 Stanton, BF, Li, X, . Parental underestimates of adolescent risk behavior: a randomized, controlled trial of a parental monitoring intervention. J Adolesc Health. 26(1): 18–26. 2000. PMID: 10638714. KQ1E4, KQ2E4, KQ3E410638714
258 Stappenbeck, J, Wendell, A, . Evaluation of the Family-based Familien stärken-Program for Preventing Substance Abuse and Behavior Problems in Youth. Gesundheitswesen. 77 Suppl 1. S74–5. 2015. 10.1055/s-0032-1333246 KQ1E12, KQ2E12, KQ3E12
259 Stein, MD, Caviness, CM, . A developmental-based motivational intervention to reduce alcohol and marijuana use among non-treatment-seeking young adults: a randomized controlled trial. Addiction. 113(3): 440–453. 2018. 10.1111/add.14026 KQ1E6b, KQ2E6b, KQ3E6b28865169
260 Stephens, RS, Roffman, RA, . The Marijuana Check-up: promoting change in ambivalent marijuana users. Addiction. 102(6): 947–57. 2007. KQ1E6b, KQ2E6b, KQ3E6b17523990
261 Sterling, S, Kline-Simon, AH, . Implementation of Screening, Brief Intervention, and Referral to Treatment for Adolescents in Pediatric Primary Care: A Cluster Randomized Trial. JAMA Pediatr. 169(11): e153145. 2015. PMID: 26523821. 10.1001/jamapediatrics.2015.3145 KQ1E4, KQ2E4, KQ3E426523821
262 Sterling, S, Kline-Simon, AH, . Pediatrician and Behavioral Clinician-Delivered Screening, Brief Intervention and Referral to Treatment: Substance Use and Depression Outcomes. J Adolesc Health. 62(4): 390–396. 2018. 10.1016/j.jadohealth.2017.10.016 KQ1E4, KQ2E4, KQ3E429396080
263 Stewart, DG, Siebert, EC, . READY or Not: Findings From a School-Based MI Intervention for Adolescent Substance Use. J Subst Abuse Treat. 71. 23–29. 2016. 10.1016/j.jsat.2016.08.007 KQ1E6b, KQ2E6b, KQ3E6b27776673
264 Stock, C, Vallentin-Holbech, L, . The GOOD life: study protocol for a social norms intervention to reduce alcohol and other drug use among Danish adolescents. BMC Public Health. 15. 704. 2016. 10.1186/s12889-016-3333-1 KQ1E7a, KQ2E7a, KQ3E7a27488390
265 Stolle, Martin, Stappenbeck, Julian, . Family-based prevention against substance abuse and behavioral problems: Culture-sensitive adaptation process for the modification of the US-American Strengthening Families Program 10-14 to German conditions. J Public Health (Bangkok). 19(4): 389–395. 2011. 10.1007/s10389-011-0405-7 KQ1E8, KQ2E8, KQ3E8
266 Stormshak, E, Caruthers, A, . Reducing Risk Behavior with Family-Centered Prevention During the Young Adult Years. Prev Sci. 2018. PMID: 2995197429951974. 10.1007/s11121-018-0917-2 KQ1E4, KQ2E4, KQ3E4
267 Stormshak, EA, Connell, AM, . An ecological approach to promoting early adolescent mental health and social adaptation: family-centered intervention in public middle schools. Child Dev. 82(1): 209–25. 2011. PMID: 21291438. 10.1111/j.1467-8624.2010.01551.x KQ1E7a, KQ2E7a, KQ3E7a21291438
268 Sussman, S, Sun, P, . One-year outcomes of a drug abuse prevention program for older teens and emerging adults: evaluating a motivational interviewing booster component. Health Psychol. 31(4): 476–85. 2012. 10.1037/a0025756 KQ1E2, KQ2E2, KQ3E221988096
269 Tait, RJ, McKetin, R, . Six-month outcomes of a Web-based intervention for users of amphetamine-type stimulants: randomized controlled trial. J Med Internet Res. 17(4): e105. 2015. 10.2196/jmir.3778 KQ1E6b, KQ2E6b, KQ3E6b25925801
270 Tait, RJ, Teoh, L, . Emergency department based intervention with adolescent substance users: 10year economic and health outcomes. Drug Alcohol Depend. 165. 168–74. 2016. 10.1016/j.drugalcdep.2016.06.005 KQ1E4, KQ2E4, KQ3E427317044
271 Teesson, M, Newton, N, . An integrated approach to substance use prevention for high-and lowrisk youth: the cap intervention. Alcoholism: clinical and experimental research. 37. 148a. 2013. 10.1111/acer.12162 KQ1E2, KQ2E2, KQ3E2
272 Teesson, Maree, Newton, NicolaC, . The CLIMATE schools combined study: A cluster randomised controlled trial of a universal Internet-based prevention program for youth substance misuse, depression and anxiety. BMC Psychiatry Vol 14 2014, ArtID 32. 14 2014. 10.1186/1471-244X-14-32 KQ1E2, KQ2E2, KQ3E2
273 Thurheimer, J, Sereika, SM, . Efficacy of the READY-Girls Program on General Risk-Taking Behaviors, Condom Use, and Sexually Transmitted Infections Among Young Adolescent Females With Type 1 Diabetes. Diabetes Educator. 42(6): 712–720. 2016. KQ1E7b, KQ2E7b, KQ3E7b27630009
274 Tingey, Lauren, Larzelere-Hinton, Francene, . Entrepreneurship education: A strength-based approach to substance use and suicide prevention for American Indian adolescents. Am Indian Alsk Native Ment Health Res. 23(3): 248–270. 2016. 10.5820/aian.2303.2016.248 KQ1E7a, KQ2E7a, KQ3E7a27383095
275 Tossmann, HP, Jonas, B, . A controlled trial of an internet-based intervention program for cannabis users. Cyberpsychol Behav Soc Netw. 14(11): 673–9. 2011. 10.1089/cyber.2010.0506 KQ1E6b, KQ2E6b, KQ3E6b21651419
276 Tucker, JS, D’Amico, EJ, . A group-based motivational interviewing brief intervention to reduce substance use and sexual risk behavior among homeless young adults. J Subst Abuse Treat. 76. 20–27. 2017. 10.1016/j.jsat.2017.02.008 KQ1E6b, KQ2E6b, KQ3E6b28340904
277 Valdez, Avelardo, Cepeda, Alice, . An adapted brief strategic family therapy for gang-affiliated Mexican American adolescents. Res Soc Work Pract. 23(4): 383–396. 2013. 10.1177/1049731513481389 KQ1E6b, KQ2E6b, KQ3E6b
278 Vallentin-Holbech, L, Rasmussen, BM, . Are perceptions of social norms regarding peer alcohol and other drug use associated with personal use in Danish adolescents?. Scand J Public Health. 45(8): 757–764. PMID: 28810812. KQ1E4, KQ2E4, KQ3E428810812
279 Van Horn, ML, Fagan, AA, . Effects of the Communities That Care system on cross-sectional profiles of adolescent substance use and delinquency. Am J Prev Med. 47(2): 188–97. 2014. 10.1016/j.amepre.2014.04.004 KQ1E7a, KQ2E7a, KQ3E7a24986217
280 Van Ryzin, MJ, Stormshak, EA, . Engaging parents in the family check-up in middle school: longitudinal effects on family conflict and problem behavior through the high school transition. J Adolesc Health. 50(6): 627–33. 2012. PMID: 22626491. 10.1016/j.jadohealth.2011.10.255 KQ1E7a, KQ2E7a, KQ3E7a22626491
281 Vidot, DC, Huang, S, . Familias Unidas’ Crossover Effects on Suicidal Behaviors among Hispanic Adolescents: Results from an Effectiveness Trial. Suicide Life Threat Behav. 46 Suppl 1. S8–14. 2016. 10.1111/sltb.12253 KQ1E2, KQ2E2, KQ3E2
282 Vogl, Laura Elise, Newton, Nicola Clare, . A universal harm-minimisation approach to preventing psychostimulant and cannabis use in adolescents: A cluster randomised controlled trial. Substance Abuse Treatment, Prevention, and Policy Vol 9 2014, ArtID 24. 9 2014. KQ1E2, KQ2E2, KQ3E2
283 Wagner, EF, Hospital, MM, . A randomized controlled trial of guided self-change with minority adolescents. J Consult Clin Psychol. 82(6): 1128–39. 2014. 10.1037/a0036939 KQ1E6b, KQ2E6b, KQ3E6b24841864
284 Wagner, Ef, Morris, Sl, . Examiningthe effectiveness of an alcohol-targeted text messaging intervention with minority adolescents. Alcoholism: clinical and experimental research. 37. 284a. 2013. 10.1111/acer.12163 KQ1E7b, KQ2E7b, KQ3E7b
285 Walker, DD, Stephens, R, . Randomized controlled trial of motivational enhancement therapy with nontreatment-seeking adolescent cannabis users: a further test of the teen marijuana check-up. Psychol Addict Behav. 25(3): 474–84. 2011. 10.1037/a0024076 KQ1E6b, KQ2E6b, KQ3E6b21688877
286 Walker, DD, Stephens, RS, . Augmenting brief interventions for adolescent marijuana users: The impact of motivational check-ins. J Consult Clin Psychol. 84(11): 983–992. 2016. PMID: 27762569. 10.1037/ccp0000094 KQ1E6b, KQ2E6b, KQ3E6b27762569
287 Watson, J, Back, D, . A randomised controlled feasibility trial of family and social network intervention for young people who misuse alcohol and drugs: study protocol (Y-SBNT). Pilot Feasibility Stud. 1. 8. 2015. PMID: 27965788. 10.1186/s40814-015-0004-4 KQ1E6b, KQ2E6b, KQ3E6b27965788
288 Watson, J, Toner, P, . Youth social behaviour and network therapy (Y-SBNT): adaptation of a family and social network intervention for young people who misuse alcohol and drugs - a randomised controlled feasibility trial. Health Technol Assess. 21(15): 1–260. 2017. PMID: 28399988. 10.3310/hta21150 KQ1E6b, KQ2E6b, KQ3E6b28399988
289 Wechsberg, WM, Novak, SP, . Sustainability of intervention effects of an evidence-based HIV prevention intervention for African American women who smoke crack cocaine. Drug Alcohol Depend. 109(1-3): 205–212. 2010. 10.1016/j.drugalcdep.2010.01.014 KQ1E5a, KQ2E5a, KQ3E5a20219294
290 Werch, CC, Moore, MJ, . A multihealth behavior intervention integrating physical activity and substance use prevention for adolescents. Prev Sci. 6(3): 213–26. 2005. PMID: 16133900. 10.1007/s11121-005-0012-3 KQ1E7b, KQ2E7b, KQ3E7b16133900
291 Werch, CE, Bian, H, . Brief multiple behavior health interventions for older adolescents. American Journal of Health Promotion. 23(2): 92–6. 2008. 10.4278/ajhp.07040533 KQ1E9, KQ2E9, KQ3E919004157
292 Werch, CE, Moore, MJ, . Efficacy of a brief image-based multiple-behavior intervention for college students. Annals of Behavioral Medicine. 36(2): 149–57. 2008. 10.1007/s12160-008-9055-6 KQ1E7b, KQ2E7b, KQ3E7b18800217
293 Werch, CE, Moore, MM, . Single vs. multiple drug prevention: is more always better?: a pilot study. Subst Use Misuse. 40(8): 1085–101. 2005. PMID: 16040370. 10.1081/JA-200030814 KQ1E3, KQ2E3, KQ3E316040370
294 Whicher, EmmaV, Utku, Ferhal, . Pilot project to evaluate the effectiveness and acceptability of single-session brief counseling for the prevention of substance misuse in pregnant adolescents. Addict Disord Their Treat. 11(1): 43–49. 2012. 10.1097/ADT.0b013e3182387029 KQ1E8, KQ2E8, KQ3E8
295 White, Hr, Jiao, Y, . Effects of brief alcohol-focused interventions on marijuana use among college students. Alcoholism: clinical and experimental research. 39. 208a. 2015. 10.1111/acer.12741 KQ1E7b, KQ2E7b, KQ3E7b
296 White, J, Hawkins, J, . Adaptation of the ASSIST peer-led smoking intervention to deliver information from the Talk to FRANK drug education website (ASSIST+FRANK): a pilot cluster-randomised controlled trial. The lancet. Conference: public health science conference 2017. United kingdom. 390(Spec.iss 1): S1. 2017. KQ1E7a, KQ2E7a, KQ3E7a
297 White, J, Hawkins, J, . Public Health Research. Adapting the ASSIST model of informal peer-led intervention delivery to the Talk to FRANK drug prevention programme in UK secondary schools (ASSIST + FRANK): intervention development, refinement and a pilot cluster randomised controlled trial. 2017. 10.3310/phr05070 KQ1E7a, KQ2E7a, KQ3E7a
298 Williams, C, Griffin, KW, . Efficacy of a drug prevention CD-ROM intervention for adolescents. Subst Use Misuse. 40(6): 869–878. 2005. 10.1081/ja-200042219 KQ1E9, KQ2E9, KQ3E915974146
299 Winters, K. Parents as interventionists to address adolescent drug abuse. Drug Alcohol Depend. 156. e240. 2015. 10.1016/j.drugalcdep.2015.07.647 KQ1E13, KQ2E13, KQ3E13
300 Winters, KC, Lee, S, . One-year outcomes and mediators of a brief intervention for drug abusing adolescents. Psychol Addict Behav. 28(2): 464–74. 2014. PMID: 24955669. 10.1037/a0035041 KQ1E6b, KQ2E6b, KQ3E6b24955669
301 Wolchik, SA, Millsap, RE. Group based interventions for mothers and mothers plus children reduced mental health problems in adolescent children of divorced parents. Evid Based Nurs. 6(3): 74. 2003. 10.1136/ebn.6.3.74 KQ1E8, KQ2E8, KQ3E812882187
302 Wolchik, SA, Sandler, IN, . Fifteen-year follow-up of a randomized trial of a preventive intervention for divorced families: effects on mental health and substance use outcomes in young adulthood. J Consult Clin Psychol. 81(4): 660–73. 2013. PMID: 23750466. 10.1037/a0033235 KQ1E7b, KQ2E7b, KQ3E7b23750466
303 Wolchik, SA, Sandler, IN, . Six-year follow-up of preventive interventions for children of divorce: a randomized controlled trial. JAMA. 288(15): 1874–1881. 2002. 10.1001/jama.288.15.1874 KQ1E7b, KQ2E7b, KQ3E7b12377086
304 Wolchik, SA, Tein, JY, . Developmental cascade models of a parenting-focused program for divorced families on mental health problems and substance use in emerging adulthood. Dev Psychopathol. 28(3): 869–88. 2016. 10.1017/S0954579416000365 KQ1E7b, KQ2E7b, KQ3E7b27427811
305 Woodruff, SI, Clapp, JD, . Randomized clinical trial of the effects of screening and brief intervention for illicit drug use: the Life Shift/Shift Gears study. Addict Sci Clin Pract. 9. 8. 2014. 10.1186/1940-0640-9-8 KQ1E5a, KQ2E5a, KQ3E5a24886786
306 Wright, CJ, Dietze, PM, . An Ecological Momentary Intervention to Reduce Alcohol Consumption in Young Adults Delivered During Drinking Events: Protocol for a Pilot Randomized Controlled Trial. JMIR Res Protoc. 6(5): e95. 2017. 10.2196/resprot.6760 KQ1E7b, KQ2E7b, KQ3E7b28546136
307 Wu, Y, Stanton, BF, . Sustaining and broadening intervention impact: a longitudinal randomized trial of 3 adolescent risk reduction approaches. Pediatrics. 111(1): e32–8. 2003. PMID: 12509592. KQ1E3, KQ2E3, KQ3E312509592
308 Yonkers, KA, Forray, A, . Motivational enhancement therapy coupled with cognitive behavioral therapy versus brief advice: a randomized trial for treatment of hazardous substance use in pregnancy and after delivery. Gen Hosp Psychiatry. 34(5): 439–49. 2012. 10.1016/j.genhosppsych.2012.06.002 KQ1E6b, KQ2E6b, KQ3E6b22795046
309 Yurasek, A, Fernandez, A, . Do alcohol-focused interventions reduce marijuana use in mandated college students?. Drug Alcohol Depend. 156. e243–e244. 2015. 10.1016/j.drugalcdep.2015.07.656 KQ1E13, KQ2E13, KQ3E13
310 Yurasek, AliM. A randomized controlled trial of a behavioral economic intervention for substance abuse in a diverse college sample. Dissertation Abstracts International: Section B: The Sciences and Engineering. 76(6-B(E)). 2015. KQ1E6b, KQ2E6b, KQ3E6b
311 Yurasek, AM, Dennhardt, AA, . A randomized controlled trial of a behavioral economic intervention for alcohol and marijuana use. Exp Clin Psychopharmacol. 23(5): 332–8. 2015. 10.1037/pha0000025 KQ1E3, KQ2E3, KQ3E326191947
312 Zahradnik, A, Otto, C, . Randomized controlled trial of a brief intervention for problematic prescription drug use in non-treatment-seeking patients. Addiction. 104(1): 109–117. 2009. 10.1111/j.1360-0443.2008.02421.x KQ1E5a, KQ2E5a, KQ3E5a19133895
313 Zatzick, D, Russo, J, . Collaborative care intervention targeting violence risk behaviors, substance use, and posttraumatic stress and depressive symptoms in injured adolescents: a randomized clinical trial. JAMA Pediatr. 168(6): 532–9. 2014. 10.1001/jamapediatrics.2013.4784 KQ1E2, KQ2E2, KQ3E224733515
314 Zellner, T, Trotter, J, . Color It Real: A Program to Increase Condom Use and Reduce Substance Abuse and Perceived Stress. Int J Environ Res Public Health. 13(1): ijerph13010051. 2015. PMID: 26703653. 10.3390/ijerph13010051 KQ1E4, KQ2E4, KQ3E426703653