# Appendix B Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

Baldus, C, Thomsen, M, Evaluation of a German version of the Strengthening Families Programme 10-14: a randomised controlled trial. Eur J Public Health. 26(6): 953–959. 2016. 10.1093/eurpub/ckw082 27374805
Broning, S, Sack, PM, Implementing and evaluating the German adaptation of the “Strengthening Families Program 10 - 14”- a randomized-controlled multicentre study. BMC Public Health. 14. 83. 2014. 10.1186/1471-2458-14-83 24467917
Broning, Sonja, Baldus, Christiane, Children with elevated psychosocial risk load benefit most from a family-based preventive intervention: Exploratory differential analyses from the German “Strengthening Families Program 10-14” adaptation trial. Prevention Science. 18(8): 932–942. 2017. 10.1007/s11121-017-0797-x 28643133
Bannink, R, Broeren, S, Effectiveness of a Web-based tailored intervention (E-health4Uth) and consultation to promote adolescents’ health: randomized controlled trial. J Med Internet Res. 16(5): e143. 2014. 10.2196/jmir.3163 24878521
Barlow, A, Varipatis-Baker, E, Home-visiting intervention to improve child care among American Indian adolescent mothers: a randomized trial. Arch Pediatr Adolesc Med. 160(11): 1101–7. 2006. PMID: 17088511. 10.1001/archpedi.160.11.1101 17088511
Barlow, Allison, Mullany, Britta, Effect of a paraprofessional home-visiting intervention on American Indian teen mothers’ and infants’ behavioral risks: A randomized controlled trial. Am J Psychiatry. 170(1): 83–93. 2013. 10.1176/appi.ajp.2012.12010121 23409290
Barlow, A, Mullany, B, Paraprofessional-delivered home-visiting intervention for American Indian teen mothers and children: 3-year outcomes from a randomized controlled trial. Am J Psychiatry. 172(2): 154–62. 2015. 10.1176/appi.ajp.2014.14030332 25321149
Mullany, Britta, Barlow, Allison, The Family Spirit Trial for American Indian teen mothers and their children: CBPR rationale, design, methods and baseline characteristics. Prevention Science. 13(5): 504–518. 2012. 10.1007/s11121-012-0277-2 22932743
D’Amico, EJ, Parast, L, Brief motivational interviewing intervention to reduce alcohol and marijuana use for at-risk adolescents in primary care. J Consult Clin Psychol. 86(9): 775–786. 2018. PMID: 30138016. 10.1037/ccp0000332 30138016
Dembo, Richard, Briones-Robinson, Rhissa, Brief intervention impact on truant youths’ marijuana use: Eighteen-month follow-up. J Child Adolesc Subst Abuse. 25(1): 18–32. 2016. 10.1080/1067828X.2013.872068
Dembo, Richard, Cervenka, KathleenA, Engaging high risk families in community based intervention services. Aggress Violent Behav. 4(1): 41–58. 1999. 10.1016/S1359-1789%2897%2900028-1
Estrada, Y, Lee, TK, eHealth Familias Unidas: Efficacy Trial of an Evidence-Based Intervention Adapted for Use on the Internet with Hispanic Families. Prevention Science. 10. 10. 2018. 10.1007/s11121-018-0905-6
Fang, L, Schinke, SP, Preventing substance use among early Asian-American adolescent girls: initial evaluation of a web-based, mother-daughter program. J Adolesc Health. 47(5): 529–532. 2010.20970090
Fang, L, Schinke, SP. Two-year outcomes of a randomized, family-based substance use prevention trial for Asian American adolescent girls. Psychol Addict Behav. 2012.
Foxcroft, DR, Callen, H, Effectiveness of the strengthening families programme 10-14 in Poland: cluster randomized controlled trial. Eur J Public Health. 27(3): 494–500. 2017. 10.1093/eurpub/ckw195 28339547
Gmel, G, Gaume, J, Effectiveness of a brief integrative multiple substance use intervention among young men with and without booster sessions. J Subst Abuse Treat. 44(2): 231–40. 2013. 10.1016/j.jsat.2012.07.005 22885010
Harris, SK, Csemy, L, Computer-facilitated substance use screening and brief advice for teens in primary care: an international trial. Pediatrics. 129(6): 1072–1082. 2012.22566420
Jalling, Camilla, Bodin, Maria, Parent programs for reducing adolescent’s antisocial behavior and substance use: A randomized controlled trial. J Child Fam Stud. 25(3): 811–826. 2016. 10.1007/s10826-015-0263-y 26900316
Johnson, Sarah Lindstrom, Jones, Vanya, Promoting “healthy futures” to reduce risk behaviors in urban youth: A randomized controlled trial. Am J Community Psychol. 56(1-2): 36–45. 2015. 10.1007/s10464-015-9734-y 26122751
Kerr, JC, Valois, RF, Effects of Promoting Health Among Teens on Dietary, Physical Activity and Substance Use Knowledge and Behaviors for African American Adolescents. American Journal of Health Education. 44(4): 191–202. 2013.23957017
Kim, HK, Leve, LD. Substance use and delinquency among middle school girls in foster care: a three-year follow-up of a randomized controlled trial. J Consult Clin Psychol. 79(6): 740–750. 2011. 10.1037/a0025949 22004305
Kim, HK, Pears, KC, Intervention Effects on Health-Risking Sexual Behavior Among Girls in Foster Care: The Role of Placement Disruption and Tobacco and Marijuana Use. J Child Adolesc Subst Abuse. 22(5): 370–387. 2013.24043921
Knight JR, Sherritt L, Gibson EB, Effect of Computer-Based Substance Use Screening and Brief Behavioral Counseling vs Usual Care for Youths in Pediatric Primary Care: A Pilot Randomized Clinical Trial. JAMA Netw Open. 2019;2(6):e196258.31225897
Lee, CM, Neighbors, C, A brief, web-based personalized feedback selective intervention for college student marijuana use: a randomized clinical trial. Psychology of Addictive Behaviors. 24(2): 265–73. 2010. 10.1037/a0018859 20565152
Malmberg, M, Kleinjan, M, Effectiveness of the ‘Healthy School and Drugs’ prevention programme on adolescents’ substance use: a randomized clustered trial. Addiction. 109(6): 1031–40. 2014. 10.1111/add.12526 24612164
Malmberg, M, Kleinjan, M, Substance use outcomes in the Healthy School and Drugs program: results from a latent growth curve approach. Addict Behav. 42. 194–202. 2015. 10.1016/j.addbeh.2014.11.021 25481454
Mason, M, Light, J, Peer Network Counseling with Urban Adolescents: A Randomized Controlled Trial with Moderate Substance Users. J Subst Abuse Treat. 58. 16–24. 2015. PMID: 26234955. 10.1016/j.jsat.2015.06.013 26234955
Rhee, H, Hollen, PJ, Decision-making program for rural adolescents with asthma: a pilot study. J Pediatr Nurs. 23(6): 439–450. 2008.19026912
Sanci, L, Chondros, P, Responding to Young People’s Health Risks in Primary Care: A Cluster Randomised Trial of Training Clinicians in Screening and Motivational Interviewing. PLoS One. 10(9): e0137581. 2015. 10.1371/journal.pone.0137581 26422235
Schinke, SP, Fang, L, Computer-delivered, parent-involvement intervention to prevent substance use among adolescent girls. Prev Med. 49(5): 429–435. 2009.19682490
Schinke, SP, Fang, L, Preventing substance use among adolescent girls: 1-year outcomes of a computerized, mother-daughter program. Addict Behav. 34(12): 1060–1064. 2009.19632053
Schwinn, TM, Schinke, SP, An Online Drug Abuse Prevention Program for Adolescent Girls: Posttest and 1-Year Outcomes. J Youth Adolesc. 2017. PMID: 2875524728755247. 10.1007/s10964-017-0714-4
Schwinn, T, Hopkins, J, Using Facebook ads with traditional paper mailings to recruit adolescent girls for a clinical trial. Addict Behav. 65. 207–213. 2017. 10.1016/j.addbeh.2016.10.011 27835860
Schwinn, TM, Schinke, SP, Preventing drug abuse among adolescent girls: outcome data from an internet-based intervention. Prev Sci. 11(1): 24–32. 2010. 10.1007/s11121-009-0146-9 19728091
Schwinn, TM, Thom, B, Preventing drug use among sexual-minority youths: findings from a tailored, web-based intervention. J Adolesc Health. 56(5): 571–3. 2015. PMID: 25744209. 10.1016/j.jadohealth.2014.12.015 25744209
Walkup, JT, Barlow, A, Randomized controlled trial of a paraprofessional-delivered in-home intervention for young reservation-based American Indian mothers. J Am Acad Child Adolesc Psychiatry. 48(6): 591–601. 2009. 10.1097/CHI.0b013e3181a0ab86 19454915
Walton, MA, Bohnert, K, Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: One year outcomes. Drug Alcohol Depend. 2013.
Walton, MA, Resko, S, A randomized controlled trial testing the efficacy of a brief cannabis universal prevention program among adolescents in primary care. Addiction. 109(5): 786–97. 2014. PMID: 24372937. 10.1111/add.12469 24372937