# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Sources searched:

Cochrane Central Register of Controlled Clinical Trials, via Wiley

Medline, via Ovid

PsycInfo, via Ovid

PubMed, publisher-supplied records

Key:

- * = truncation
- ab = word in abstract
- ag= age group
- id = keyword
- kf = keyword heading [word not phrase indexed]
- kw = keyword
- md= methodology
- ti = word in title

CENTRAL, Issue 1 of 12, January 2019

#1 | (drug or drugs or substance*):ti,ab,kw near/1 (use or using):ti,ab,kw
#2 | (drug or drugs or substance*) near/5 (abuse* or abusing or misus* or overus* or overutili* or nonprescri* or (non next prescri*) or nonmedical or “non medical” or extramedical or “extra medical” or illicit* or illegal* or recreation*):ti,ab,kw
#3 | (opioid* or opiate* or oxycodone or hydrocodone or ritalin or adderall or amphetamine* or methylphenidate or “laughing gas” or “nitrous oxide” or ketamine or dextromethorphan or GHB or gamma-hydroxybutyrate or inhalant* or stimulant* or sedative* or barbiturate* or benzodiazepine* or (sleep next medication*)):ti,ab,kw near/5 (use* or using or abuse* or abusing or misus* or overus* or overutili* or nonprescri* or (non next prescri*) or nonmedical or “non medical” or extramedical or “extra medical” or illicit* or illegal* or recreation*):ti,ab,kw
#4 | (“pain relief” or (pain next reliever*) or (pain next medication*) or medicine* or “over the counter” or OTC):ti,ab,kw near/5 (abuse* or abusing or misus* or overus* or overutili* or nonprescri* or (non next prescri*) or nonmedical or “non medical” or extramedical or “extra medical” or illicit* or illegal* or recreation*):ti,ab,kw
#5 | prescription*:ti,ab,kw near/5 (abuse* or abusing or misus* or overus* or overutili* or nonmedical or “non medical” or extramedical or “extra medical” or illicit* or illegal* or recreation*):ti,ab,kw
#6 | (street* or designer* or club):ti,ab,kw next drug*:ti,ab,kw
#7 | (legal next high*):ti,ab,kw
#8 | nmupd:ti,ab,kw
#9 | marijuana:ti,ab,kw
#10 | (Cannabi* or hash or hashish):ti,ab,kw
#11 | (cocaine or methamphetamine* or khat or “Catha edulis”):ti,ab,kw
#12 | (heroin or opium or kratom or “mitragyna speciosa” or “manufactured fentanyl”):ti,ab,kw
#13 | (mdma or ecstasy or flunitrazepam or rohypnol or “bath salts” or “synthetic cathinone”):ti,ab,kw
#14 | (salvia or phencyclidine):ti,ab,kw
#15 | (hallucinogen* or dimethyltryptamine or lsd or mescaline or psilocybin):ti,ab,kw
#16 | {or #1-#15}
#17 | counsel*:ti,ab,kw or advice:ti,ab,kw or advise*:ti,ab,kw
#18 | (behavio* next chang*):ti,ab,kw
#19 | (behavio* next intervention*):ti,ab,kw
#20 | (behavio* next modification*):ti,ab,kw
#21 | motivational next interview*:ti,ab,kw
#22 | (cognitive next behavio*):ti,ab,kw or (behavio* next therap*):ti,ab,kw or CBT:ti,ab,kw
#23 | (brief next intervention*):ti,ab,kw or “computer based”:ti,ab,kw or “self help”:ti,ab,kw
#24 | SBIRT:ti,ab,kw
#25 | email*:ti,ab,kw or internet:ti,ab,kw or (text next messag*):ti,ab,kw or web:ti,ab,kw or website:ti,ab,kw
#26 | (reduc* or decreas* or prevent* or delay or avoid):ti,ab,kw near/3 initiation*:ti,ab,kw
#27 | “patient education”:ti,ab,kw or “health education”:ti,ab,kw or “health promotion”:ti,ab,kw
#28 | intervention*:ti or prevention:ti or preventive:ti or psychosocial:ti
#29 | {or #17-#28}
#30 | #16 and #29
#31 | ((reduc* or decreas* or prevent* or delay or avoid):ti,ab,kw near/3 (drug* or substance* or marijuana* or cannabi* or opioid* or opiate* or heroin or oxycodone or hydrocodone or crack or cocaine or “pain relief” or pain reliever* or pain medication* or prescription* or medicine* or over the counter or OTC):ti,ab,kw) near/5 (abuse* or abusing or misuse* or misusing or overus* or overuitili* or use* or using or experiment*):ti,ab,kw
#32 | #30 or #31
#33 | (child* or teen or teens or teenage* or adolescen* or youth or youths or “young people” or pediatric* or paediatric* or school age* or juvenile*):ti,ab,kw
#34 | #32 and #33 Publication Year from 2013 to 2018 899
#35 | (young or emerging or early):ti,ab,kw next adult*:ti,ab,kw
#36 | late:ti,ab,kw next (teen* or adolescen*):ti,ab,kw
#37 | (college* or universit*):ti,ab,kw
#38 | (undergraduate or graduate):ti,ab,kw next student*:ti,ab,kw
#39 | “high school”:ti,ab,kw near/2 senior*:ti,ab,kw
#40 | (12th next grade):ti,ab,kw
#41 | {or #35-#40}
#42 | #32 and #41 Publication Year from 1992 to 2018 1219
#43 | #34 or #42 in Trials

### MEDLINE

Ovid MEDLINE(R) <1946 to January Week 4 2019>, Ovid MEDLINE(R) Daily Update <January 30, 2019>, Ovid MEDLINE(R) Epub Ahead of Print <January 30, 2019>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <1946 to January 28, 2019>

------------------------------------------------------------

1 | substance-related disorders/
2 | Drug misuse/
3 | Prescription drug misuse/
4 | Prescription drug overuse/
5 | amphetamine-related disorders/
6 | cocaine-related disorders/
7 | inhalant abuse/ (183)
8 | marijuana abuse/ (5652)
9 | opioid-related disorders/
10 | phencyclidine abuse/
11 | substance abuse, intravenous/
12 | substance abuse, oral/
13 | street drugs/
14 | hallucinogens/
15 | ((drug or drugs or substance$) adj1 (“use” or using)).ti,ab,kf.
16 | ((drug or drugs or substance$) adj5 (abuse$ or abusing or misus$ or overus$ or overutili$ or nonprescri$ or non prescri$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,kf.
17 | ((opioid$ or opiate$ or oxycodone or hydrocodone or ritalin or adderall or amphetamine$ or methylphenidate or laughing gas or nitrous oxide or ketamine or dextromethorphan or GHB or gamma-hydroxybutyrate or inhalant$ or stimulant$ or sedative$ or barbiturate$ or benzodiazepine$ or sleep medication$) adj5 (use$ or using or abuse$ or abusing or misus$ or overus$ or overutili$ or nonprescri$ or non prescri$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,kf.
18 | ((pain relief or pain reliever$ or pain medication$ or medicine$ or over the counter or OTC) adj5 (abuse$ or abusing or misus$ or overus$ or overutili$ or non prescript$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,kf.
19 | (prescription$ adj5 (abuse$ or abusing or misus$ or overus$ or overutili$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,kf.
20 | ((street$ or designer$ or club) adj drug$).ti,ab,kf.
21 | legal high$.ti,ab,kf
22 | nmupd.ti,ab,kf.
23 | marijuana.ti,ab,kf.
24 | (Cannabi$ or hash or hashish).ti,ab,kf.
25 | (cocaine or methamphetamine$ or methamphetamine$ or khat).ti,ab,kf.
26 | (Heroin or opium or kratom or mitragyna speciosa or manufactured fentanyl).ti,ab,kf.
27 | (mdma or ecstasy or flunitrazepam or rohypnol or bath salts or synthetic cathinone).ti,ab,kf.
28 | (salvia or phencyclidine).ti,ab,kf.
29 | (hallucinogen$ or dimethyltryptamine or lsd or mescaline or psilocybin).ti,ab,kf.
30 | or/1-29
31 | Behavior Therapy/
32 | Cognitive Therapy/
33 | Counseling/
34 | Directive Counseling/
35 | Distance Counseling/
36 | Patient Education as Topic/
37 | Risk Reduction Behavior/
38 | Feedback, psychological/
39 | Health education/
40 | Health promotion/
41 | Motivation/
42 | Internet/
43 | Motivational interviewing/
44 | Persuasive communication/
45 | Preventive health services/
46 | Primary prevention/
47 | Self-help groups/
48 | Text messaging/
49 | Therapy, computer-assisted/
50 | counsel$.ti,ab,kf.
51 | advice.ti,ab,kf.
52 | advise$.ti,ab,kf.
53 | behavio?r$ chang$.ti,ab,kf.
54 | behavio?r$ intervention$.ti,ab,kf.
55 | behavio?r$ modification$.ti,ab,kf.
56 | motivational interview$.ti,ab,kf.
57 | (cognitive behavio$ or behavio$ therap$ or cbt).ti,ab,kf.
58 | brief intervention$.ti,ab,kf.
59 | computer based.ti,ab,kf.
60 | self help.ti,ab,kf.
61 | email$.ti,ab,kf.
62 | internet.ti,ab,kf.
63 | text messag$.ti,ab,kf.
64 | (web or website).ti,ab,kf.
65 | ((reduc$ or decreas$ or prevent$ or delay or avoid) adj3 initiation$).ti,ab,kf.
66 | (intervention$ or prevent$ or psychosocial).ti.
67 | or/31-66
68 | 30 and 67
69 | substance-related disorders/pc
70 | amphetamine-related disorders/pc
71 | cocaine-related disorders/pc
72 | inhalant abuse/pc
73 | marijuana abuse/pc
74 | opioid-related disorders/pc
75 | phencyclidine abuse/pc
76 | substance abuse, intravenous/pc
77 | substance abuse, oral/pc
78 | ((reduc* or decreas* or prevent* or delay or avoid) adj3 (drug$ or substance$ or marijuana* or cannabi* or opioid* or opiate* or heroin or oxycodone or hydrocodone or crack or cocaine or pain relief or pain reliever$ or pain medication$ or prescription$ or medicine$ or over the counter or OTC) adj5 (abuse$ or abusing or misuse$ or misusing or overus$ or overuitili$ or use$ or using or experiment$)).ti,ab,kf.
79 | or/68-78
80 | adolescent/ or child/
81 | (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$ or school age$ or juvenile$).ti,ab,kf.
82 | 79 and (80 or 81)
83 | (clinical trial or controlled clinical trial or randomized controlled trial or adaptive clinical trial or equivalence clinical trial or pragmatic clinical trial or meta analysis).pt.
84 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or adaptive clinical trials as topic/ or equivalence clinical trials as topic/ or pragmatic clinical trials as topic/
85 | Meta-Analysis as Topic/
86 | Random allocation/
87 | clinical trial$.ti,ab,kf.
88 | (control$ adj3 (study or studies or trial$)).ti,ab,kf.
89 | random$.ti,ab,kf.
90 | (metaanaly$ or meta analy$).ti,ab,kf.
91 | trial.ti.
92 | or/83-91
93 | 82 and 92 (3022)
94 | limit 93 to (english language and yr=“2013 -Current”)
95 | remove duplicates from 94
96 | Young adult/
97 | Universities/
98 | Student Health Services/
99 | ((young or emerging or early) adj adult$).ti,ab,kf.
100 | (late adj (teen$ or adolescen$)).ti,ab,kf.
101 | (college$ or universit$).ti,ab,kf.
102 | ((undergraduate or graduate) adj student$).ti,ab,kf.
103 | (high school adj2 senior$).ti,ab,kf.
104 | 12th grade.ti,ab,kf.
105 | or/96-104
106 | 79 and 92 and 105
107 | limit 106 to (english language and yr=“1992 -Current”)
108 | remove duplicates from 107
109 | 95 or 108
110 | Animals/ not (Humans/ and Animals/)
111 | 109 not 110

### PsycINFO

Database: PsycINFO <1806 to January Week 3 2019>

------------------------------------------------------------

1 | Drug Abuse/
2 | “substance use disorder”/
3 | Drug Usage/
4 | Inhalant Abuse/
5 | Glue Sniffing/
6 | Polydrug Abuse/
7 | Drug Abstinence/
8 | Intravenous Drug Usage/
9 | Marijuana Usage/
10 | Cocaine/
11 | Opiates/
12 | Hallucinogenic Drugs/
13 | Phencyclidine/
14 | Methamphetamine/
15 | Methylenedioxymethamphetamine/
16 | Lysergic Acid Diethylamide/
17 | ((drug or drugs or substance$) adj1 (“use” or using)).ti,ab,id.
18 | ((drug or drugs or substance$) adj5 (abuse$ or abusing or misus$ or overus$ or overutili$ or nonprescri$ or non prescri$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,id.
19 | ((opioid$ or opiate$ or oxycodone or hydrocodone or ritalin or adderall or amphetamine$ or methylphenidate or laughing gas or nitrous oxide or ketamine or dextromethorphan or GHB or gamma-hydroxybutyrate or inhalant$ or stimulant$ or sedative$ or barbiturate$ or benzodiazepine$ or sleep medication$) adj5 (use$ or using or abuse$ or abusing or misus$ or overus$ or overutili$ or nonprescri$ or non prescri$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,id.
20 | ((pain relief or pain reliever$ or pain medication$ or medicine$ or over the counter or OTC) adj5 (abuse$ or abusing or misus$ or overus$ or overutili$ or non prescript$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,id.
21 | (prescription$ adj5 (abuse$ or abusing or misus$ or overus$ or overutili$ or nonmedical or non medical or extramedical or extra medical or illicit$ or illegal$ or recreation$)).ti,ab,id.
22 | ((street$ or designer$ or club) adj drug$).ti,ab,id.
23 | legal high$.ti,ab,id.
24 | nmupd.ti,ab,id.
25 | marijuana.ti,ab,id.
26 | (Cannabi$ or hash or hashish).ti,ab,id.
27 | (cocaine or methamphetamine$ or methamphetamine$ or khat).ti,ab,id.
28 | (Heroin or opium or kratom or mitragyna speciosa or manufactured fentanyl).ti,ab,id.
29 | (mdma or ecstasy or flunitrazepam or rohypnol or bath salts or synthetic cathinone).ti,ab,id.
30 | (salvia or phencyclidine).ti,ab,id.
31 | (hallucinogen$ or dimethyltryptamine or lsd or mescaline or psilocybin).ti,ab,id.
32 | or/1-31
33 | Health Promotion/
34 | Motivation/
35 | behavio?r$ chang$.ti,ab,id.
36 | behavio?r$ intervention$.ti,ab,id.
37 | behavio?r$ modification$.ti,ab,id.
38 | behavior therapy/
39 | cognitive behavior therapy/
40 | cognitive therapy/
41 | Cognitive Techniques/
42 | (cognitive behavio$ or behavio$ therapy or cbt).ti,ab,id.
43 | brief intervention$.ti,ab,id.
44 | SBIRT.ti,ab,id.
45 | Behavior Modification/
46 | Behavior Change/
47 | Persuasive Communication/
48 | Motivational Interviewing/
49 | motivational interview$.ti,ab,id.
50 | Health Knowledge/
51 | Health Behavior/
52 | Health Education/
53 | Client Education/
54 | Feedback/
55 | Online Therapy/
56 | Computer Assisted Therapy/
57 | Computer Mediated Communication/
58 | Internet/
59 | computer based.ti,ab,id.
60 | text messag$.ti,ab,id.
61 | email$.ti,ab,id.
62 | internet.ti,ab,id.
63 | (web or website).ti,ab,id.
64 | Self Help Techniques/
65 | self help.ti,ab,id.
66 | counseling/
67 | Group Counseling/
68 | counsel$.ti,ab,id.
69 | counselling.ti,ab,id.
70 | advice.ti,ab,id.
71 | advise$.ti,ab,id.
72 | (intervention$ or prevention or preventive or psychosocial).ti.
73 | ((reduc$ or decreas$ or prevent$ or delay or avoid) adj3 initiation$).ti,ab,id.
74 | or/33-73
75 | 32 and 74
76 | Drug Abuse Prevention/
77 | ((reduc* or decreas* or prevent* or delay or avoid) adj3 (drug$ or substance$ or marijuana* or cannabi* or opioid* or opiate* or heroin or oxycodone or hydrocodone or crack or cocaine or pain relief or pain reliever$ or pain medication$ or prescription$ or medicine$ or over the counter or OTC) adj5 (abuse$ or abusing or misuse$ or misusing or overus$ or overuitili$ or use$ or using or experiment$)).ti,ab,id.
78 | 75 or 76 or 77
79 | (adolescence 13 17 yrs or childhood birth 12 yrs).ag.
80 | (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$ or school age$ or juvenile$).ti,ab,id.
81 | 79 or 80
82 | 78 and 81
83 | (treatment outcome or clinical trial).md.
84 | Experiment Controls/
85 | (control$ adj3 (study or studies or trial$)).ti,ab,id.
86 | clinical trial$.ti,ab,id.
87 | random$.ti,ab,id.
88 | meta analy$.ti,ab,id.
89 | metaanaly$.ti,ab,id.
90 | trial.ti.
91 | or/83-90
92 | 82 and 91
93 | limit 92 to (english language and yr=“2013 -Current”)
94 | young adulthood 18 29 yrs.ag.
95 | emerging adulthood/
96 | colleges/ or community colleges/ or college students/
97 | ((young or emerging or early) adj adult$).ti,ab,id.
98 | (late adj (teen$ or adolescen$)).ti,ab,id.
99 | (college$ or universit$).ti,ab,id.
100 | ((undergraduate or graduate) adj student$).ti,ab,id.
101 | (high school adj2 senior$).ti,ab,id.
102 | 12th grade.ti,ab,id.
103 | or/94-102
104 | 78 and 103
105 | 78 and 91 and 103
106 | limit 105 to (english language and yr=“1992 -Current”)
107 | 93 or 106

### PubMed, publisher-supplied records

#26 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | (#22 OR #25) AND publisher[sb]
#25 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #24 AND (“1992/01/01”[Date - Publication] : “3000”[Date - Publication]) AND English[Language]
#24 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #9 AND #18 AND #20 AND #23
#23 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | young adult*[tiab] OR emerging adult*[tiab] OR early adult*[tiab] OR late teen*[tiab] OR late adolescen*[tiab] OR college*[tiab] OR university*[tiab] OR undergraduate student*[tiab] OR graduate student*[tiab] OR high school senior*[tiab] OR 12th grade[tiab]
#22 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #21 AND (“2013/01/01”[Date - Publication] : “3000”[Date - Publication]) AND English[Language]
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #9 AND #18 AND #19 AND #20
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | random*[tiab] OR clinical trial*[tiab] OR controlled trial*[tiab] OR “controlled study”[tiab] OR “controlled studies”[tiab] OR trial*[title] or meta analy*[tiab] OR metaanaly*[tiab]
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | child*[tiab] OR teen[tiab] OR teens[tiab] OR teenage*[tiab] OR adolescen*[tiab] OR youth[tiab] OR youths[tiab] OR “young people”[tiab] OR pediatric*[tiab] OR paediatric*[tiab] OR school age*[tiab] OR juvenile*[tiab]
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | intervention*[ti] OR prevention[ti] OR preventive[ti] OR psychosocial[ti]
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | “patient education”[tiab] OR “health education”[tiab] OR “health promotion”[tiab]
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | email*[tiab] OR internet[tiab] OR text messag*[tiab] OR web[tiab] OR website[tiab]
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | brief intervention*[tiab] OR SBIRT[tiab]
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | cognitive behavio*[tiab] OR behavio* therap*[tiab] OR cbt[tiab]
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | motivational interview*[tiab]
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | behavio* chang*[tiab] OR behavio* intervention*[tiab] OR behavio* modification*[tiab]
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | counsel*[tiab] OR advice[tiab] OR advise*[tiab]
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #3 OR #4 OR #5 OR #6 OR #7 OR #8
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | marijuana[tiab] OR Cannabi*[tiab] OR hash[tiab] OR hashish[tiab] OR cocaine[tiab] OR methamphetamine[tiab] OR khat[tiab] OR “Catha edulis”[tiab] OR Heroin[tiab] OR opium[tiab] OR kratom[tiab] OR “mitragyna speciosa”[tiab] OR “manufactured fentanyl” [tiab] OR mdma[tiab] OR ecstasy[tiab] OR flunitrazepam[tiab] OR rohypnol[tiab] OR “bath salts”[tiab] OR “synthetic cathinone”[tiab] OR salvia[tiab] OR phencyclidine[tiab] OR hallucinogen*[tiab] OR dimethyltryptamine[tiab] OR lsd[tiab] OR mescaline[tiab] OR psilocybin[tiab]
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | nmupd[tiab]
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | legal high*[tiab]
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | street drug*[tiab] OR designer drug*[tiab] OR club drug*[tiab]
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | drug use*[tiab] OR substance use*[tiab] OR using drug*[tiab]
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #1 AND #2
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | abuse*[tiab] OR abusing[tiab] OR misus*[tiab] OR overus*[tiab] OR overutili*[tiab] OR nonprescri*[tiab] OR non prescri*[tiab] OR nonmedical[tiab] OR “non medical”[tiab] OR extramedical[tiab] OR “extra medical”[tiab] OR illicit*[tiab] OR illegal*[tiab] OR recreation*[tiab]
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | drug[tiab] OR drugs[tiab] OR substance*[tiab] OR opioid*[tiab] OR opiate*[tiab] OR oxycodone[tiab] OR hydrocodone[tiab] OR ritalin[tiab] OR adderall[tiab] OR Adderall[tiab] OR amphetamine*[tiab] OR methylphenidate[tiab] OR “laughing gas”[tiab] OR “nitrous oxide” [tiab] OR ketamine[tiab] OR dextromethorphan[tiab] OR GHB[tiab] or “gamma-hydroxybutyrate”[tiab] OR inhalant*[tiab] OR stimulant*[tiab] OR sedative*[tiab] OR barbiturate*[tiab] OR benzodiazepine*[tiab] OR sleep medication*[tiab] OR “pain relief”[tiab] OR pain reliever*[tiab] OR pain medication*[tiab] OR medicine*[tiab] OR “over the counter”[tiab] OR OTC[tiab] prescription*[tiab]

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Aim | Preventing illicit and nonmedical drug use is a primary study aim, with or without addressing other substances or behaviors (e.g., addressing drug use and alcohol and tobacco use, addressing drug use and risky sexual behaviors) | Change in drug use is not a stated aim but is a reported outcome
Condition | Any use of psychoactive illicit drugs and nonmedical use of psychoactive prescription or over-the-counter medications, e.g.:; - Cannabinoids (marijuana, hashish, synthetic cannabinoids); - Club drugs (3,4-methylenedioxymethamphetamine [MDMA or ecstasy], flunitrazepam [Rohypnol], gamma-hydroxybutyrate [GHB], synthetic cathinone [bath salts]); - Dissociative drugs (ketamine, phencyclidine [PCP] and analogs, Salvia divinorum [salvia], dextromethorphan [DXM]); - Hallucinogens (lysergic acid diethylamide [LSD or acid], N,N-dimethyltryptamine [DMT], mescaline, psilocybin); - Inhalants (also known as volatile substances); - Illicit opioids (heroin, opium, Mitragyna speciosa [kratom], illicitly manufactured fentanyl [IMF]); - Stimulants (cocaine, amphetamine, Catha edulis [khat], methamphetamine); - Prescription opioid pain relievers; - Prescription sedatives (barbiturates, benzodiazepines, sleep medications); - Prescription stimulants; - Over-the-counter drugs (e.g., DXM); - Combination of any of the above | - Medical use of drugs as prescribed; - Nonpsychoactive drugs (e.g., anabolic steroids, laxatives, aspirin)
Population | - Children, adolescents, and young adults (age ≤25 years), including pregnant females who do not regularly use illicit drugs or medications for nonmedical psychoactive effects.; - A priori subpopulations of interest will be examined based on: age (early childhood, preadolescent, adolescent, young adult), sex, race/ethnicity, risk level, rural vs. urban residence, and substance used | - Young persons who regularly use illicit drugs or prescription drugs nonmedically, including those with harmful or hazardous use, or with drug abuse or dependence (DSM-IV-TR) or a drug use disorder (DSM-5)^1^; - Children and adolescents seeking treatment for drug-related issues^1^; - Children and adolescents who are referred to treatment for drug-related issues by the juvenile justice system, a social or health agency, or their parents, or otherwise directly referred for substance abuse treatment in a specialty setting^1^; - Trials limited to young persons with health issues (e.g., schizophrenia, HIV) that would limit generalizability to general primary care patients
Interventions | - Counseling interventions designed to prevent and/or reduce illicit and nonmedical prescription drug use, with or without referral, including interventions targeting parents or caregivers to prevent and/or reduce drug use in young persons; - Counseling interventions can vary in their approach (e.g., 12-step programs, cognitive behavioral therapy, motivational enhancement therapy), specific strategies (e.g., action plans, diaries), delivery method (e.g., in person, electronic, individual, group-based), length of contact (e.g., brief, extended), and number of contacts (e.g., single, multiple) | - Detoxification, medically managed withdrawal, or medication-assisted treatment (e.g., methadone maintenance programs, buprenorphine, naltrexone); - Maintaining abstinence after substance use treatment for dependence or drug use disorder (i.e., secondary abstinence); - Broad public health, media, or policy interventions; - Inpatient/residential treatment; - Contingency management/vouchers; - Vocational rehabilitation/customized employment supports; - Outward Bound/life skills training
Comparators | - No intervention; - Usual care; - Waitlist; - Attention control (e.g., intervention is similar in format and intensity but on a different content area); - Minimal intervention (no more than one brief contact [i.e., <5 minutes] per year or brief written materials, such as pamphlets) | Active intervention (i.e., more than one brief contact per year or brief written materials)
Outcomes | KQ 1 : Health, social, educational, and other outcomes; Health outcomes; - All-cause mortality; - Drug-related mortality (intentional and unintentional); - Drug-related morbidity (including but not limited to: mental health disorders; STI/HIV transmission; hepatitis B or C virus transmission; unintended pregnancy/pregnancy complications; deep bacterial abscesses; endocarditis; respiratory infections; cardiovascular complications; stroke; seizures); - Drug-related injury or accidents; - Nonfatal overdose; - Quality of life; - Pain; - Other drug-related consequences; Social, educational, or other outcomes:; - Health care utilization; - Global functioning; - Educational attainment/school performance; - Social/legal outcomes (e.g., incarceration, out-of-home juvenile placement, criminal activity, violence, driving under the influence); - Family functioning; - Other related social or educational outcomes; KQ 2: Behavioral outcomes; - Drug use (required) (self-reported and/or biologic measures):; ○ Abstinence (use/no use); ○ Frequency and/or quantity of use; ○ Severity of substance use disorder (reported as an index measured by a standardized questionnaire, such as the Short Inventory of Problems, Addiction Severity Index, or Severity of Dependence Scale); ○ Meeting criteria for substance use disorder; - Composite substance use outcome; - Other risky behaviors (e.g., alcohol, tobacco, or other drug use; risky sexual behaviors); KQ 3: Harms; - Serious treatment-related harms at any time point after the intervention began (e.g., death (including suicide), seizure, cardiovascular event, or other medical issue requiring urgent medical treatment); - Demoralization due to failed quit attempt; - Harms associated with parents finding out about their children’s drug use; - Discontinuation of effective treatment due to fears of addiction (e.g., ADHD medication) | - Attitudes, knowledge, or beliefs related to drug use; - Intention to change behavior; - Intervention participation/compliance
Outcome assessment timing | At least 3 months after baseline measurement (except for studies in pregnant women, for which shorter length of follow-up will be included) | Less than 3 months after baseline measurement
Setting | - Primary care settings; - Other primary care–relevant settings, including other health care clinics, emergency departments, research clinics/offices, school health clinics, community centers, homes, and virtual settings (e.g., online support groups) | - Substance abuse treatment centers; - School classrooms; - Worksites; - Inpatient/residential settings; - Other institutions (e.g., juvenile detention facility)
Study design | - Randomized, controlled trials; - Cluster randomized, controlled trials; - Nonrandomized, controlled trials | - Prospective or retrospective cohort studies; - Case-control studies; - Time-series studies; - Before-after studies; - Cross-sectional studies; - Editorials, commentaries, case studies, case series
Study geography | Studies conducted in countries categorized as “Very High” on the United Nations Human Development Index (based on 2015 indicators) | Studies conducted in countries not categorized as “Very High” on the 2015 Human Development Index
Publication language | English | Languages other than English
Quality rating | Fair- or good-quality studies | Poor-quality studies (according to design-specific USPSTF criteria)

Abbreviations: KQ = Key Question; USPSTF = U.S. Preventative Services Task Force.

Appendix A Table 2 Study Design-Specific Quality Rating Criteria

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^74^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Appendix A Figure 1 Literature Flow Diagram

*Studies may appear in more than one Key Question.

This figure is a flow chart that summarizes the search and selection of articles in this review. There were 8264 citations identified through literature databases. An additional 59 citations were identified from outside sources, and 27 citations were identified from the USPSTF Adolescent Drug Abuse Review from 2013. After duplicates were removed, 4453 unique citations were screened at the title/abstract stage. The full-text of 352 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=22), Key question 2 (k=29), and Key Question 3 (k=1). Reasons for excluding the other articles are available in Appendix C.