# References

1 Klein R, Klein BEK. Vision Disorders in Diabetes. In: National Diabetes Data Group, Ed. Diabetes in America, 2nd Edition. National Diabetes Data Group. Bethesda, Md.: National Institutes of Health. National Institute of Diabetes and Digestive and Kidney Diseases; 338.
2 Klein R, Klein BEK, Moss SE. Visual impairment in diabetes. Ophthalmology. 1984;91:1-9. [pmid: 6709312].
3 Saaddine JB, Narayan KMV, Engelgau NM, Aubert RE, Klein R, Beckles GLA. Prevalence of self-rated visual impairment among adults with diabetes. Am J Pub Health. 1999;89:1200-1205. [pmid: 10432906].
4 United States Renal Data System. Executive Summary of United States Renal Data System, 1994-1999. 1999. Available at www.usrds.org. Accessed December 13, 1999. [pmcid: 325679].
5 Perneger TV, Brancati FL, Whelton PK, Klag MJ. End-stage renal disease attributable to Diabetes Mellitus. Ann Intern Med. 1994;121:912-918. [pmid: 7978716].
6 Reiber GE, Boyko EJ, Smith DG. Lower extremity foot ulcers and amputations in diabetes. National Diabetes Data Group. Diabetes in America. 2nd ed. Bethesda, Md.: National Institutes of Health. National Institute of Diabetes and Digestive and Kidney Diseases. 1995:409-428. [pmcid: 157603].
7 Humphrey LL, Palumbo PJ, Butters MA, et al. The contribution of non-insulin-dependent diabetes to lower-extremity amputation in the community. Arch Int Med. 1994;154:885-892. [pmid: 8154951].
8 Stamler J, Vaccaro O, Neaton JD, Wentworth D. Diabetes, other risk factors, and 12 year cardiovascular mortality for men screened in the Multiple Risk Factor Intervention Trial. Diabetes Care. 1993;16:434-444. [pmid: 8432214].
9 Manson JE, Colditz GA, Stampfer MJ, et al. A prospective study of maturity-onset diabetes mellitus and risk of coronary heart disease and stroke in women. Arch Int Med. 1991;151:1141-1147. [pmid: 2043016].
10 Pan WH, Cedres LB, Liu K, et al. Relationship of clinical diabetes and asymptomatic hyperglycemia to risk of coronary heart disease mortality in men and women. J Epidemiol. 1986;123:504-516.
11 Seeman T, de Leon CM, Berkman L, Ostfeld A. Risk factors for coronary heart disease among older men and women: a prospective study of community-dwelling elderly. Am J Epidemiol. 1993;138:1037-1049. [pmid: 8266906].
12 Kuusisto J, Mykkanen L, Pyorala K, Laasko M. NIDDM and its metabolic control predict coronary heart disease in elderly subjects. Diabetes. 1994;43:960-967. [pmid: 8039603].
13 Folsom AR, Szklo M, Stevens J, Liao F, Smith R, Eckfeldt JH. A prospective study of coronary heart disease in relation to fasting insulin, glucose and diabetes. Diabetes Care. 1997.
14 Berglund G, Eriksson KF, Isrealsson B, et al. Cardiovascular risk groups and mortality in an urban Swedish male population: the Malmo Preventive Project. J Intern Med. 1996;239:489-497. [pmid: 8656142].
15 Haffner SM, Lehto S, Ronnemaa T, Pyorala K, Laakso M. Mortality from coronary heart disease in subjects with type 2 diabetes and in nondiabetic subjects with and without prior myocardial infarction. N Engl J Med. 1998;339:229-234. [pmid: 9673301].
16 Laws A, Marcus EB, Grove JS, Curb JD. Lipids and lipoproteins as risk factors for coronary heart disease in men with abnormal glucose tolerance: the Honolulu Heart Program. J Int Med. 1993;234:471-478.
17 Kannel WB, McGee DL. Diabetes and cardiovascular risk factors: the Framingham Study. Circulation. 1979;59:8-13. [pmid: 758126].
18 Barrett-Connor EL, Cohn BA, Wingard DL, Edelstein SL. Why is diabetes mellitus a stronger risk factor for fatal ischemic heart disease in women than in men? The Rancho Bernardo Study [published erratum appears in JAMA 1991 Jun 26;265(24):3249]. JAMA. 1991;265:627-631. [pmid: 1987413].
19 Kleinman JC, Donahue RP, Harris MI, Finucane FF, Madans JH, Brock DB. Mortality among diabetics in a national sample. Am J Epidemiol. 1988;128:389-401. [pmid: 3394705].
20 Jarrett RJ, McCartney P, Keen H. The Bedford Survey: ten year mortality rates in newly diagnosed diabetics, borderline diabetics and normoglycemic controls and risk indices for coronary heart disease in borderline diabetics. Diabetologia. 1982;22:79-84. [pmid: 7060853].
21 Fuller JH, Shipley MJ, Rose G, Jarrett RJ, Keen H Coronary-heart disease risk and impaired glucose tolerance: the Whitehall Study Lancet. 1980 1(8183):1373 1376 6104171
22 Songer TJ. Disability in Diabetes. National Diabetes Data Group. Bethesda, Md.: National Institutes of Health. National Institute of Diabetes and Digestive and Kidney Diseases. 1995. [pmcid: 441483].
23 American Diabetes Association. Economic consequences of diabetes mellitus in the U.S. in 1997. Diabetes Care. 1998;21:296-309. [pmid: 9539999].
24 Centers for Disease Control. Trends in the prevalence and incidence of self-reported diabetes mellitus - United States, 1980-1994. MMWR Morb Mortal Wkly Rep. 1997;46:1013-1018. [pmid: 9367134].
25 Harris MI, Flegal KM, Cowie CC, et al. Prevalence of diabetes, impaired fasting glucose, and impaired glucose tolerance in U.S. adults: the third National Health and Nutrition Examination Survey, 1988-1994. Diabetes Care. 1998;21:518-524. [pmid: 9571335].
26 Burke JP, Williams K, Gaskill SP, Hazuda HP, Haffner SM, Stern MP. Rapid rise in the incidence of type 2 diabetes from 1987 to 1996. Arch Intern Med. 1999;159:1450-1456. [pmid: 10399896].
27 Mokdad AH, Serdula MK, Dietz WH, Bowman BA, Marks JS, Koplan JP. The spread of the obesity epidemic in the United States, 1991-1998. JAMA. 1999;282:1519-1522. [pmid: 10546690].
28 Leibson CL, O'Brien PC, Atkinson E, Palumbo PJ, Melton LJ. Relative contributions of incidence and survival to increasing prevalence of adult-onset diabetes mellitus: a population-based study. Am J Epidemiol. 1997;146:12-22. [pmid: 9215219].
29 Harris MI, Eastman RC, Cowie CC, Flegal KM, Eberhardt MS. Comparison of diabetes diagnostic categories in the U.S. population according to 1997 American Diabetes Association and 1980-1985 World Health Diagnostic Criteria. Diabetes Care. 1997;20:1859-1862. [pmid: 9405907].
30 UK Prospective Diabetes Study Group. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes: UKPDS 33. Lancet. 1998:837-853.
31 UK Prospective Diabetes Study Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. BMJ. 1998;317:703-713. [pmid: 9732337]. [pmcid: 28659].
32 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. Lancet. 1998;351:1755-1762. [pmid: 9635947].
33 Ohkubo Y, Kishikawa H, Araki E, et al. Intensive insulin therapy prevents the progression of diabetic microvascular complications in Japanese patients with non-insulin-dependent diabetes mellitus: a randomized prospective 6-year study. Diabetes Res Clin Pract. 1995;28:103-117. [pmid: 7587918].
34 Heart Outcomes Prevention Evaluation Study. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. N Engl J Med. 2000;342:145-153. [pmid: 10639539].
35 US. Preventive Services Task Force;. Guide to Clinical Preventive Services. 2nd ed. Alexandria, Va.: International Medical Publishing; 1996. 193.
36 American Diabetes Association. Screening for Diabetes. Diabetes Care. 2002;25:S21-S24.
37 Harris R, Donahue K, Rathore S, Frame P, Woolf S, Lohr KN. Screening Adults for Type 2 Diabetes:A Review of the Evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;138:215-229. [pmid: 12558362].
38 Harris MI, et al. Onset of NIDDM Occurs at least 4-7 yr. before clinical diagnosis. Diabetes Care. 1992;15:815-819. [pmid: 1516497].
39 Jarrett RJ. Duration of non-insulin-dependent diabetes and development of retinopathy: Analysis of possible risk factors. Diabet Med. 1986;3:261-263. [pmid: 2951182].
40 McCance DR, Hanson RL, Charles MA, et al. Comparison of tests for glycated haemoglobin and fasting and two hour plasma glucose concentrations as diagnostic methods for diabetes. BMJ. 1994;308:1323-1328. [pmid: 8019217].
41 Engelgau MM, Thompson TJ, Herman WH, et al. Comparison of fasting and 2-hour glucose and HbA1c levels for diagnosing diabetes: diagnostic criteria and performance revisited. Diabetes Care. 1997;20:785-791. [pmid: 9135943].
42 Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 1997;20:1183-1197. [pmid: 9203460].
43 Coutinho M, Gerstein HC, Wang Y, Yusuf S. The relationship between glucose and incident cardiovascular events: a metaregression analysis of published data from 20 sudies of 95,783 individuals followed for 12.4 years. Diabetes Care. 1999;22:233-240. [pmid: 10333939].
44 Bjornholt JV, Erikssen G, Aaser E, et al. Fasting blood glucose: an underestimated risk factor for cardiovascular death: results from a 22-year follow-up of healthy nondiabetic men. Diabetes Care. 1999;22:45-49. [pmid: 10333902].
45 Turner RC, Millns H, Neil HA, et al. Risk factors for coronary artery disease in non-insulin dependent diabetes mellitus: United Kingdom Prospective Diabetes Study (UKPDS: 23). BMJ. 1998;316:823-828. [pmid: 9549452]. [pmcid: 28484].
46 Saydah SH, Loria CM, Eberhardt MS, Brancati FL. Subclinical states of glucose intolerance and risk of death in the U.S. Diabetes Care. 2001;24:447-453. [pmid: 11289466].
47 Khaw KT, Wareham N, Luben R, et al. Glycated haemoglobin, diabetes, and mortality in men in Norfolk cohort of European prospective investigation of cancer and nutrition (EPIC- Norfolk). BMJ. 2001;322:15-18. [pmid: 11141143]. [pmcid: 26599].
48 Blunt BA, Barrett-Connor E, Wingard DL. Evaluation of fasting plasma glucose as screening test for NIDDM in older adults. Rancho Bernardo Study. Diabetes Care. 1991;14:989-993. [pmid: 1797513].
49 Davidson MB, Schriger DL, Peters AL, Lorber B. Relationship between fasting plasma glucose and glyosylated hemoglobin: potential for false positive diagnoses of type 2 diabetes using new diagnostic criteria. JAMA. 1999;281:1203-1210. [pmid: 10199430].
50 Olefsky JM, Reaven GM. Insulin and glucose responses to identical oral glucose tolerance tests performed forty-eight hours apart. Diabetes. 1974;23:449-453. [pmid: 4830180].
51 Little RR. Recent progress in glycohemoglobin (HbA1c) testing. Diabetes Care. 2000;23:265-266. [pmid: 10868848].
52 Kilpatrick ES, Maylor PW, Keevil BG. Biological variation of glycated hemoglobin: implications for diabetes screening and monitoring. Diabetes Care. 1998;21:261-264. [pmid: 9539993].
53 Engelgau MM, Thompson TJ, Smith PJ, et al. Screening for diabetes mellitus in adults. The utility of random capillary blood glucose measurements. Diabetes Care. 1995;18:463-466. [pmid: 7497854].
54 Rolka DB, Narayan KM, Thompson TJ, et al. Performance of recommended screening tests for undiagnosed diabetes and dysglycemia. Diabetes Care. 2001;24:1899-1903. [pmid: 11679454].
55 Cowie CC, Harris MI, Eberhardt MS. Frequency and determinants of screening for diabetes in the U.S. Diabetes Care. 1994;17:1158-1163. [pmid: 7821136].
56 Harwell TS, Smilie JG, McDowall JM, Helgerson SD, Gohdes D. Diabetes screening practices among individuals aged 45 years and older. Diabetes Care. 2000;23:125-126. [pmid: 10857982].
57 UK Prospective Diabetes Study Group. UK Prospective Diabetes Study 6: complications in newly diagnosed type 2 diabetic patients and their association with different clinical and biochemical risk factors. Diabetes Res. 1990;13:1-11. [pmid: 2097090].
58 Kohner EM, Aldington SJ, Stratton IM, et al. United Kingdom Prospective Diabetes Study, 30: diabetic retinopathy at diagnosis of non-insulin-dependent diabetes mellitus and associated risk factors. Arch Ophthalmol. 1998;116:297-303. [pmid: 9514482].
59 Harris MI, Klein R, Cowie CC, Rowland M, Byrd-Holt DD. Is the risk of diabetic retinopathy greater in non-Hispanic blacks and Mexican-Americans than in non-Hispanic whites with type 2 diabetes? A U. S. population study. Diabetes Care. 1998;21:1230-1235. [pmid: 9702425].
60 Haffner SM, Fong D, Stern MP, et al. Diabetic retinopathy in Mexican-Americans and non-Hispanic whites. Diabetes. 1988;37:878-884. [pmid: 3384186].
61 Klein R, Klein BE, Moss SE. Relation of glycemic control to diabetic microvascular complications in diabetes mellitus. Ann Int Med. 1996;124:90-96. [pmid: 8554220].
62 Klein R, Klein BE, Moss SE, Cruickshanks KJ. Relationship of hyperglycemia to the long-term incidence and progression of diabetic retinopathy. Arch Int Med. 1994;154:2169-2178. [pmid: 7944837].
63 Klein R, Klein BEK, Moss SE, Cruickshanks KJ. The Wisconsin Epidemiologic Study of Diabetic Retinopathy XIV: ten-year incidence and progression of diabetic retinopathy. Arch Ophthalmol. 1994;112:1217-1228. [pmid: 7619101].
64 UK Prospective Diabetes Study Group. UK Prospective Diabetes Study (UKPDS). XI: Biochemical risk factors in type 2 diabetic patients at diagnosis compared with age-matched normal subjects. Diabetic Medicine. 1994;11:534-544. [pmid: 7955969].
65 Moss SE, Klein R, Klein BE. Ten-year incidence of visual loss in a diabetic population. Ophthalmology. 1994;101:1061-1070. [pmid: 8008348].
66 Eastman RC, Javitt JC, Herman WH, et al. Model of complications of NIDDM. II. Analysis of the health benefits and cost-effectiveness of treating NIDDM with the goal of normoglycemia. Diabetes Care. 1997;20:735-744. [pmid: 9135935].
67 Eastman RC, Javitt JC, Herman WH, et al. Model of complications of NIDDM. I. Model construction and assumptions. Diabetes Care. 1997;20:725-734. [pmid: 9135934].
68 Ferris FL. How effective are treatments for diabetic retinopathy?. JAMA. 1993;269:1290-1291. [pmid: 8437309].
69 Early Treatment Diabetic Retinopathy Study Research Group. Photocoagulation for diabetic macular edema: Early Treatment Diabetic Retinopathy Study Report no. 4. Int Ophthalmol Clin. 1987;27:265-272. [pmid: 3692708].
70 Davis MD, Fisher MR, Gangnon RE, et al. Risk factors for high-risk proliferative diabetic retinopathy and severe visual loss: Early Treatment Diabetic Retinopathy Study Report :18. Invest Ophthalmol Vis Sci. 1998;39:233-252. [pmid: 9477980].
71 The Diabetes Control and Complications Trial Research Group. The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. N Engl J Med. 1993;329:977-986. [pmid: 8366922].
72 Harris EL, Sherman SH, Georgopoulos A. Black-white differences in risk of developing retinopathy among individuals with type 2 diabetes. Diabetes Care. 1999;22:779-783. [pmid: 10332681].
73 Lee ET, Lee VS, Lu M, Russell D. Development of proliferative retinopathy in NIDDM. A follow-up study of American Indians in Oklahoma. Diabetes. 1992;41:359-367. [pmid: 1551496].
74 Turner RC The U.K. Prospective Diabetes Study. A review Diabetes Care. 1998 21Suppl 3:C35 8 9850487
75 Standl E, Stiegler H. Microalbuminuria in a random cohort of recently diagnosed type 2 (non-insulin-dependent) diabetic patients living in the greater Munich area. Diabetologia. 1993;36:1017-1020. [pmid: 8243849].
76 Hamman RF, Franklin GA, Mayer EJ, et al Microvascular complications of NIDDM in Hispanics and non-Hispanic whites Diabetes Care. 1991 14(Suppl. 3):655 664 1914815
77 Ballard DJ, Humphrey LL, Melton LJ, et al. Epidemiology of persistent proteinuria in type II diabetes mellitus: population-based study in Rochester, Minnesota. Diabetes. 1988;37:405-412. [pmid: 3378684].
78 Humphrey LL, Ballard DJ, Frohnert PP, Chu CP, O'Fallon WM, Palumbo PJ. Chronic renal failure in non-insulin-dependent diabetes mellitus. A population-based study in Rochester, Minnesota. Ann Intern Med. 1989;111:788-796. [pmid: 2817626].
79 Kasiske BL, Kalil RS, Ma JZ, Liao M, Keane WF. Effect of antihypertensive therapy on the kidney in patients with diabetes: a meta-regression analysis. Ann Int Med. 1993;118:129-138. [pmid: 8416309].
80 Lovell HG. Are angiotensin converting enzyme inhibitors useful for normotensive diabetic patients with microalbuminuria?. Cochrane Library. 1997.
81 Gansevoort RT, Sluiter WJ, Hemmelder MH, de Zeeuw D, de Jong PE. Antiproteinuric effect of blood-pressure-lowering agents: a meta-analysis of comparative trials. Nephrol Dial Transplantation. 1995;10:1963-1974.
82 Ahmad J, Siddiqui MA, Ahmad H. Effective postponement of diabetic nephropathy with enalapril in normotensive type 2 diabetic patients with microalbuminuria. Diabetes Care. 1997;20:1576-1581. [pmid: 9314638].
83 Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. 2001;345:851-860. [pmid: 11565517].
84 Brenner BM, Cooper ME, de Zeeuw D, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. N Engl J Med. 2001;345:861-869. [pmid: 11565518].
85 Parving HH, Lehnert H, Brochner-Mortensen J, Gomis R, Andersen S, Arner P. The effect of irbesartan on the development of diabetic nephropathy in patients with type 2 diabetes. N Engl J Med. 2001;345:870-878. [pmid: 11565519].
86 Ravid M, Brosh D, Levi Z, Bar-Dayan Y, Ravid D, Rachmani R. Use of enalapril to attenuate decline in renal function in normotensive, normoalbuminuric patients with type 2 diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1998;128:982-988. [pmid: 9625684].
87 UK Prospective Diabetes Study Group. Efficacy of atenolol and captopril in reducing risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 39. BMJ. 1998;317:713-720. [pmid: 9732338]. [pmcid: 28660].
88 Fogari R, Zoppi A, Corradi L, et al. Long-term effects of ramipril and nitrendipine on albuminuria in hypertensive patients with type II diabetes and impaired renal function. J Human Hyperten. 1999;13:47-53.
89 Yusuf S, Sleight P, Pogue J, Bosch J, Davies R, Dagenais G. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. 2000;342:145-153. [pmid: 10639539].
90 Lewis EJ, Hunsicker LG, Bain RP, Rohde RD. The effect of angiotensin-converting-enzyme inhibition on diabetic nephropathy. The Collaborative Study Group. N Engl J Med. 1993;329:1456-1462. [pmid: 8413456].
91 Giatros I, Lau J, Levey AS. Effect of angiotensin-converting enzyme inhibitors on the progression of non-diabetic renal disease: a meta-analysis of randomized trials. Ann Int Med. 1997;127:337-345. [pmid: 9273824].
92 Feldman HI, Klag MJ, Chiapella AP, Whelton PK. End-stage renal disease in US minority groups. Am J Kidney Dis. 1992;19:397-410. [pmid: 1585925].
93 Partanen J, Niskanen L, Lehtinen J, Mervaala E, Siitonen O, Uusitupa M. Natural history of peripheral neuropathy in patients with non-insulin-dependent diabetes mellitus. N Engl J Med. 1995;333:89-94. [pmid: 7777034].
94 Franklin GM, Kahn LB, Baxter J, Marshall JA, Hamman RF. Sensory neuropathy in non-insulin-dependent diabetes mellitus. The San Luis Valley Diabetes Study. Am J Epidemiol. 1990;131:633-643. [pmid: 2316495].
95 Melton LJI, Macken KM, Elveback LR. Incidence and prevalence of clinical peripheral vascular disease in a population-based cohort of diabetic patients. Diabetes Care. 1980;3:650-654. [pmid: 7449595].
96 Dyck PJ, Kratz KM, Karnes JL, et al. The prevalence by staged severity of various types of diabetic neuropathy, retinopathy, and nephropathy in a population-based cohort: the Rochester Diabetic Neuropathy Study [published erratum appears in Neurology 1993 Nov;43(11):2345]. Neurology. 1993;43:817-824. [pmid: 8469345].
97 Ramsey SD, Newton K, Blough D, et al. Incidence, outcomes, and cost of foot ulcers in patients with diabetes. Diabetes Care. 1999;22:382-387. [pmid: 10097914].
98 Abbott CA, Vileikyte L, Williamson S, Carrington AL, Boulton AJ. Multicenter study of the incidence of and predictive risk factors for diabetic neuropathic foot ulceration. Diabetes Care. 1998;21:1071-1075. [pmid: 9653597].
99 Resnick HE, Valsania P, Phillips CL. Diabetes mellitus and nontraumatic lower extremity amputation in black and white Americans: The National Health and Nutrition Examination Survey Epidemiologic Follow-up Study, 1971-1992. Arch Intern Med. 1999;159:2470-275. [pmid: 10665896].
100 Moss SE, Klein R, Klein BE. The 14-year incidence of lower-extremity amputations in a diabetic population. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. Diabetes Care. 1999;22:951-959. [pmid: 10372248].
101 Mason J, O'Keeffe C, McIntosh A, Booth A, Young RJ. A systematic review of foot ulcer in patients with Type 2 diabetes mellitus: prevention. Diabet Med. 1999;16:801-812. [pmid: 10547206].
102 Malone JM, Snyder M, Anderson G, Bernhard VM, Holloway GAJr, Bunt TJ. Prevention of amputation by diabetic education. Am J Surg. 1989;158:520-523. [pmid: 2589581].
103 Litzelman DK, Slemenda CW, Langefeld CD, et al. Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1993;119:36-41. [pmid: 8498761].
104 Wetterhall SF, Olson DR, DeStefano F, et al. Trends in diabetes and diabetic complications, 1980-1987. Diabetes Care. 1992;15:960-967. [pmid: 1324144].
105 Lavery LA, Vela SA, Lavery DC, Quebedeaux TL. Reducing dynamic foot pressures in high-risk diabetic subjects with foot ulcerations. A comparison of treatments. Diabetes Care. 1996;19:818-821. [pmid: 8842597].
106 Valway SE, Linkins RW, Gohdes DM. Epidemiology of lower-extremity amputations in the Indian Health Service, 1982-1987. Diabetes Care. 1993;16:349-353. [pmid: 8422808].
107 Valway S, Freeman W, Kaufman S, Welty T, Helgerson SD, Gohdes D. Prevalence of diagnosed diabetes among American Indians and Alaska Natives, 1987: estimates from a national outpatient database. Diabetes Care. 1993;16:271-276. [pmid: 8422791].
108 Kannel WB, McGee DL. Diabetes and glucose tolerance as risk factors for cardiovascular disease: the Framingham Study. Diabetes Care. 1979;2:120-126. [pmid: 520114].
109 Knatterud GL, Klimt CR, Levin ME, Jacobson ME, Goldner MG. Effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. VII. Mortality and selected nonfatal events with insulin treatment. JAMA. 1978;240:37-42. [pmid: 351218].
110 Abraira C, Colwell J, Nuttall F, et al. Cardiovascular events and correlates in the Veterans Affairs Diabetes Feasibility Trial. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes. Arch Intern Med. 1997;157:181-188. [pmid: 9009975].
111 Curb JD, Pressel SL, Cutler JA, et al. Effect of diuretic-based antihypertensive treatment on cardiovascular disease risk in older diabetic patients with isolated systolic hypertension. Systolic Hypertension in the Elderly Program Cooperative Research Group. JAMA. 1996;276:1886-1892. [pmid: 8968014].
112 Tuomilehto J, Rastenyte D, Birkenhager WH, et al. Effects of calcium-channel blockade in older patients with diabetes and systolic hypertension. Systolic Hypertension in Europe Trial Investigators. N Engl J Med. 1999;340:677-684. [pmid: 10053176].
113 Hansson L, Lindholm LH, Niskanen L, et al. Effect of angiotensin-converting-enzyme inhibition compared with conventional therapy on cardiovascular morbidity and mortality in hypertension: the Captopril Prevention Project (CAPPP) randomised trial. Lancet. 1999;353:611-616. [pmid: 10030325].
114 Tatti P, Pahor M, Byington RP, et al. Outcome results of the Fosinopril Versus Amlodipine Cardiovascular Events Randomized Trial (FACET) in patients with hypertension and NIDDM. Diabetes Care. 1998;21:597-603. [pmid: 9571349].
115 Estacio RO, Jeffers BW, Hiatt WR, Biggerstaff SL, Gifford N, Schrier RW. The effect of nisoldipine as compared with enalapril on cardiovascular outcomes in patients with non-insulin-dependent diabetes and hypertension. N Engl J Med. 1998;338:645-652. [pmid: 9486993].
116 Dahlof B, Devereux RB, Kjeldsen SE, et al. Cardiovascular morbidity and mortality in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359:995-1003. [pmid: 11937178].
117 Lindholm LH, Ibsen H, Dahlof B, et al. Cardiovascular morbidity and mortality in patients with diabetes in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359:1004-1010. [pmid: 11937179].
118 Pyorala K, Pedersen TR, Kjekshus J, Faergeman O, Olsson AG, Thorgeirsson G. Cholesterol lowering with simvastiatin improves prognosis of diabetic patients with coronary heart disease: a subgroup analysis of the Scandinavian Simvastatin Survival Study (4S). Diabetes Care. 1997;20:614-620. [pmid: 9096989].
119 Haffner SM, Alexander CM, Cook TJ, et al. Reduced coronary events in simvastatin-treated patients with coronary heart disease and diabetes or impaired fasting glucose levels:subgroup analyses in the Scandinavian Simvastatin Survival Study. Arch Intern Med. 1999;159:2661-2667. [pmid: 10597756].
120 Goldberg RB, Mellies MJ, Sacks FM, et al. Cardiovascular events and their reduction with Pravastatin in diabetic and glucose-intolerant myodardial infarction survivors with average cholesterol levels: subgroup analyses in the Cholesterol and Recurrent Events (CARE) Trial. Circulation. 1998;98:2513-2519. [pmid: 9843456].
121 The Long-Term Intervention with Pravastatin in Ischaemic Disease (LIPID) Study Group. Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels. N Engl J Med. 1998;339:1349-1357. [pmid: 9841303].
122 Rubins HB, Robins SJ, Collins D, et al. Gemfibrozil for the secondary prevention of coronary heart disease in men with low levels of high-density lipoprotein cholesterol. N Engl J Med. 1999;341:410-418. [pmid: 10438259].
123 Sacks FM, Tonkin AM, Craven T, et al. Coronary heart disease in patients with low LDL-cholesterol: benefit of pravastatin in diabetics and enhanced role for HDL-cholesterol and triglycerides as risk factors. Circulation. 2002;105:1424-1428. [pmid: 11914249].
124 Downs JR, Clearfield M, Weis S, et al. Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels. JAMA. 1998;279:1615-22. [pmid: 9613910].
125 Elkeles RS, Diamond JR, Poulter C, et al. Cardiovascular outcomes in type 2 diabetes. A double-blind placebo-controlled study of bezafibrate: the St. Mary's, Ealing, Northwick Park Diabetes Cardiovascular Disease Prevention (SENDCAP) Study. Diabetes Care. 1998;21:641-648. [pmid: 9571357].
126 Steering Committee of the Physicians' Health Study Research Group. Final report on the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1989;321:129-135. [pmid: 2664509].
127 Early Treatment Diabetic Research Study Investigators. Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early Treatment Diabetic Retinopathy Study report 14. JAMA. 1992;268:1292-1300. [pmid: 1507375].
128 Antithrombotic Trialists' Collaboration. Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. BMJ. 2002;324:71-86. [pmid: 11786451]. [pmcid: 64503].
129 Prosser LA, Stinnett AA, Goldman PA, et al. Cost-effectiveness of cholesterol-lowering therapies according to selected patient characteristics. Ann Int Med. 2000;132:769-779. [pmid: 10819699].
130 Carter JS, Pugh JA, Monterrosa A. Non-insulin-dependent diabetes mellitus in minorities in the United States. Ann Intern Med. 1996;125:221-232. [pmid: 8686981].
131 Howard BV, Lee ET, Cowan LD, et al. Coronary heart disease prevalence and its relation to risk factors in American Indians. The Strong Heart Study. Am J Epidemiol. 1995;142:254-268. [pmid: 7631630].
132 Nelson RG, Sievers ML, Knowler WC, et al. Low incidence of fatal coronary heart disease in Pima Indians despite high prevalence of non-insulin-dependent diabetes. Circulation. 1990;81:987-995. [pmid: 2306842].
133 Hu FB, Sigal RJ, Rich-Edwards JW, et al. Walking compared with vigorous physical activity and risk of type 2 diabetes in women: a prospective study. J Am Med Assoc. 1999;282:1433-1439.
134 Manson JE, Nathan DM, Krolewski AS, Stampfer MJ, Willett WC, Hennekens CH. A prospective study of exercise and incidence of diabetes among US male physicians. JAMA. 1992;268:63-67. [pmid: 1608115].
135 Helmrich SP, Ragland DR, Leung RW, Paffenbarger RJ. Physical activity and reduced occurrence of non-insulin-dependent diabetes mellitus. N Engl J Med. 1991;325:147-152. [pmid: 2052059].
136 Manson JE, Rimm EB, Stampfer MJ, et al. Physical activity and incidence of non-insulin-dependent diabetes mellitus in women. Lancet. 1991;338:774-778. [pmid: 1681160].
137 Burchfiel CM, Sharp DS, Curb JD, et al. Physical activity and incidence of diabetes: the Honolulu Heart Program. Am J Epidemiol. 1995;141:360-368. [pmid: 7840114].
138 Mayer-Davis EJ, D'Agostino RJr, Karter AJ, et al. Intensity and the amount of physical activity in relation to insulin sensitivity: the Insulin Resistance Atherosclerosis Study. JAMA. 1998;279:669-674. [pmid: 9496984].
139 Keen H, Jarrett RJ, McCartney P. Ten year follow-up of the Bedford survey: glucose tolerance and diabetes. Diabetologica. 1982;22:73-78.
140 Jarrett RJ, Keen H, McCartney P. The Whitehall Study: ten year follow-up report on men with impaired glucose tolerance with reference to worsening diabetes and predictors of death. Diabetic Med. 1984;1:279-283. [pmid: 6242817].
141 Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20:537-544. [pmid: 9096977].
142 Diabetes Prevention Program Research Group. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346:393-403. [pmid: 11832527].
143 Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344:1343-5130. [pmid: 11333990].
144 Dyson PA, Hammersley MS, Morris RJ, Holman RR, Turner RC. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997;46:50-55. [pmid: 9439560].
145 Yusuf S, Gerstein H, Hoogwerf B, et al. Ramipril and the development of diabetes. JAMA. 2001;286:1882-1885. [pmid: 11597291].
146 Freeman DJ, Norrie J, Sattar N, et al. Pravastatin and the development of diabetes mellitus: evidence for a protective treatment effect in the West of Scotland Coronary Prevention Study. Circulation. 2001;103:357-362. [pmid: 11157685].
147 Chiasson JL, Gomis R, Hanefeld M, Josse RG, Karasik A, Laakso M. The STOP-NIDDM Trial: an international study on the efficacy of an alpha-glucosidase inhibitor to prevent type 2 diabetes in a population with impaired glucose tolerance: rationale, design, and preliminary screening data. Study to Prevent Non-Insulin-Dependent Diabetes Mellitus. Diabetes Care. 1998;21:1720-1725. [pmid: 9773737].
148 Cummings S T, Fraser CG. Variability of capillary plasma glucose in healthy individuals in repeated 75 g oral glucose tolerance tests. Ann Clin Biochem. 1988;25:634-637. [pmid: 3254103].
149 Banerji MA, Chaiken RL, Lebovitz HE. Long-term normoglycemic remission in black newly diagnosed NIDDM subjects. Diabetes. 1996;45:337-341. [pmid: 8593939].
150 Mooy JM, Grootenhuis PA, de Vries H, et al. Intra-individual variation of glucose, specific insulin and proinsulin concentrations measured by two oral glucose tolerance tests in a general Caucasian population: the Hoorn Study. Diabetologia. 1996;39:298-305. [pmid: 8721775].
151 Burke JP, Haffner SM, Gaskill SP, Williams KL, Stern MP. Reversion from type 2 diabetes to nondiabetic status. Influence of the 1997 American Diabetes Association criteria. Diabetes Care. 1998;21:1266-1270. [pmid: 9702431].
152 Ollerton RL, Playle R, Ahmed K, Dunstan FD, Luzio SD, Owens DR. Day-to-day variability of fasting plasma glucose in newly diagnosed type 2 diabetic subjects. Diabetes Care. 1999;22:394-398. [pmid: 10097916].
153 Eriksson KE, Lindgärde. Impaired glucose tolerance in a middle-aged male urban population: a whole new approach for identifying high-risk cases. Diabetologia. 1990;33:526-531. [pmid: 2253828].
154 Yudkin JS, Alberti KGMM, McLarty DG, Swai ABM. Impaired glucose tolerance: is it a risk factor for diabetes or a diagnostic ragbag?. Brit Med J. 1990;301:397-401. [pmid: 2282392].
155 Balkau B, Eschwege E. Repeatability of the oral glucose tolerance test for the diagnosis of impaired glucose tolerance and diabetes mellitus. Diabetologia. 1991;34:201-202. [pmid: 1884894].
156 Ramaiya KL, Swai ABM, McLarty DG, Kitange HM, Alberti KGMM. Improvement in glucose tolerance after one year of follow-up in a Hindu community in Africa. Diabet Res Clin Pract. 1990;10:245-255.
157 Swai ABM, McLarty DG, Kitange HM, et al. Study in Tanzania of impaired glucose tolerance: methodological myth?. Diabetes. 1991;40:516-520. [pmid: 2010053].
158 Bourn DM, Williams SM, Mann JI. Distinguishing between persistent and transient impaired glucose tolerance using a prediction model. Diabet Med. 1992;9:744-748. [pmid: 1395468].
159 Warram JH, Sigal RJ, Martin BC, Krolewski AS, Soeldner JS. Natural history of impaired glucose tolerance: follow-up at Joslin Clinic. Diabet Med. 1996;13:S40-S45. [pmid: 8894480].
160 Israili ZH, Wall WD. Cough and angioneurotic edema associated with angiotensin-coverting-enzyme inhibitor therapy: a review of the literature and pathophysiology. Ann Intern Med. 1992;117:234-242. [pmid: 1616218].
161 Pierce LR, Wysowski DK, Gross TP. Myopathy and rhabdomyolysis associated with lovastatin-gemfibrozil combination therapy. JAMA. 1990;264:71-75. [pmid: 2355431].
162 Bradford RH, Shear CL, Chremos AN, et al. Expanded Clinical Evaluation of Lovastatin (EXCEL) study results: two-year efficacy and safety follow-up. Am J Cardiol. 1994;74:667-73. [pmid: 7942524].
163 Testa MA, Simonson DC. Health economic benefits and quality of life during improved glycemic control in patients with type 2 diabetes mellitus: a randomized, controlled, double-blind trial. JAMA. 1998;280:1490-1496. [pmid: 9809729].
164 Testa MA, Simonson DC, Turner RR Valuing quality of life and improvements in glycemic control in people with type 2 diabetes Diabetes Care. 1998 21Suppl 3:C44 52 9850489
165 UK Prospective Diabetes Study Group. Quality of life in type 2 diabetic patients is affected by complications but not by intensive policies to improve blood glucose or blood pressure control (UKPDS 37). Diabetes Care. 1999;22:1125-1136. [pmid: 10388978].
166 Brown JB, Nichols GA, Glauber HS, Bakst AW. Type 2 diabetes: incremental medical care costs during the first 8 years after diagnosis. Diabetes Care. 1999;22:1116-1124. [pmid: 10388977].
167 Centers for Disease Control and Prevention. The cost-effectiveness of screening for type 2 diabetes. CDC Diabetes Cost-Effectiveness Study Group, Centers for Disease Control and Prevention. JAMA. 1998;280:1757-1763. [pmid: 9842951].
168 Brown JB, Pedula KL, Bakst AW. The progressive cost of complications in type 2 diabetes mellitus. Arch Intern Med. 1999;159:1873-1880. [pmid: 10493317].
169 UK Prospective Diabetes Study (UKPDS) Group. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). Lancet. 1998:837-53.
170 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. Lancet. 1998;351:1755-62. [pmid: 9635947].
171 McCance DR, Hanson RL, Charles MA, et al. Which test for diagnosing diabetes?. Diabetes Care. 1995;18:1042-1044. [pmid: 7555540].
172 DRS. Photocoagulation treatment of proliferative diabetic retinopathy. Clinical application of Diabetic Retinopathy Study (DRS) findings, DRS Report Number 8. The Diabetic Retinopathy Study Research Group. Ophthalmology. 1981;88:583-600. [pmid: 7196564].
173 Early Treatment Diabetic Retinopathy Study Research Group. Photocoagulation for diabetic macular edema. Early Treatment Diabetic Retinopathy Study report number 1. Arch Ophthalmol. 1985;103:1796-1806. [pmid: 2866759].
174 Early Treatment Diabetic Retinopathy Study Research Group. Early Treatment Diabetic Retinopathy Study design and baseline patient characteristics. ETDRS report number 7. Ophthalmology. 1991;98:741-756. [pmid: 2062510].
175 Knatterud GL, Meinert CL, Klimt CR, Osborne RK, Martin DB. Effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. IV. A preliminary report on phenoformin results. JAMA. 1971;217:777-84. [pmid: 4935344].
176 Knatterud GL, Klimt CR, Levin ME, Jacobson ME, Goldner MG. Effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. VII. Mortality and selected nonfatal events with insulin treatment. JAMA. 1978;240:37-42. [pmid: 351218].
177 UK Prospective Diabetes Study (UKPDS) Group. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). Lancet. 1998;352:854-65. [pmid: 9742977].
178 Ohkubo Y, Kishikawa H, Araki E, et al. Intensive insulin therapy prevents the progression of diabetic microvascular complications in Japanese patients with non-insulin-dependent diabetes mellitus: a randomized prospective 6-year study. Diabetes Res Clin Pract. 1995;28:103-17. [pmid: 7587918].
179 Shichiri M, Kishikawa H, Ohkubo Y, Wake N Long-term results of the Kumamoto Study on optimal diabetes control in type 2 diabetic patients Diabetes Care. 2000 23Suppl 2:B21 9 10860187
180 Abraira C, Colwell J, Nuttall F, et al. Cardiovascular events and correlates in the Veterans Affairs Diabetes Feasibility Trial. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes. Arch Intern Med. 1997;157:181-8. [pmid: 9009975].
181 Abraira C, Colwell JA, Nuttall FQ, et al. Veterans Affairs Cooperative Study on glycemic control and complications in type II diabetes (VA CSDM). Results of the feasibility trial. Veterans Affairs Cooperative Study in Type II Diabetes. Diabetes Care. 1995;18:1113-23. [pmid: 7587846].
182 Azad N, Emanuele NV, Abraira C, et al. The effects of intensive glycemic control on neuropathy in the VA cooperative study on type II diabetes mellitus (VA CSDM). J Diabetes Complications. 1999;13:307-13. [pmid: 10765007].
183 Levin SR, Coburn JW, Abraira C, et al. Effect of intensive glycemic control on microalbuminuria in type 2 diabetes. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type 2 Diabetes Feasibility Trial Investigators. Diabetes Care. 2000;23:1478-85. [pmid: 11023140].
184 Gaede P, Vedel P, Parving HH, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353:617-22. [pmid: 10030326].
185 Estacio RO, Jeffers BW, Hiatt WR, Biggerstaff SL, Gifford N, Schrier RW. The effect of nisoldipine as compared with enalapril on cardiovascular outcomes in patients with non-insulin-dependent diabetes and hypertension. N Engl J Med. 1998;338:645-52. [pmid: 9486993].
186 Tatti P, Pahor M, Byington RP, et al. Outcome results of the Fosinopril Versus Amlodipine Cardiovascular Events Randomized Trial (FACET) in patients with hypertension and NIDDM. Diabetes Care. 1998;21:597-603. [pmid: 9571349].
187 UK Prospective Diabetes Study Group (UKPDS). Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. BMJ. 1998;317:703-13. [pmid: 9732337].
188 UK Prospective Diabetes Study Group (UKPDS). Efficacy of atenolol and captopril in reducing risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 39. BMJ. 1998;317:713-20. [pmid: 9732338].
189 Hansson L, Lindholm LH, Niskanen L, et al. Effect of angiotensin-converting-enzyme inhibition compared with conventional therapy on cardiovascular morbidity and mortality in hypertension: the Captopril Prevention Project (CAPPP) randomised trial. Lancet. 1999;353:611-6. [pmid: 10030325].
190 Niskanen L, Hedner T, Hansson L, Lanke J, Niklason A. Reduced cardiovascular morbidity and mortality in hypertensive diabetic patients on first-line therapy with an ACE inhibitor compared with a diuretic/beta-blocker-based treatment regimen: A subanalysis of the Captopril Prevention Project. Diabetes Care. 2001;24:2091-6. [pmid: 11723089].
191 Brown MJ, Palmer CR, Castaigne A, et al. Morbidity and mortality in patients randomised to double-blind treatment with a long-acting calcium-channel blocker or diuretic in the International Nifedipine GITS study: Intervention as a Goal in Hypertension Treatment (INSIGHT). Lancet. 2000;356:366-72. [pmid: 10972368].
192 Estacio RO, Jeffers BW, Gifford N, Schrier RW Effect of blood pressure control on diabetic microvascular complications in patients with hypertension and type 2 diabetes Diabetes Care. 2000 23Suppl 2:B54 64 10860192
193 Hansson L, Hedner T, Lund-Johansen P, et al. Randomised trial of effects of calcium antagonists compared with diuretics and beta-blockers on cardiovascular morbidity and mortality in hypertension: the Nordic Diltiazem (NORDIL) Study. Lancet. 2000;356:359-65. [pmid: 10972367].
194 Lindholm LH, Hansson L, Ekbom T, et al. Comparison of antihypertensive treatments in preventing cardiovascular events in elderly diabetic patients: results from the Swedish Trial in Old Patients with Hypertension-2. STOP Hypertension-2 Study Group. J Hypertens. 2000;18:1671-5. [pmid: 11081782].
195 Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. 2001;345:851-60. [pmid: 11565517].
196 UK Prospective Diabetes Study Group. U.K. Prospective Diabetes Study 27. Plasma lipids and lipoproteins at diagnosis of NIDDM by age and sex. Diabetes Care. 1997;20:1683-1687. [pmid: 9353608].
197 Vijan S, Hofer TP, Hayward RA. Estimated benefits of glycemic control in microvascular complications in type 2 diabetes. Ann Intern Med. 1997;127:788-795. [pmid: 9382399].
198 UK Prospective Diabetes Study Group. Cost effectiveness analysis of improved blood pressure control in hypertensive patients with type 2 diabetes: UKPDS 40. BMJ. 1998;317:720-726. [pmid: 9732339]. [pmcid: 28661].