# Discussion

## Effects of Screening

The benefits of screening for type 2 diabetes mellitus (DM-2) have not been demonstrated in any well-performed randomized controlled trial (RCT). Indirect evidence indicates that diabetic complications such as blindness, chronic renal failure (CRF), and lower extremity amputation (LEA) are relatively uncommon until diabetes has been present for 15 to 20 years. The effect on these distant outcomes of an additional few years of tight glycemic control during the period between a screening diagnosis and a clinical diagnosis is uncertain. The incremental benefit of systematic screening is further mitigated by the prevalence of haphazard screening. Systematic screening poses some potential but unproven harm. The costs of screening and earlier treatment and the efforts required of primary care providers are substantial.

In the decade after the diagnosis of DM-2, diabetic outcomes such as visual impairment less severe than blindness and cardiovascular disease (CVD) events are more common than the complications noted above. Visual impairment and CVD events can be reduced by a clinically important amount among hypertensive diabetics by tight control of blood pressure, using a target diastolic blood pressure of 80 mm Hg and ACE inhibitors as a first line of therapy.

Three factors are significant in understanding the impact of screening and estimating numbers needed to screen (NNS): extent to which diabetics with hypertension attain optimal blood pressure control, length of any preclinical period, and prevalence of undetected diabetes among hypertensives. That is, all other things equal, estimates of the NNSs to prevent either 1 case of visual impairment or 1 CVD event will be lower if knowledge of the diagnosis of DM-2 substantially increases the percentage of hypertensive diabetics with optimal blood pressure control, if the detectable preclinical period is 5 years or more, or if the prevalence of undiagnosed DM-2 among those with blood pressure of 140/90 or greater is about 6% (or if any combination of these factors holds).

A similar analysis might be made for other CVD risk factors. If detection of DM-2 improves CVD risk assessment and increases the number of people appropriately treated for dyslipidemia, if it increases the effectiveness of treatment for tobacco use, or if it increases the number of people appropriately treated with prophylactic aspirin, then this earlier diagnosis would add to the benefits of screening. No direct evidence permits one to estimate the degree to which detection of DM-2 would lead to these types of improved treatment.

If treatment of people with IFG/IGT not only prevents the development of DM-2 but also has a large effect on its complications, or if knowledge of the presence of IFG/IGT improves optimal treatment of CVD risk factors among this large group, then these would be added benefits of screening. However, we do not yet have full enough understanding of these issues to base widespread action on them.

## Recommendations for Further Research

Screening for DM-2 is an important issue with many unanswered questions. Although several treatments started at clinical diagnosis are known to reduce diabetic complications, the extent to which they have added effect by earlier initiation, during the period between screening and clinical detection, is unknown. Studies are needed that examine the optimal starting time, including the preclinical period, of various treatments in preventing complications. Because some of these complications occur only many years after diagnosis, these studies should include long-term follow-up.

Because not all people with abnormal glycemic tests are at equal risk of diabetic complications, studies that help define high- and low-risk groups are needed to better target such interventions as screening.

Ideally, an RCT should be considered. Mounting such a study, although expensive and difficult, could teach us much about preventing diabetic complications. In the absence of such a trial, natural experiments should be examined. Areas that adopt an aggressive screening strategy could be compared with areas that include little screening. Registries of people with diabetes, including diabetic complications, would be helpful in these studies.

Until we have better evidence about the benefits, harms, and costs of screening, its role in the effort to reduce the burden of suffering of diabetes will remain uncertain. Current evidence suggests that the benefits of screening are more likely to come from modifications of CVD risk factors than from tight glycemic control.