# Results

Our presentation of results is arranged chiefly in accordance with the 6 key questions (KQ) introduced in Chapter 2 and Table 1. Specifically, we address the following issues: presence of a detectable preclinical period for DM-2; properties of diabetes screening tests (KQ No. 2); efficacy and effectiveness of various treatments (KQ No. 3); including interventions for persons with IFG or IGT (KQ No. 4); harms of screening or earlier treatment (KQ No. 5); and costs and cost-effectiveness (KQ No. 6). For KQ No. 3 on therapies, we organize the discussion in terms of the four major health outcomes - vision impairment, chronic renal failure, lower extremity ulcers or amputations, and cardiovascular events (myocardial infarction, stroke, cardiovascular death) - specified in the Analytic Framework (Figure 2).

Studies meeting our inclusion criteria that provide data for the sections that follow appear in one or more of the 9 evidence tables found in Appendix B. Those tables contain abstracted information on the following topics:

- Properties of screening studies (KQ 2) (Evidence Table [ET] 1);
- Treatment studies (KQ 3): impact of tight glycemic control (ET 2); studies on antihypertensives and angiotensin interruptors (ET 3); laser photocoagulation for visual impairment (ET 4); foot care and lower extremity amputation (ET 5); lipid-lowering medications for cardiovascular disease (ET 6);
- efficacy of lifestyle interventions for persons identified on screening as having IFT/IGT (KQ 4) (ET 7);
- harms of screening or treatment (KQ 5) (ET 8); and
- costs and cost-effectiveness (KQ 6) (ET 9).

## Presence of a Detectable Preclinical Period

Many people not known to have DM-2 meet criteria for this disease.^ 25 ^ Thus, the natural history of DM-2 often includes a detectable preclinical period, but the length of this period is uncertain. One can estimate the length of this period by (a) extrapolating backward in time from the prevalence of retinopathy at various times after clinical diagnosis to the presumed time when retinopathy begins^ 38 ^ and (b) then adding to that an estimate of the time after disease origin when retinopathy becomes apparent.^ 39 ^ Using these two estimates, some have suggested that the detectable preclinical period has a mean length of 10 to 12 years and that systematic screening would detect the disease at an average of 5 to 6 years before clinical diagnosis.

The length is important because any added benefit of screening must be produced by effective treatment during this preclinical period. If the period is short, then the treatment will have limited time to influence outcomes. Only a randomized controlled trial (RCT) of screening can accurately determine the length of the detectable preclinical period.

The classification of diabetes includes an intermediate category, "impaired glucose tolerance" (IGT, used when the glucose tolerance test defines the disease) or "impaired fasting glucose" (IFG, used when the fasting plasma glucose defines the disease). Criteria for these conditions include a 2-hour post-load plasma glucose (or a fasting plasma glucose) above the "normal" range but below the "diabetic" range. People in this intermediate category would also be detected by screening. Although not everyone with IFG/IGT progresses to DM-2, the group as a whole manifests an increased risk of developing DM-2. Thus, the preclinical period for DM-2 includes both a "pre-detection" period (during which people meet diagnostic criteria but have not been diagnosed) and an earlier "pre-disease" period (during which people do not yet meet diagnostic criteria but are at increased risk).

## Accuracy and Acceptability of Screening Tests

Key Question No. 2 dealt with the yield of screening, including accuracy and reliability of the various tests. Determining the accuracy of screening tests for DM-2 is complicated by the uncertainty about the most appropriate "gold standard" for comparison. Ideally, the gold standard should be the test that best distinguishes persons who do not develop complications from those who do. Data on studies relevant to these issues are presented in Evidence Table 1 (Appendix B). Our main finding, discussed here, is that although no test is perfect, several screening tests with adequate acceptability and accuracy for DM-2 are available.

Three large population-based studies have examined the sensitivity of 3 potential screening tests in detecting existing retinopathy among those not previously diagnosed as diabetic. The tests are the 2-hour post-load plasma glucose (2 hr PG), the fasting plasma glucose (FPG), and the hemoglobin A1c (Hb A1c). At current nationally used cutpoints (FPG 126 mg/dl; 2 hr PG 200 mg/dl; Hb A1c > 6.4%), both sensitivity and specificity for detecting retinopathy were in the range of 74% to 88% for all 3 tests.^40-42^ One of these studies also examined the performance of the 3 tests in predicting future retinopathy, finding that they each performed about the same.^ 40 ^

Other studies have examined whether these 3 tests predict future cardiovascular disease (CVD). In a recent meta-regression analysis of 20 observational studies, Coutinho et al found that both FPG and 2 hr PG were significantly associated with future CVD events.^ 43 ^ The association was curvilinear with the greatest risk at the highest glucose levels, but some increased risk persisted below the current cutpoint for DM-2 (i.e., FPG _ 126 mg/dl; 2 hr PG 200 mg/dl). The Coutinho et al analysis was not able to determine to what extent this association was independent of other CVD risk factors, but later work has shown that only part of the increased risk is explained by other known risk factors.^44,45^ These findings are seen also in other, more recent studies, which include Hb A1c as well as FPG and 2 hr PG.^44,46,47^

Although all these tests can detect or predict diabetes complications, their results are not identical. Because diabetics often develop postprandial hyperglycomia before fasting hyperglycemia, the 2 hr PG test is more often abnormal than the FPG.^ 29 ^ Using a 2 hr PG of 200 mg/dl as the reference standard, Harris et al showed that the specificity of an FPG 126 mg/dl is greater than 90% and that the sensitivity is about 50%.^ 29 ^ According to Blunt et al, the sensitivity may be lower for people older than age 65 years.^ 48 ^

Among the general, previously nondiabetic population of people ages 40 to 74 years in NHANES III (prevalence of 2 hr PG 200 mg/dl of 6.6%), a person with an FPG of 140 mg/dl or greater has a 91% probability of having a 2 hr PG of 200 mg/dl. For an FPG of 110 to 126 mg/dl, the probability is 18%.^ 29 ^

Hb A1c is not sensitive to lower-level elevations of FPG. Among persons meeting the current definition of IFG (110 to 125 mg/dl) in one large study, Hb A1c was normal (less than or equal to 6.1%) in nearly 87% of those tested.^ 49 ^ Among those with previously undiagnosed DM-2 who are in the low range of "diabetic level" FPG (ie, FPG between 126 and 140 mg/dl), Hb A1c was normal in about 60% of those tested.

Some experts have argued that excessive glycosylation, as exemplified by Hb A1c, is an important intermediate step in some of the microvascular complications of DM-2. By this reasoning, persons with lower levels of hyperglycemia should also have an elevated Hb A1c before any conclusive diagnosis is made.^ 49 ^

A single 2 hr PG is less reproducible than an FPG.^ 50 ^ The Hb A1c assay has not been completely standardized, although the National Glycohemoglobin Standardization Program has made progress in this direction.^ 51 ^ Because of individual differences in glycosylation and red blood cell turnover, Hb A1c varies more between individuals than within nondiabetic individuals, thus raising questions as to whether any screening cutpoint can be determined for a large group of people.^ 52 ^

In clinical practice, the requirement for a screening test to be either fasting (as with the FPG) or post glucose load (as with the 2 hr PG) presents logistical problems. A well-conducted, population-based study found that random capillary blood glucose (CBG) had sensitivity and specificity in the 75% to 80% range for detecting DM-2 defined by older criteria (i.e., FPG 140 mg/dl or 2 hr PG 200 mg/dl) if results were interpreted according to age and time since last meal.^ 53 ^ Another analysis found a sensitivity of 75% to 84% and a specificity of 88% to 90% in primary care populations for a random CBG with a cutpoint of 126 mg/dl.^ 54 ^

## Efficacy and Effectiveness of Treatment

We review here whether treatments affect any of the 4 health outcomes shown in Figure 2: namely, visual impairment, chronic renal failure, lower extremity amputations, and CVD events. The analysis also tries to clarify the "delta" question reflected in Figure 2, that is, whether early treatment started at screening diagnosis will yield benefits (reduce complications over and above those produced from treatments started at clinical diagnosis.

Evidence Tables 2-6 (Appendix B) deal with the main therapeutic approaches that are used singly or in combination to address these clinical issues. We also examine the evidence that treatments aimed at those people with IFG or IGT (IFG/IGT), a group frequently identified through screening, produce a difference in these diabetic complications.

The most compelling evidence for a difference in the incidence of health outcomes between those diabetics detected by screening and those identified by clinical detection would come from an RCT of screening. Several recent RCTs of treatment (comparing Lines A and B in Figure 1) have been conducted. However, no RCT of screening for DM-2 (comparing Lines B and C) has yet been done; as noted earlier, this means no direct evidence answers KQ No. 6. Thus, the evidence we review in this section is necessarily indirect, requiring extrapolation to answer our remaining key questions.

Screening for DM-2 involves a further complexity. The alternative to screening is not the absence of screening because the latter already occurs "haphazardly" through incidental blood work and urine screening. Surveys in the United States have found that about 30% to 40% of people more than 45 years of age report having been screened for DM-2 within the previous year.^55,56^

Our interest in this review, however, is to compare the health outcomes between a strategy of no screening and a strategy of systematic (not haphazard) screening. In this review, we use the term "clinical detection" for Line B (meaning detection by clinical symptoms or associated conditions) and the term "screening detection" for Line C (meaning detection by systematic screening); we do not consider the consequences of haphazard screening.

## Severe Visual Impairment

Diabetes affects vision in at least 3 ways. First, diabetics develop changes in retinal blood vessels - diabetic retinopathy (including its related condition, macular edema) - not generally seen in nondiabetics. In addition, diabetics develop cataracts and glaucoma more frequently than nondiabetics. Most diabetes-related visual impairment is associated with retinopathy, and thus our review will focus on this area.

### Incidence and Prevalence of Retinopathy and Visual Impairment

The prevalence of any retinopathy increases from about 8% to 10% at screening diagnosis to about 21% at clinical diagnosis.^57-59^

The prevalence of the most severe form of retinopathy ("proliferative diabetic retinopathy") is less than 1% at both screening and clinical diagnosis. The prevalence of retinopathy of intermediate severity increases from about 4% at screening to about 10% at clinical detection.^ 60 ^

Newly diagnosed diabetics (by either screening or clinical means) rarely have retinopathy severe enough to require immediate photocoagulation. Of nearly 3,000 newly clinically diagnosed diabetics examined in the United Kingdom Prospective Diabetes Study (UKPDS), only 8 had retinopathy severe enough to require immediate photocoagulation.^57,58^

After 20 to 25 years, the great majority of all diabetics have some degree of retinopathy, but the incidence of severe retinopathy varies by baseline glycemic level. Less than 5% of those with Hb A1c levels less than 8.5% at baseline, and about 40% of those with Hb A1c greater than 11.6%, have severe retinopathy.^61-63^ Today at clinical diagnosis more people are in the former category than the latter; in the UKPDS, the mean Hb A1c at clinical diagnosis was 9.3%.^ 64 ^

After 10 years' duration, about 18% of diabetics will have some degree of visual deterioration (defined as "doubling of the visual angle," eg, going from vision of 20/40 to 20/80) and 5% or less will be blind, although the absolute difference between diabetics and nondiabetics for both outcomes is not clear. People developing DM-2 after the age of 60 to 70 years have higher 10-year rates of blindness and visual deterioration, but this is also true of nondiabetics at this age.^ 65 ^ A national survey found that, compared with persons who did not have diabetes, diabetic patients (including those with recent and those with remote onset), 8% to 10% more reported "trouble seeing" and 1% to 2% reported blindness.^ 1 ^

Few studies have reported the prevalence of visual impairment among patients with DM-2 for longer than 10 years; and those that have are based on small numbers of diabetics with long-term survival who have had limited access to present-day ophthalmological techniques, including photocoagulation. The best data show that the 10-year incidence of blindness among those with DM-2 of 20 to 25 years duration is between 5% and 15%, and the 10-year incidence of visual deterioration (doubling of the visual angle) is between 35% and 45%; the higher numbers are for those diabetics requiring insulin treatment.^ 65 ^

Modeling studies extrapolating from increasing rates of retinopathy over time have estimated that nearly 20% of diabetics will eventually become blind. The highest risk is among those with onset at a younger age, who have a longer time to develop visual complications.^66,67^

### Treatment to Prevent Visual Impairment

Three treatments to reduce the incidence of visual impairment have been studied: laser photocoagulation (Evidence Table 2), tight glycemic control (Evidence Table 3), and tight blood pressure control (>Evidence Table 4).

#### Photocoagulation

For those diabetics who receive regular retinal screening, retinal photocoagulation dramatically decreases the development of severe visual impairment and blindness. Good evidence from well-performed RCTs indicates that photocoagulation for those with the worst forms of retinopathy reduces the incidence of severe visual impairment by 90%; photocoagulation for macular edema reduces the incidence of less severe visual impairment by 50%. Photocoagulation at an earlier stage of retinopathy is not as useful, making this treatment less applicable to the period between screening and clinical diagnosis.^68-70^

#### Tight glycemic control

Two well-performed RCTs have shown that tight glycemic control reduces the relative risk of development or progression of retinopathy by a relative 29% (P = 0.0031)^ 30 ^ to 40% (P not given).^ 33 ^ Absolute risk reduction is smaller: in the UKPDS, 10.3% of patients in the conventional glycemic control arm and 7.6% of those in the tight control group required laser photocoagulation after 10 years (absolute difference = 2.7%). Neither trial found a difference in visual outcomes. These results are similar to those of the Diabetes Control and Complications Trial among people with type 1 diabetes.^ 71 ^

#### Tight blood pressure control

One large (n = 1,148) well-performed RCT found that a reduction in blood pressure among hypertensive diabetics to 144/82 from 154/87 decreased the need for retinal photocoagulation by an absolute 4.1% (12.1% vs. 8.0%).^ 31 ^ Such a reduction also decreased deterioration in visual acuity (defined as a reduction in visual acuity by 3 or more lines in a standardized scale) by an absolute 9.2% (19.4% vs 10.2%) over 7.5 years. About the same percentage in each group (3.3% vs. 2.4%) developed blindness.

#### Summary

Retinal photocoagulation is effective in reducing the incidence of visual impairment among those with severe retinopathy or macular edema. It is not of great use during the period between screening and clinical diagnosis.

Tight glycemic control reduces the development and progression of retinopathy, but the degree to which it reduces visual impairment is less clear. Any reduction in visual impairment occurs more than 10 years after the diagnosis of diabetes.^ 30 ^ Even less certain is the degree to which tight glycemic control during the preclinical period between screening and clinical detection, a time when glucose levels are at less than their peak, reduces retinopathy and later visual impairment.

Tight blood pressure control among hypertensive diabetics reduces visual impairment. Detection of DM-2 through screening could prompt tighter blood pressure control during the preclinical period. Depending on the length of the preclinical period, this practice could perhaps decrease the later emergence of vision problems related to diabetes.

Table 2 considers the number needed to screen (NNS) to prevent 1 case of blindness given various assumptions. For cases of blindness, we start with several favorable assumptions (Table 2, Case 1). Assuming that tight glycemic control yields a 29% reduction in the risk of blindness in 1 eye among diabetics identified by screening (the relative risk reduction in retinal photocoagulation in the UKPDS trial^ 30 ^), that the risk of blindness over 5 years is 1.5% (half of the 10 year risk found in UKPDS^ 30 ^), and that all newly identified diabetics achieve tight glycemic control, then the NNS is about 3,900 to prevent 1 case of blindness by tight glycemic control for 5 years. Cases 2 through 4 change the assumptions in less optimistic directions. If screening increases the percentage of newly identified diabetics with tight glycemic control by only 50% (Case 2, middle example) rather than 100% (Case 1), then the NNS becomes about 7,700. Cases 3 and 4, with even less favorable assumptions about, respectively, years of additional treatment and prevalence of undiagnosed diabetes, given higher NNS calculations.

Table 3 provides 5-year NNS calculations to prevent 1 CVD event by screening people with hypertension for diabetes. Assuming a 7.5% 5-year risk of a CVD event and a 50% relative risk reduction from tight blood pressure control, the NNS is about 500 (Table 3, Case 1). If only 50% of diabetic hypertensives detected by screening actually receive tight blood pressure control as a result of diabetes screening, the NNS is about 900 (Case 2, middle example).

Table 2. Number Needed to Screen (NNS) for Diabetes to Prevent One Case of Blindness in One Eye by Tight Glycemic Control

Case 1: Screen 1,000 persons with BP>= 140/90 Assume: a. 6% prevalence of undiagnosed diabetes b. 5 years of additional treatment for diabetes c. 1.5% 5-year risk of blindness in one eye with loose (no) glycemic control* d. 29% relative risk reduction for blindness in one eye with tight glycemic control† e. Screening produces 100% absolute increase in the percentage of diabetics with tight glycemic control (i.e., all newly detected diabetics achieve adequate control)
  Number of diabetics detected by screening | | 60
  Number of cases of blindness in one eye after 5 years, among the 60 newly detected diabetics | If 0% achieve tight control, | 0.90
  | If 100% achieve tight control, | 0.64
  Difference: number of cases of blindness prevented** | | 0.26
  Number needed to screen (NNS)‡ to prevent one case | | 3,900
Case 2: Same as Case 1, except that we vary the absolute increase in the percentage of diabetics with tight control produced by screening.
  Screening increases the percentage of newly detected diabetics with tight glycemic control by: | Cases Prevented ** | NNS ‡
  10% | 0.03 | 38,400
  25% | 0.07 | 15,400
  50% | 0.13 | 7,700
  75% | 0.20 | 5,200
  90% | 0.23 | 4,300
Case 3: Same as Case 2, except that we assume that screening produces only 2.5 years of additional treatment rather than 5 years, thus decreasing the number of cases of blindness prevented by 50%.
  Screening increases the percentage of newly detected diabetics with tight glycemic control by: | Cases Prevented ** | NNS ‡
  10% | 0.01 | 76,700
  25% | 0.03 | 30,700
  50% | 0.07 | 15,400
  75% | 0.10 | 10,300
  90% | 0.12 | 8,600
Case 4: Same as Case 3, except that we assume that the prevalence of undiagnosed diabetes is 3%, rather than 6%, thus decreasing the number of cases of blindness prevented by a further 50%.
  Screening increases the percentage of newly detected diabetics with tight glycemic control by: | Cases Prevented ** | NNS ‡
  10% | 0.01 | 153,300
  25% | 0.02 | 61,400
  50% | 0.04 | 30,700
  75% | 0.06 | 20,500
  90% | 0.07 | 17,000

* Loose glycemic control is equivalent to no treatment for hyperglycemia

† Based on assumption that reduction in the relative risk of blindness in one eye attributable to tight glycemic control is equal to the reduction in the rate of retinal photocoagulation in the UKPDS study^ 169 ^.

** Cases prevented calculations rounded to nearest 0.01.

‡ All NNS calculations are rounded upward to nearest hundred.

Table 3. Number Needed to Screen (NNS) for Diabetes to Prevent One Cardiovascular (CVD) Event by Tight Blood Pressure Control

Case 1: Screen 1,000 persons with blood pressure >= 140/90 Assume: a. 6% prevalence of undiagnosed diabetes among those with elevated blood pressure levels b. 5 years of additional treatment for elevated blood pressure c. 7.5% 5-year risk of CVD event with loose blood pressure control* d. 50% relative risk reduction in CVD events with tight blood pressure control† e. Screening produces 100% absolute increase in the percentage of diabetic hypertensives with tight control of blood pressure
  Number of diabetics detected by screening | | 60
  Number of CVD events after 5 years, among the 60 diabetic hypertensives detected | If 0% achieve tight control, | 4.50
  | If 100% achieve tight control, | 2.25
  Difference: CVD events prevented** | | 2.25
  Number needed to screen (NNS) to prevent one CVD event‡ | | 500
Case 2: Same as Case 1, except that we vary the absolute increase in the percentage of diabetic hypertensives with tight blood pressure control produced by screening.
  Screening increases the percentage of diabetic hypertensives with tight blood pressure control by: | CVD Events Prevented** | NNS‡
  10% | 0.23 | 4,500
  25% | 0.56 | 1,800
  50% | 1.13 | 900
  75% | 1.69 | 600
  90% | 2.03 | 500
Case 3: Same as Case 2, except that we assume screening produces only 2.5 years of additional blood pressure treatment, thus decreasing the number of CVD events prevented by 50%.
  Screening increases the percentage of diabetic hypertensives wth tight blood pressure control by: | CVD Events Prevented** | NNS‡
  10% | 0.11 | 8,900
  25% | 0.28 | 3,600
  50% | 0.56 | 1,800
  75% | 0.84 | 1,200
  90% | 1.01 | 1,000
Case 4: Same as Case 3, except we assume prevalence of undiagnosed diabetes is 3%, rather than 6%, thus decreasing the number of CVD events prevented by a further 50%.
  Screening increases the percentage of diabetic hypertensives with tight blood pressure control by: | CVD Events Prevented** | NNS‡
  10% | 0.06 | 17,800
  25% | 0.14 | 7,200
  50% | 0.28 | 3,600
  75% | 0.42 | 2,400
  90% | 0.51 | 2,000

* Loose blood pressure control is equivalent to a diastolic goal of 90mm Hg; tight blood pressure control is having a diastolic goal of 80mm Hg.

† Based on results for intensive treatment to lower pressure from the Hyptertension Optimal Treatment (HOT) trial.^ 170 ^

** All CVD events prevented calculations are rounded off to nearest 0.01.

‡ All NNS calculations are rounded upward to nearest hundred.

### Special Populations

Cross-sectional data and 1 prospective cohort study show that black diabetics have a higher prevalence and incidence of retinopathy and visual impairment than white diabetics.^59,72^ Mexican American^ 60 ^ and American Indian diabetics^ 73 ^ also have higher rates of retinopathy than do white diabetics. If these rates translate into increased visual impairment in these groups, any benefit of screening would be larger than that for white diabetics. The NNS figures given in Table 2 for tight blood pressure control may be more favorable (ie, lower) for these groups than for white diabetics with respect to treatments to reduce visual impairment; however, the benefit of screening is as uncertain for these groups as it is for white diabetics.

## Chronic Renal Failure

In some diabetics, metabolic, hemodynamic, and genetic factors interact to produce diabetic nephropathy, a condition that can progress to chronic renal failure (CRF). The hallmark of diabetic nephropathy is albuminuria. Albuminuria develops some years after the actual onset of diabetes, first in small amounts (microalbuminuria) and then larger amounts (macroalbuminuria); in some cases, it eventually progresses to CRF.

### Incidence and Prevalence of Albuminuria and Chronic Renal Failure

About 18% to 20% of people with both screening and clinically detected diabetes have microalbuminuria.^74-76^ The prevalence of macroalbuminuria is about 3% at screening detection and between 4% and 8% at clinical detection.^74,77^

After 20 years with diabetes, about 25% of those without initial macroalbuminuria will have developed it. The incidence depends on baseline glycemic levels.^ 77 ^

The incidence of CRF among those without macroalbuminuria at clinical diagnosis is about 0.5% after 15 years with diabetes, 3% after 20 years with diabetes, and 10% after 30 years. Among those with macroalbuminuria at DM-2 diagnosis, the incidence of CRF is about 8% after 10 years DM-2 duration and 12% after 15 years.^ 78 ^

### Treatments to Prevent Chronic Renal Failure

Three treatments have been examined to reduce the incidence of CRF among diabetics: tight glycemic control (Evidence Table 3), tight blood pressure control (Evidence Table 4), and ACE inhibitors or other agents that interrupt the renin-angiotensin system, such as angiotensin receptor blockers (ARBs) (Evidence Table 4).

#### Tight glycemic control

Two RCTs have examined the effectiveness of tight glycemic control in reducing the development of albuminuria and CRF in those with DM-2 - one in Japanese patients^ 33 ^ and the other in the United Kingdom.^ 30 ^ The UKPDS also incorporated a trial of tight versus loose blood pressure control among hypertensive diabetics.^ 31 ^ The studies found that both tight glycemic control and tight blood pressure control reduced the development and progression of albuminuria. Neither intervention, however, had a statistically significant effect on the incidence of CRF. After 10 years in the UKPDS trial, less than 1% of participants in either the tight or the loose glycemic control arms had developed CRF.^ 30 ^

#### Use of ACE inhibitors or ARBs

Three well-conducted meta-analyses^79-81^ and 8 more recent RCTs^82-89^ examined the effectiveness of interruption of the renin-angiotensin system in reducing albuminuria and CRF among people with DM-2. All found that either ACE inhibitors or ARBs reduced the development and progression of albuminuria, with an effect greater than that for other antihypertensives. Two of these studies, both involving diabetics with macroalbuminuria, found a reduction in CRF in patients taking ARBs compared with placebo.^83,84^ In the other trials, the number of participants developing CRF over the time of the trials was low.

One RCT among people with type 1 diabetes reported a decrease in CRF among those receiving ACE inhibitors.^ 90 ^ A meta-analysis of RCTs among nondiabetics with proteinuric renal disease reported similar findings.^ 91 ^

#### Summary

Few people have macroalbuminuria at either screening or clinical diagnosis. Among the great majority without macroalbuminuria, CRF is rare for more than 15 years. Tight glycemic and blood pressure control and use of ACE inhibitors or ARBs reduce the development and progression of albuminuria; ARBs can reduce CRF among diabetics with macroalbuminuria. Whether any of these treatments, if started between screening and clinical diagnosis, which is a time when few diabetics have albuminuria, would have an important impact on the long-term incidence of CRF remains uncertain.

### Special Populations

More than 15 studies have consistently found that diabetic American Indians, blacks, and Hispanics in the United States have more than twice the incidence of macroalbuminuria and CRF that diabetic whites have.^ 92 ^ A higher rate of CRF would potentially mean a higher benefit from screening for these groups compared with white diabetics. The benefit of screening (ie, starting treatment at screening compared with clinical diagnosis), however, is as uncertain for these groups as it is for white diabetics.

## Lower Extremity Amputations

Diabetes affects the lower extremities in 2 main ways. Diabetes affects peripheral nerves, causing pain and loss of sensation; it also promotes the development of peripheral vascular disease, thereby decreasing the ability to heal ulcers and fight infections in the feet. The loss of sensation and decreased vascular supply lead to foot ulcers and infections, which lead to amputation.

### Incidence and Prevalence

We sought data on the incidence and prevalence of diabetic distal sensory neuropathy (DSN), peripheral vascular disease (PVD), foot ulcers, and lower extremity amputation (LEA). No study provided evidence about the prevalence of any of these conditions at the time DM-2 would be detected by screening.

At clinical diagnosis, from 7%^ 93 ^ to 17%^ 94 ^ of diabetics have symptomatic DSN, and from 8%^ 95 ^ to 13%^ 57 ^ have lost one or more pulses in their feet. Ten years after clinical diagnosis, between 17% and 25% of people with DM-2 will have DSN from diabetes. Incidence varies with higher baseline levels of glycemia.^61,93,96^

No study provided information about the incidence or prevalence of foot ulcers after clinical diagnosis of diabetes; we assume that prevalence is low. Two studies of people with DM-2 of both short and long duration found an incidence of foot ulcers of 5% to 7% after 1 to 3 years of follow-up.^97,98^ Other studies estimate that about 15% of all diabetics will develop at least 1 foot ulcer during their lifetimes.^ 6 ^ A large historical cohort study found that about 15% of those with foot ulcers required some level of amputation over 3 years of follow-up.^ 97 ^

We uncovered no information on LEA prevalence at clinical diagnosis. One prospective and 1 historical cohort study found that the 20- to 25-year cumulative incidence of LEA is between 3% and 11%.^7,99^ This includes all types of LEA, about three-quarters of which are below the knee or lower.^ 7 ^ In the UKPDS cohort, between 1% and 2% of participants had had an amputation within 10 years. In the Wisconsin Epidemiologic Study of Diabetic Retinopathy (WESDR) population-based cohort, about 7% of those with short duration DM-2 had had an amputation within 14 years.^ 100 ^

### Treatments to Prevent Lower Extremity Amputation

Three types of treatments have been tested to reduce LEA: tight glycemic control (Evidence Table 3), tight blood pressure control (Evidence Table 4), and foot care programs (Evidence Table 5).

#### Tight glycemic and blood pressure control

The UKPDS tested the efficacy of tight glycemic^ 30 ^ and blood pressure control^ 31 ^ on LEA. Although the UKPDS reported a trend toward a lower incidence of amputations with both tight glycemic control and tight blood pressure control, the differences did not attain statistical significance (P = 0.099 for tight glycemic control and P = 0.17 for tight blood pressure control). Because the incidence of LEA was so low, the absolute differences were also low (0.6% difference for tight glycemic control and 1.3% for tight blood pressure control).

#### Foot care programs

A recent well-conducted systematic review examined the efficacy of foot care programs on the incidence of foot ulcers and amputations.^ 101 ^ Many of the studies had flaws such as too few participants or too brief an intervention. Two well-conducted trials have been reported: 1 in a primary care setting and the other of diabetics at high risk of foot ulcers. They found that intensive programs including patient education, special shoes, and health care interventions can reduce the incidence of both foot ulcers and LEAs by as much as 60%.^102,103^

#### Summary

In the first 10 years after the onset of DM-2, the incidence of LEA is low. LEA in diabetics occurs primarily as a later complication, related to the development of DSN and PVD, which themselves take time to develop. Although foot care programs, and perhaps tight glycemic and blood pressure control, may reduce LEA over the long term, it is not clear that implementation of these interventions during the time between screening and clinical detection would have a large impact on the later development of LEA.

### Special Populations

At least 2 well-conducted cohort studies^99,104^ and 2 cross-sectional studies^105-107^ found that the incidence of LEA is greater among black and American Indian diabetics than among non-Hispanic white diabetics. The data are less clear for other ethnic groups. Although the incidence of LEA is higher in these groups, the benefit of treatment between screening and clinical detection is as uncertain as it is for white diabetics.

## Cardiovascular Events

Many studies establish DM-2 as an important risk factor for CVD events, including myocardial infarction (MI) and thromboembolic stroke (cerebrovascular accident [CVA]). Although glucose may itself have some vascular toxicity, some of the increased CVD risk experienced by diabetics can be attributed to the association of DM-2 and IFG/IGT with traditional risk factors such as hypertension and dyslipidemia. New CVD risk factors (eg, small, dense low-density lipoprotein (LDL) particles, apolipoproteins (a) and (b), homocysteine, insulin, and both impaired fibrinolysis and hypercoagulability), as well as yet-undiscovered risk factors, may also contribute to the increased risk of those with DM-2. Thus, DM-2 is both an independent risk factor for CVD and also a marker of increased CVD risk from other risk factors.

### Incidence and Prevalence of CVD Events

The absolute prevalence of established CVD at screening or clinical diagnosis of DM-2 ranges from 8% to 23% depending on the presence of other CVD risk factors. The prevalence is 3% to 12% higher than among similar nondiabetics; people with IFG/IGT have an intermediate prevalence between diabetics and nondiabetics.

At least 14 prospective cohort studies have found that the risk of CVD events in diabetic men is about twice that in nondiabetics, even after adjusting for age, hypertension, dyslipidemia, and smoking.^8-16,18-21,108^ For women, the adjusted CVD risk among diabetics is perhaps fourfold that in nondiabetics.

The absolute excess CVD risk for diabetics compared with nondiabetics depends on the number of other CVD risk factors. It ranges from less than 5% over 10 years for those with few additional risk factors to 15% or more for those with several additional risk factors. The absolute excess CVD risk for those with IFG/IGT is about half that of people with DM-2, although whether this excess risk is independent of other risk factors is not clear.

The UKPDS provided information about the absolute CVD risk among a population-based cohort of newly clinically diagnosed diabetics.^ 30 ^ After excluding people with recent MI and current angina or congestive heart failure (CHF), the investigators found that between 14% and 18% of all other diabetics (median age, 53 years) had suffered an MI within 10 years, and that 5% to 6% had suffered a stroke. Between 10% and 12% had died from diabetes-related causes, primarily CVD events.

### Treatment to Prevent CVD Events

Three treatments to reduce the incidence of CVD events among diabetics have been studied with high-quality RCTs: tight glycemic control (Evidence Table 3), tight blood pressure control (Evidence Table 4), and treatment of dyslipidemia (Evidence Table 6).

#### Tight glycemic control

To date, no RCT has demonstrated a statistically significant reduction in CVD events from tight glycemic control.^30,109,110^ The UKPDS reported 3 key findings: (1) a reduction in both fatal and nonfatal MI (16.3% to 14.2%, for a relative risk [RR] of 0.84) of borderline statistical significance (P = 0.052); (2) a reduction in sudden death (1.6% to 0.9%, RR = 0.54, P = 0.047, with a P value of < 0.01 required for statistical significance); and (3) no reductions in stroke (RR = 1.11, P = 0.52), heart failure (RR = 0.91, P = 0.52), or angina (RR = 1.02, P = 0.91).^ 30 ^

#### Tight blood pressure control

Nine recent RCTs have examined various aspects of the treatment of hypertension among people with DM-2. As a whole, they have shown that:

- An aggressive approach to blood pressure control among diabetics reduces CVD events by a relative 50% or more. In the Hypertension Optimal Treatment trial, the absolute risk reduction was 24.4 vs 11.9 events per 1,000 patient-years, P = 0.005; the number needed to treat (NNT) for 3.8 years was 80. The target blood pressure should be even lower than that for nondiabetics.^31,32^
- Treatment of isolated systolic hypertension among older diabetics reduces CVD events by a relative 34% to 69%.^111,112^
- Treatment of diabetics with at least 1 other CVD risk factor (whether or not they have hypertension) with ramipril reduces CVD events by a relative 22% and all-cause mortality by a relative 16%.^ 34 ^
- ACE inhibitors may reduce CVD events more than other antihypertensives,^113-115^ although 1 trial found no difference between treatment with an ACE inhibitor and a beta blocker.^ 87 ^ A more recent study found that diabetics (but not nondiabetics) achieved more benefit from an ARB than a beta blocker.^116,117^

#### Lipid control

Four secondary prevention trials of treating lipids had enough diabetics to permit subgroup analyses. Three used HMG co-A reductase inhibitors (statins);^118-121^ 1 tested gemfibrozil.^ 122 ^ In each case, lipid treatment reduced the incidence of coronary heart disease (CHD) events by about the same relative percentage among diabetics as among nondiabetics and those with IFG/IGT. The relative risk reduction ranged between 19% and 42%. In a pooled study of the results of 2 secondary prevention trials^120,121^ that used the same drug (pravastatin) found that, among participants with an initial LDL level of 125 mg/dl or less, diabetics had a greater benefit from pravastatin treatment than nondiabetics.^ 123 ^

No primary prevention trial of lipid therapy has included sufficient numbers of diabetics to perform reliable analyses, although trends in these trials are also in the direction of benefit.^ 124 ^ In a small primary prevention trial, Elkeles et al found a statistically significant 16% absolute reduction in definite CHD events (an endpoint combining MI and ischemia) between diabetics assigned to bezafibrate and those given placebo.^ 125 ^

Aspirin treatment also reduces CHD events among people with diabetes to the same degree as among nondiabetics.^126-128^

#### Summary

The absolute incidence of CVD events among newly clinically diagnosed diabetics is more than 15% after 10 years, higher for those with additional risk factors and lower for those with fewer risk factors. This rate is substantially higher than the rate for nondiabetics at the same risk factor level. Whether tight glycemic control will lower this incidence is not clear.

Some evidence suggests that tight blood pressure control with a target diastolic pressure of 80 mm Hg, probably using an ACE inhibitor or an ARB, reduces event rates by approximately a relative 50%. Further, knowing whether a person has diabetes is important in determining CHD risk. Treating persons at higher CHD risk, including diabetics, for dyslipidemia is both effective and cost-effective.^ 129 ^

Table 3 provides 5-year NNS calculations to prevent 1 CVD event by screening people with hypertension for diabetes. Assuming a 7.5% 5-year risk of a CVD event and a 50% relative risk reduction from tight blood pressure control, the NNS is about 500 (Table 3, Case 1). If only 50% of diabetic hypertensives detected by screening actually receive tight blood pressure control as a result of diabetes screening, the NNS is about 900 (Case 2, middle example).

Even with less optimistic assumptions (Cases 3 and 4), the NNS calculations for preventing 1 CVD event are still lower than those for preventing blindness in 1 eye (from Table 2). Moreover, the initial assumptions for the CVD calculations are more secure and based less on extrapolation than those in the blindness example.

### Special Populations

Data are not clear about the relative prevalence and incidence of CVD in diabetic black, Hispanic, and American Indian groups compared with diabetic non-Hispanic whites.^ 130 ^ Some American Indian groups may have lower incidence, but other American Indian groups may have higher incidence.^131,132^ Thus, no clear evidence exists at present to alter conclusions about screening to reduce CVD events because of membership in one of these population groups.

## Early Treatment of Impaired Fasting Glucose/Impaired Glucose Tolerance

Several observational studies have shown that people who develop DM-2 have potentially modifiable risk factors such as obesity and reduced physical activity.^133-140^ This has led clinicians to wonder whether lifestyle interventions at the IFG/IGT stage might reduce the incidence of DM-2 and thereby lower diabetes complications. If lifestyle modification (weight management, increased physical activity) in persons with IFG/IGT can reduce the progression to DM-2, an additional argument for screening would be to detect persons at this stage who could benefit from interventions. A potentially large group might benefit; NHANES III found that 6.9% of adults ages 20 and older met criteria for IFG and 15.8% met criteria for IGT. What is unclear is whether lifestyle interventions in this group are effective.

Three well-conducted RCTs of lifestyle interventions have been reported (Evidence Table 7).^141-143^ A large 6-year study from China (the Da Qing trial) reported a 20% absolute reduction in progression from IGT to DM-2.^ 141 ^ Two large RCTs are most relevant for this discussion. One from Finland found that an intensive lifestyle change program reduced the development of DM-2 by 58% over 3.2 years.^ 143 ^ A similar trial in the United States found the same relative risk reduction from an intensive lifestyle change program; in a group assigned to the drug metformin, the relative risk reduction was 31%.^ 142 ^ A small RCT (with appreciable attrition) from the United Kingdom found no change in lifestyle and no change in progression to DM-2.^ 144 ^

Two other RCTs have found that ACE inhibitors reduced the development of DM-2 in populations at increased CVD risk;^89,145^ another found the same result in hypertensive patients.^ 113 ^ The absolute reductions were small: 0.8% in one trial and 1.6% in the other. Two other trials found small reductions in the incidence of DM-2 among people taking losartan (an ARB) compared with atenolol (a beta blocker)^ 116 ^ and among people with high CVD risk taking pravastatin compared with placebo.^ 146 ^ A drug trial of acarbose to reduce the progression from IGT to DM-2 is in progress.^ 147 ^

In summary, lifestyle modification and/or drugs can reduce the incidence of DM-2, although the degree to which this reduces diabetic complications (i.e., health outcomes) is uncertain. The cost-effectiveness of intensive lifestyle change programs is also untested.

## Harms of Screening and Treatment

Screening for DM-2 could cause harm in at least 2 ways. One is by labeling people unnecessarily, thus causing anxiety and a change in self-perception. Another is by subjecting people to a potentially harmful treatment for a longer time.

We found no studies of the psychological effects of being diagnosed with diabetes by screening. Nevertheless, adverse effects of labeling remain a potential problem. For example, false-positive screening tests could contribute to psychological distress.^50,148-152^ In addition, between 30% and 50% of those labeled as having IGT will revert to normal glycemia without developing DM-2.^153-159^

On the whole, treatments for diabetes are relatively safe (Evidence Table 8). Tight glycemic control at a time when glycemic levels are relatively low (ie,, the time between screening and clinical diagnosis) can induce hypoglycemia; in the UKPDS, 2.3% of people on insulin suffered a major hypoglycemic episode each year, as did 0.4% to 0.6% of those on oral hypoglycemics.^ 30 ^ ACE inhibitors^ 160 ^ and statins^161,162^have reasonably low levels of serious adverse effects.

The impact of diabetes treatment on quality of life has been a concern. Three RCTs indicate, however, that better glycemic control actually improves quality of life.^30,163-165^

In short, despite the potential for newly screen-detected diabetics to be harmed by labeling or earlier treatment (or both), the magnitude of this problem is unclear. Among those who have symptomatic hyperglycemia, which may include few people detected by screening, better glycemic control improves quality of life.

## Costs and Cost-Effectiveness of Screening and Earlier Treatment

In a clinically diagnosed group of diabetics, diabetes-associated incremental costs are evident from the first year and may average $2,000 to $3,000 per person annually.^ 166 ^ Intensive treatment will cost more.^ 167 ^ Cardiovascular and renal complications increase costs by a factor of 3 to 7^ 168 ^ (Evidence Table 9).

We found 1 modeling study of the cost-effectiveness of screening for DM-2 in the United States.^ 167 ^ The model assumed that screening allows an additional 5.5 years of tight glycemic control and that the effect of this treatment would be seen only in reduction of eye, kidney, and lower extremity complications. The risk of these complications was taken from the body of literature reviewed in this systematic review; risk reduction was extrapolated from the major study of glycemic control for type 1 diabetics.^ 71 ^ Glycemic control after diagnosis in both screened and unscreened modeling groups was assumed to be similar to the level for the UKPDS diet-control group rather than the level for the intensive-control group.

The cost-effectiveness of one-time screening varied by age and ethnic group. Cost per quality-adjusted life year (QALY) gained for persons ages 25 to 34 was $13,376 for whites and $822 for African Americans; for persons in the age range 55 to 64 years, the figures were $116,908 for whites and $70,759 for African Americans. This differential by age reflects the extrapolation that tight glycemic control needs to be applied for some years before it reduces visual impairment or CRF. Sensitivity analyses found that cost-effectiveness ratios triple if the preclinical period is cut in half or if intensive rather than loose glycemic control is instituted at diagnosis.

The prevalence of undiagnosed DM-2 is low in younger age groups (eg, 0.6% of those ages 20 to 39 years).^ 25 ^ For this reason, a strategy of screening younger people would detect relatively few of the people destined eventually to develop DM-2.

Diabetes care, especially intensive glycemic control and the care of complications, is expensive. According to one modeling study, screening younger people was more cost-effective than screening older people, and screening African Americans was more cost-effective than screening whites. This study extrapolated benefits from studies showing that tight glycemic control effectively reduces intermediate outcomes (eg, retinopathy and albuminuria) rather than health outcomes (eg, severe vision impairment and CRF). It also found that if the preclinical period were shorter than assumed, or if intensive glycemic control were instituted at diagnosis (whether screening or clinical), then cost-effectiveness would be considerably worse. Finally, this study did not consider any benefits of earlier, more intensive treatment of CVD risk factors.