# Introduction

The burden of suffering caused by type 2 diabetes mellitus (hereafter DM-2) is enormous. Studies in the United States have shown that nearly 10% of people who have had DM-2 for 20 years or longer are legally blind.^1,2^ About 25% of diabetics over the age of 18 report some difficulty with vision.^ 3 ^ About 33% of people undergoing renal replacement treatment (ie, dialysis or transplant) have end-stage renal disease primarily attributable to diabetes,^ 4 ^ about half of these due to DM-2.^ 5 ^ About half of all lower extremity amputations in the United States occur in diabetics.^6,7^ The risk for cardiovascular disease (CVD), including both coronary heart disease (CHD) and stroke (cerebrovascular accident [CVA]), is 2 to 4 times greater in diabetics than nondiabetics with the same age and CVD risk status.^8-21^ Diabetics report 2 to 3 times more activity limitations than nondiabetics.^ 22 ^

In addition to these real human costs, in 1997 the US health care system spent some $98 billion on medical care and lost productivity for people with diabetes. Per capita medical costs for diabetics were nearly 4 times those for nondiabetics.^ 23 ^

The incidence and prevalence of DM-2 in the United States are increasing.^24-28^ Based on national data from the National Health and Nutrition Examination Survey (NHANES III, 1988-1994), the prevalence of diabetes (both diagnosed and undiagnosed) among people ages 40 to 74 years (the great majority of whom have DM-2) increased from 8.9% for the period 1976 to 1980 to 12.3% for the period 1988 to 1994.^ 25 ^

National data have demonstrated convincingly that many people who satisfy the criteria for DM-2 have not been diagnosed and are thus not under medical care for this condition. For example, NHANES-III found that 5.3% of the adult population ages 20 and older had been previously diagnosed with diabetes but that another 2.8% had not been diagnosed and yet met diagnostic criteria.^25,29^ Such data, combined with new information from randomized controlled trials (RCTs) of treatment of people with DM-2, have raised the question of whether screening and early treatment would reduce the burden of suffering caused by this condition.

For screening to be effective in decreasing the complications of DM-2, we must first demonstrate the existence of a detectable preclinical period and of acceptable and accurate screening tests to detect the disease during that period. The efficacy of treatments for patients with existing disease is well established.^30-34^ Screening is justified only if it offers incremental benefit beyond this level of efficacy (see Figure 1, the "delta question" diagram). Specifically, do treatments started at screening diagnosis reduce the incidence of complications (Line C, Figure 1) below that which would be expected with customary clinical detection (Line B)? The "delta" (i.e., difference between lines B and C) is the reduction in the incidence of complications achieved by starting earlier rather than later. Finally, we must also show that the inevitable harms and financial costs associated with screening and earlier treatment are small enough that they do not outweigh the benefits of earlier treatment.

Figure 1. The "Delta Question" in Screening for Types 2 Diabetes

In its review of this topic in 1996, the US Preventive Services Task Force (USPSTF) concluded there was "insufficient evidence to recommend for or against routine screening for diabetes mellitus in asymptomatic adults."^ 35 ^ The Task Force cited the lack of a practical, accurate screening test and insufficient evidence that detection of diabetes in the asymptomatic period significantly improves long-term outcomes.

In a 2002 policy statement, the American Diabetes Association indicated that screening every 3 years should be considered for all people beginning at age 45 and for younger people with such risk factors as family history, overweight, minority race or ethnicity, previously identified impaired fasting glucose or impaired glucose tolerance, hypertension, high density lipoprotein cholesterol 35 mg/dl or less, or history of gestational diabetes or delivery of a baby weighing more than 9 pounds.^ 36 ^