# Appendix B. Evidence Tables

Evidence Table 1. Properties and Yield of Screening Tests

Source Author, Year | Study Population | Measurements | Results | Quality
Olefsky JM et al., 1974^ 50 ^ | N: 31 (adult volunteers) | FPG 2-hour PG (each repeated for each participant, 48 hours apart) | 9 of 31: FPG deviated by > 10%, but none by > 30% 17 of 31: 2-hour PG deviated by > 10% and 3 deviated by > 30% | Greater variability in 2-hour PG than in FPG Quality: Fair
Blunt BA, et al., 1991^ 48 ^ | N: 1,851 men and women Design: Cross-sectional, population-based | FPG 2-hour PG | For gold standard of 2-hour PG > 200 mg/dl: FPG, cutpoint 121 mg/dl Sensitivity: 65.6% (ages 50-64) Sensitivity: 40% (ages 65-70) Specificity:> 95% (both ages) | FPG less sensitive for detecting 2-hour PG > 200 mg/dl in older age groups Quality: Good
McCance DR, et al., 1995^ 171 ^ | N : 960 Pima Indians Ages : 25+ Design : Cross-sectional and longitudinal Not receiving drugs for diabetes | FPG 2-hour PG Hb A1c Direct opthalmoscopy through dilated pupils | For detecting retinopathy: FPG, cutpoint 122 mg/dl Sensitivity: 81.2% Specificity: 77.1% 2-hour PG, cutpoint 200 mg/dl Sensitivity: 87.5% Specificity: 75.8% HbA1c, cutpoint 6.1% Sensitivity: 81.3%KB. Specificity: 76.8% | Also found threshold for predicting 5-year incidence of retinopathy Quality: Good
Mooy JM, et al., 1996^ 150 ^ | N: 246 (with NGT), 198 (with IGT), 80 (with new-DM) Ages: 50-74 Design: Hoorn Study, population-based, prospective cohort | Repeated FPG and 2-hour PG in same individuals | Intra-individual variation: [standard deviation of test-retest difference (mg/dl)]: | Variation greater for 2-hour PG than for FPG Variation greater for new-DM and IGT than for NGT Quality: Good
  | FPG | 2-hour PG
  NGT | 7.2 | 23.4
  IGT | 9.0 | 32.4
  New-DM | 12.6 | 41.4
Engelgau MM, et al., 1997^ 41 ^ | N: 1,018 Egyptians Ages: 20+ Design: Cross-sectional, population-based Examination of people with capillary blood glucose > 100 mg/dl, diabetic and nondiabetic | FPG 2-hour PG Hb A1c Retinal photograph | For detecting retinopathy (excludes those with diabetes): FPG, cutpoint 125 mg/dl Sensitivity: 84% Specificity: 77% 2-hour PG, cutpoint 200 mg/dl Sensitivity: 86% Specificity: 78% Hb A1c, cutpoint 6.4% Sensitivity: 80% Specificity: 74% | ROC curves very similar for all 3 tests 30 % non-response Quality: Fair
Expert Committee on Diagnosis and Classification of Diabetes Mellitus, 1997^ 42 ^ | N: 2,821 Ages: 40-74 Design: NHANES III, cross-sectional | FPG 2-hour PG Hb A1c Retinal photograph | Exact sensitivity and specificity not given All 3 tests very similar by graph | Personal communi-cation in another report Quality: Fair
Harris MI et al., 1997^ 29 ^ | N: 2,844 (no diagnosed diabetes) Ages: 40-74 Design: NHANES III, cross-sectional, population-based | FPG 2-hour PG | For 2-hour PG > 200 mg/dl as reference standard for diagnosing diabetes, probability of diabetes given following FPG: > 140 mg/dl=91% 126-139 mg/dl=47% 110-125 mg/dl=18% <110 mg/dl =1.6% | 2-hour PG > 200 classifies more people as diabetic than FPG > 126 mg/dl 2-hour PG 140-199 classifies more people as IGT than FPG 110-125 classifies as IFG Quality: Good
Bjornholt JV, et al., 1999^ 44 ^ | N: 1,973 (healthy nondiabetic men) Ages: 40-59 Design: Population-based, prospective cohort (22 years followup) | Fasting blood glucose | Men in highest fasting blood glucose quartile (> 85 mg/dl) had higher CVD mortality than those in lower three quartiles, independent of major CVD risk factors, (RR=1.4 [1.04-1.8]) Non-CVD deaths were unrelated to blood glucose | Quality: Good
Coutinho M, et al., 1999^ 43 ^ | N: 20 studies including 95,783 persons followed an average of 12.4 years Design: Meta-regression analysis All persons nondiabetics | FPG 2-hour PG | Exponential relationship between either FPG or 2-hour PG and CVD events beginning far below diabetes cutpoint | Could not adjust for other CVD risk factors, thus uncertain if CVD risk is independent Quality: Fair
Khaw KT, et al., 2001^ 47 ^ | N: 4,662 men Ages: 45-79 Design: Population-based, prospective cohort (2-4 year followup) | Hb A1c CVD events CVD Mortality All-cause mortality | Hb A1c continuously associated with all-cause and CVD mortality throughout the entire population distribution of Hb A1c down to 5% Increase of 1% in Hb A1c associated with a 28% increase in risk of death independent of other CVD risk factors | Quality: Good
Rolka DB, et al., 2001^ 54 ^ | N: 1,471 volunteers Ages: 20+ Design: Cross-sectional Recruited during routine health center visits and at community health fairs | FPG 2-hour PG Random capillary blood glucose ADA screening questionnaire (7 items) | For detecting either FPG > 126 or 2-hour PG > 200 mg/dl: CBG (> 120 mg/dl) Sensitivity: 75% Specificity: 88% | Questionnaire much less sensitive Quality: Fair
Saydah SH, et al., 2001^ 46 ^ | N: 3,174 adults Ages: 30-75 Design: NHANES II followup study, prospective cohort (12-16 years followup) | FPG 2-hour PG All-cause mortality CVD mortality | Using normal glucose tolerance as referent group: Multivariate adjusted RR for all-cause mortality: - Abnormal glucose tolerance: 1.42 (1.08=1.87) - Undiagnosed diabetes: 1.77 (1.13-2.75) - Diagnosed diabetes: 2.11 (1.56-2.84) - (Similar trend for CVD mortality) | FPG and 2-hour PG both used in constructing categories Quality: Good

Evidence Table 2. Studies of Laser Photocoagulation

Source: Author, Year | Study Population: Selection/Randomization | Study Population: Description | Time Frame | Interventions/Co-Interventions | Measurements: Exposures and Outcomes | Attrition: Loss of Follow-Up | Results | Conclusions | Comments/Quality Issues
The Diabetic Retinopathy Study Research Group, 1981^ 172 ^ | Selection: Clinic-based multi-center trial; US Randomization: One eye randomly assigned to photocoagulation and the other eye no treatment Inclusion: Severe non-proliferative diabetic retinop. in both eyes or PDR in one eye and visual acuity of 20/100 or better in each eye | | Start: 1971 F/u: 1976 5-yr f/u | Interventions: Photocoagulation: xenon arc and argon laser (direct and scatter) | Exposures: Diabetes mellitus with varying degrees of retinopathy Outcomes: Severe visual loss: visual acuity <5/200 at 2 consecutive visits (inability to read top line of Snellen chart at distance of 5 feet) Measurements: Fundus photographs graded according to modified Airlie House Classification scheme, Snellen chart Blinding: Visual acuity measured by masked examiners | Loss to f/u: None | Intention to Treat: Cumulative Incidence of severe visual loss in eyes with severe retinopathy P < .001 | This 5-yr study demonstrated a 50% reduction in severe visual loss in eyes with severe retinopathy treated with photocoagulation | Limitations: Clinic-based Comments (Harms): Decrease in visual field in 25% xenon-treated eyes vs. 5% argon-treated Decrease in visual acuity of two or more lines: 11% xenon-treated eyes; 3% argon-treated eyes. Also, some decrease in dark adaptation Quality: Good
  Baseline: 1,742
  1-yr f/u: | 1,624
  3-yr f/u: | 1,187
  5-yr f/u: | 519
  Age:
  20-29 yrs: | 23%
  30-39 yrs: | 17%
  40-49 yrs: | 18%
  50-59 yrs: | 27%
  Gender:
  Male: | 56%
  Ethnicity:
  White: | 94%
  | 3-yr f/u | 5-yr f/u
  Treated: | 9% | 13%
  Control: | 21% | 32%
Early Treatment Diabetic Retinopathy Study, 1985,^ 173 ^ 1987,^ 69 ^ 1991^ 174 ^ | Selection: Clinic-based multi-center trial Randomization: One eye randomly assigned to immediate photocoagulation and the other eye to deferral Inclusion: Mild-to severe nonproliferative retinop. or early PDR with or without diabetic macular edema | | Start: 1980-1985 F/u: 1990 5-yr f/u | Interventions: Photocoagulation: immediate and deferred | Exposures: Diabetes mellitus with varying degrees of retinopathy Outcomes: Moderate visual loss: loss of 15 or more letters (3 or more lines) on the visual acuity chart Severe visual loss: visual acuity <5/200 at 2 consecutive visits Measurements: Fluoroscein angiograms, fundus photographs graded according to modified Airlie House Classification scheme, and best-corrected visual acuity Blinding: Masked treatment assignment | Loss to f/u: 164 lost to f/u, 706 died, 34 vital status unknown | Intention to Treat: Cumulative incidence of severe visual loss 5-yr f/u: Early photocoag 2.6% Deferral of photocoag 3.7% (NS) (For patients with only mild-moderate nonproliferative retinopathy, rates of severe visual loss were even lower) 3-yr f/u: Cumulative incidence of loss of visual acuity (doubling of visual angle) in eyes with mild-moderate nonproliferative retinopathy and macular edema: Immediate tx: 12% Deferred tx: 30% | For eyes with mild to moderate nonproliferative retinopathy treated with early photocoagulation, the rates of severe visual loss were low and were not significantly different from the deferred eyes Any reductions in the incidence of visual loss were not sufficient enough to compensate for side effects of early photocoagulation Immediate photocoagulation best for eyes with macular edema that involves or threatens the center of the macula | Limitations: Clinic-based Comments: Embedded aspirin component showed no eye benefit, but reduced CVD events by 17% Quality: Good
  Baseline: 3,711
  1-yr f/u: | 3,600
  3-yr f/u: | 3,300
  5-yr f/u: | 2,200
  Age:
  < 50 yrs: | 48%
  > 50 yrs: | 52%
  Gender:
  Male: | 56%
  Ethnicity:
  White: | 76%

Evidence Table 3: Studies of Tight Glycemic Control

Study Population (Quality) | Study Years | Groups N | Glycemic Control | Renal Failure | Severe Visual Impairment | Myocardial Infarction | Stroke | Amputation | All-Cause Mortality
UGDP, 1971^ 175 ^; 1978^ 176 ^ (fair) | 8.75 | Placebo: 204 | 22.8% increase** | NR | Acuity<20/200 either eye 11.2% | Significant ECG abnormality 20% | NR | 1.5% | 26.3%
UGDP, 1971^ 175 ^; 1978^ 176 ^ (fair) | 8.75 | Insulin variable: 198 | 13.5% decrease** | NR | 11.4% (NS) | 17.6% (NS) | NR | 1.6% (NS) | 24.0% (NS)
UKPDS 33, 1998^ 169 ^ (good) | 10 | Conventional: 1,138 | 7.9%† | < 1% (P = 0.45) | Vision too poor to drive 11% | 16.3% (P = 0.052) | 4.8% (P = 0.52) | 1.6% (P = 0.15) | 18.7% (p=0.44)
UKPDS 33, 1998^ 169 ^ (good) | 10 | Intensive: 2,729 | 7.0%† | < 1% | 11% | 14.2% | 5.4% | 1.1% | 17.9%
UKPDS 34, 1998^ 177 ^ (good)* | 10.7 | Conventional: 411 (primarily diet) | 8.0%† | < 1% (P = 0.90) | Blind in one eye 3.2% (P = 0.87) | 17.8% | 5.6% | 2.2% (P = 0.57) | 21.7%
UKPDS 34, 1998^ 177 ^ (good)* | 10.7 | Intensive: 342 (metformin) | 7.4%† | < 1% | 3.5% | 11.4% | 3.5% | 1.8% | 14.6%
Kumamoto, 1995^ 178 ^; 2000^ 179 ^ (fair) | 6 | Conventional: 50 | 9.4%† | NR | NR | Major CVD event 1.3 events/100 p-y | | | NR
Kumamoto, 1995^ 178 ^; 2000^ 179 ^ (fair) | 6 | Intensive: 52 | 7.1%† | NR | NR | 0.6 events/100 p-y (NS) | | | NR
VA CSDM, 1997^ 180 ^; 1995^ 181 ^; 1999^ 182 ^; 2000^ 183 ^ (fair) | 2.25 | Standard group: 78 | 9.2%† | NR | Unilateral or bilateral visual impairment 9% | 5.1% | 2.6% | 0 | 5.1%
VA CSDM, 1997^ 180 ^; 1995^ 181 ^; 1999^ 182 ^; 2000^ 183 ^ (fair) | 2.25 | Intensive group: 75 | 7.1%† | NR | 6.7% (NS) | 6.7% (NS) | 6.7% (NS) | 1.3% (NS) | 6.7% (NS)
Steno 2, 1999^ 184 ^ (fair) | 3.8 | Standard: 80 | 9.0%† | 0 | Blind in one eye 9.0% | Nonfatal 5.1% | Nonfatal 10.2% | 5.1% | 2.6%
Steno 2, 1999^ 184 ^ (fair) | 3.8 | Intensive: 80 | 7.6%† | 0 | 1.3% (P = 0.03) | 5.2% (NS) | 1.3% (NS) | 5.2% (NS) | 5.2% (NS)

NR = Not reported

** = change in fasting blood glucose from baseline

^†^ = Median hemoglobin A1C

UGDP= University Group Diabetes Program

UKPDS= UK Prospective Diabetes Study Group

Steno = Steno type 2 randomized study

VA CSDM = VA Cooperative Study on Glycemic Control and Complication in Type 2 Diabetes

Evidence Table 4. Studies of Antihypertensive, ACE Inhibitors and ARB Medications

Study Population | Study Years Age | Groups N | BP Control | MI | Stroke | CVD Events Mortality | Non-CVD Outcomes | Adherence Withdrawal | Blinding Comments Quality
| | | | | | CVD death: | | D/C study drug:
Estacio et al., 1998^ 185 ^ ABCD | 5 57 | | 135/82 135/82 | 10.6% 2.1% P = 0.001 | 4.7% 3.0% NS | 4.3% 2.1% NS | No difference vision, ESRD | 39.1 % 34.9% | Double-blind MI a secondary endpoint Quality: Fair
  Nisoldipine | 235
  Enalapril | 235
| | | | | | CVD mortality*: | | % DBP > 90:
Hansson et al., 1998^ 170 ^ HOT | 3.8 61.5 | | 144/85 141/83 140/81 | 7.5* 4.3 3.7 P = 0.11 | 9.1 7.0 6.4 P = 0.34 | 11.1 11.2 3.7P = 0.016 | NR | 12% 7% 6% 2.6% study withdrawal | Open label Quality: Fair
  < 90** | 501
  < 85 | 501
  > | 80 499
| | | | | | Major CVD event: | | D/C study drug:
Tatti et al., 1998^ 186 ^ FACET | 2.8 62-63 | | 157/88 153/86 | 1.8% 2.4% P = 0.1 | 0.7% 1.9% P >0.1 | 2.6% 5.0% P = 0.03 | NR | 19.0% 27.2% | Open Label Quality: Fair
  Fosinopril | 189
  Amlodipine | 191
| | | | | | DM related death: | ESRD:
UKPDS-38, 1998^ 187 ^ | 8.4 56-57 | | 154/87 144/82 | 23.5 18.6* P = 0.13 | 11.6 6.5* P = 0.013 | 20.3 13.7* P = 0.019 | 2.3 1.4* P = 0.29 Vision: 19.4% 10.2% P = 0.004 | No drug 43% p−y+ Took drug 77% p−y+ 4% study withdrawal | Open label Randomization by sealed envelopes Quality: Fair
  Less tight | 390
  Tight | 758
| | | | | | DM related death: | | D/C study drug:
UKPDS-39, 1998^ 188 ^ | 8.4 56 | | 144/83 143/81 | 20.2 16.9 P = 0.35 | 6.8 6.1 P = 0.74 | 15.2 12.0 P = 0.28 | No difference vision, ESRD | 22% 35% Took study med: Captopil 80% Atenolol 74% p−y+ | Open Label Quality: Fair
  Captopril | 400
  Atenolol | 358
| | | | | | All cause:
CAPPP, 1999^ 189 ^; 2001^ 190 ^ | 6.1 55-56 | | 155/89 153/88 | 3.9% 10.3% P = 0.002 | 7.4% 7.2% P = 0.96 | 6.5% 12.9% P = 0.034 | NR | One patient lost to follow-up; compliance with meds not given | Open Label Quality: Fair
  Captopril | 309
  Conventional 263
| | | | | | CVD events: | | D/C study drug:
Brown et al., 2000^ 191 ^ INSIGHT | 4 65 | Nifedipine 649 Co-amilozide 653 | 138/82 138/82 | NR | NR | 8.3% 8.4% | NR | 33.1% 39.9% 2.4% withdrew from study | Double-blind Randomization Imbalance in DM-2 Quality: Fair
| | | | | | All-cause mortality:
Estacio et al., 2000^ 192 ^ ABCD | 5 57 | | 138/86 132/78 | No difference | No difference | 10.7% 5.5% P = 0.037 | No difference vision, ESRD, neuropathy | Participants on study drug ~70% of time. | Open label Quality: Fair
  Moderate | 233
  Intensive | 237
| | | | | | CVD events: | | On drug at end:
Hansson et al., 2000^ 193 ^ NORDIL | 4.5 60-61 | | 152/88 149/87 | 11.2* 11.1 P = 0.99 | 13.3* 12.3 P = 0.97 | 29.8* 27.7 P = 0.98 | NR | 77% 93% <1% withdrawal from study | Open Label Quality: Fair
  Diltiazem | 351
  Diuretics and/or Beta blockers 376
| | | | | | All cause: | | On drug at end:
Lindholm Hansson et al., 2000^ 194 ^ STOP-2 | 5.3 75-76 | | 161/80 162/79 161/81 | 15.3* 29.6 P = 0.025 22.2 | 31.6* 26.9 34.7 P = 0.36 | 49.0* 43.9 55.5 P = 0.20 | NR | ACEI : 61.3% CA: 66.2% D/ß: 62.3% Study Withdrawal:0% | Open Label For all participants, CHF and MI lower for ACE than CA group Quality: Fair
  ACEI | 235
  CA | 231
  Conventional 253 (D/ß)
| | | | | | All-cause mortality: | ESRD: | Discontinued Treatment:
Brenner et al., 2001^ 84 ^ RENAAL | 3.4 60 | | 140/74 142/74 P = 0.59 | 6.7% 8.9% RRR: 28% P = 0.08 | NR | 6.8* 6.6* NS | 6.8* 9.1* RRR: 28% P = 0.002 | 46.5% 53.5% | Double-blind Randomized Quality: Good
  Losarton | 751
  Placebo | 762
| | | | | | CV outcome‡: | | Renal outcome†:
Lewis et al, 2001^ 195 ^ | 2.6 58-59 | | 140/47 141/77 144/80 | NR | NR | 23.8 22.6 25.3 (NS) | | <1% study withdrawal | Double-blind Randomized by central office Quality: Good
  Irbesartan | 579
  Amlodipine | 567
  Placebo | 569
  32.6% 41.1% 39.0% | }P = 0.006 }P = 0.02
| | | | | | All-cause mortality: | Diabetes: | Dropout:
Dahlof et al., 2002^ 116 ^ LIFE | 4 66.9 | | 144/81 145/81 | 9.2* 8.7* NS | 10.8* 14.5* P = 0.001 | 17.3* 19.6* P = 0.128 | 13.0* 17.4* P = 0.001 | 105 pts 92 pts | Double-blind Randomized Quality: Good
  Losartan | 4,605
  Atenolol | 4,588
| | | | | | All-cause mortality: | Renal Outcome†: | Dropout:
Lindholm et al., 2002^ 117 ^ LIFE (diabetics only) | 4 67.4 | | 146/79 148/79 | 15.2* 18.7* P = 0.373 | 19.0* 24.5* P = 0.0204 | 22.5* 37.2* P = 0.002 | No difference | 32 pts 36 pts | Double-blind Randomized Quality: Good
  Losartan | 586
  Atenolol | 609

* indicates events per 1,000 person - year;

‡, MI, stroke, cardiovascular death, amputation, congestive heart failure;

†, doubling of creatinine, end-stage renal disease, any death

Evidence Table 5. Studies of Foot Care

Source Author, Year | Study Population: Selection & Description | Intervention/Co-Interventions | Outcomes | Results | Quality Considerations And Comments
Malone et al., 1989^ 102 ^ | US Clinic-based Randomization: Randomized: 227 Did not fit criteria: 24 Included: 203 Incidence of prior distal vascular reconstruction higher in control group (NS) Incidence of foot callous was significantly higher intervention group P< 0.05 Inclusion: NIDDM patients with uninfected foot ulcers or prior amputation in VA hospital Exclusion: Patients requiring wound debridement, formal incision and drainage of foot infections, amputation, or vascular reconstruction until after definitive surgical tx | Intervention: 1-hour education class including a simple set of patient instructions for the care of the diabetic foot | Success defined as the continued absence of foot infections, ulceration, or foot or leg amputation | Results of diabetic education program | Statistical analysis: Student's t-test Attrition: 21 patients died (13 in intervention, 8 in control) Quality: Fair
  | Education | No education
  Success | 90% | 72%
  Failure:
  Infection | 1% | 1%
  Ulcer | 5% | 15%
  Amputation | 4% | 12%
Litzelman et al., 1993^ 103 ^ | US Clinic-based Eligible: 728 Agreed to participate: 484 Assessed: 395 Completed: 352 Randomization: Randomly assigned 2 primary care teams to intervention, 2 to control. Intervention group had higher Hb A1C values than controls No differences found on other characteristics Inclusion: NIDDM, seen 2 times in preceding year by same provider; age >40 yrs; dx of diabetes >30 yrs; presence of disease requiring medication for control of hyperglycemia, intention to obtain care at practice for next 2 years, and body weight either ideal or heavier than usual Exclusion: Pregnancy; major psychiatric illness, including dementia; terminal illness likely to cause death in 1 year; renal failure; previous bilateral amputations above/below the knee; or an inability to provide self-care | Patient: Education session covering appropriate foot-care behaviors and footwear Behavioral contracts Phone and postcard reminders Health care system: Colorful folders with foot decals to identify intervention patients Health care providers: Patient-specific risk factors Patient-specific practice guidelines Have patients remove footwear for foot exams | Musculoskeletal and dermatologic abnormalities assessed using standard definitions of findings such as callus, hammer toe, and charcot foot Foot lesions defined as any wound, with or without functional interruption of the protective cutaneous barrier, ranging from a superficial scratch to an ulcer involving epidermis Serious foot lesion defined in standard way using Seattle wound classification system, severity grade of 1.3 Pressure and temperature sensations measured using 5.07-log-force Semmes-Weinstein monofilament and thermal sensitivity testing apparatus, according to standard techniques Thermal sensitivity considered abnormal if value >2 standard deviations from the mean value for healthy persons without diabetes | Effect of interventions on patient outcomes: Effect of intervention on self-foot-care behaviors: Effect of intervention on physician documentation: | Statistical analysis: Variables adjusted for baseline measurements Standard analysis of covariance and logistic regression Attrition: 43 (11%) did not complete study for following reasons: death (11), change of residence (15), illness (6), transportation problems (3), and misc reasons (8) Quality: Good Limitations: Neither the sample size nor the length of f/u was adequate to show if interventions reduced incidence of lower extremity amputations
  | OR (95% CI) | P-value
  Serious foot lesions | 0.41 (0.16-1.00) | 0.05
  All foot lesions | 0.65 (0.36-1.17) | 0.15
  Interdigit maceration | 0.63 (0.34-1.15) | 0.13
  | OR*(95% CI) | P-value
  Inspect feet | 0.23 (0.12-0.42) | <0.01
  Inspect shoes | 0.64 (0.40-1.00) | 0.05
  Lubricate feet | 0.73 (0.44-1.22) | >0.20
  Dry between toes | 0.27 (0.19-0.75) | 0.01
  * OR < 1.0 means increased likelihood of behavior in intervention grp
  | Intervention | Control | P-value
  | (N=185) | (N=198)
  Ulcers | 23.8% | 11.1% | <0.01
  Pulse exam done | 9.2% | 3.0% | 0.01
  Dry/cracked skin | 8.7% | 2.0% | 0.01

Evidence Table 6. Studies of Lipid Control

Source Author, Year | Study Population | | | Intervention | Outcomes (Primary, Secondary) | Results | Comments Quality
Source Author, Year | Description | Size | Inclusion, Exclusion | Intervention | Outcomes (Primary, Secondary) | Results | Comments Quality
Elkeles RS et al., 1998^ 125 ^ (SENDCAP) | Mean age: 50-51 years 67-75% male BMI: 28-29 | 164 from diabetes clinics at 5 British hospitals | Inclusion: Type 2 diabetes Ages: 35-65 No history of CVD At least one: Total cholesterol > 200 Triglyceride > 160 HDL < 40 | RCT 81 bezafibrate (400 mg/day) vs. 83 placebo Followup: 3 years | Primary: Ultrasonography of arterial disease Secondary: Documented MI & ECG changes indicating ischemia | No difference between groups in ultrasound arterial disease Definite CHD events bezafibrate: 7% placebo: 23% P = 0.01 | Secondary endpoint Quality: Fair
LIPID Study Group, 1998^ 121 ^ | Volunteers at 87 Centers Median age: 62 years 83% male | 4,512 pravastatin 4,502 placebo | Inclusion: Past-MI or unstable angina Total cholesterol: 155-271 mg/dl Exclusion CHF or prior surgery | RCT pravastatin (40 mg/day) vs. placebo | Mortality from coronary heart disease Followup: 6.1 years (mean) | Death from coronary disease (%) pravastatin: 6.4% placebo: 8.3% RRR: 24% (12-35%) Overall mortality pravastatin: 11.0% placebo: 14.1% RRR: 22% (13-31%) | Quality: Good
Rubins HB et al., 1999^ 122 ^ | Volunteers at 20 VA medical centers Mean age: 64-65 years 100% male | 1,264 gemfibrozil 1,267 placebo | Inclusion: Documented CHD Age: < 74 HDL: < 40 LDL: < 140 Triglyceride: < 300 | RCT gemfibrozil (1,200 mg/day) vs. placebo | Incidence of nonfatal MI and death from coronary heart disease Followup: 5.1 years (median) | CHD Event gemfibrozil: 17.3% placebo: 21.7% RRR: 22% (7-35%) | Quality: Good
Sacks FM, 2002^ 123 ^ | Secondary analysis of two secondary prevention studies (CARE & LIPID) | 2,607 with LDL < 125 mg/ld | Inclusion: LDL < 125 at start Previous MI | RCT pravastatin (40 mg/day) vs. placebo Followup: 5-6 years | Aggregate CHD death + nonfatal MI + CABG/PTCA (coronary revascularization) | No difference in CHD events for any group (by age, other risk factors) except diabetes Diabetes pravastatin: 22% placebo: 34% RR=0.56 (0.37-0.83) No Diabetes pravastatin: 22% placebo: 21% RR=1.06 (0.89-1.27) | Quality: Good

Evidence Table 7. Studies of IFG/IGT Screening and Treatment

Source: Author, Year | Study Population | | | Intervention | Outcomes | Results | Comments
Source: Author, Year | Description | Size | Inclusion, Exclusion | Intervention | Outcomes | Results | Comments
Pan X et al. 1997^ 141 ^ Da Qing Impaired Glucose Tolerance and Diabetes Study | Mean Age: No differences in mean age (44.2 - 46.5 years) Gender: No difference Mean BMI: (25.3 - 26.3) Country: China Mean FPG (mmol/L): 5.52 (0.82) control 5.56 (0.81) diet modification 5.56 (0.83) exercise modification 5.67 (0.80) diet and exercise Mean follow-up: 6 years Note: Characteristics based on subjects completing study; data from those lost to follow-up not reported | Design: Prospective non blinded randomized clinical trial Randomized: 577 population-based IGT subjects identified from broad screening of city population of Da Qing, China Randomized to 4 groups 130 diet modification 141 exercise modification 126 diet and exercise modification 133 control | Fasting Glucose: WHO criteria based on sequential screening by FPG, OGTT tests Inclusion: Meeting WHO IFG criteria by FPG, OGTT testing Exclusion: None reported other than subjects with current NIDDM | Diet modification: Diet limiting caloric intake for subjects with BMI >25; supplemented with dietary counseling Exercise modification: Increased exercise recommended, supplemented with counseling Diet and exercise modification: Combination of above Control: General information regarding DM and IFG, diet and exercise modification | Primary endpoints: Incidence of NIDDM Fasting hyperglycemia (FPG >7.8 mmol/L) | % Incidence of NIDDM: 67.7 control, 43.8 diet, 41.1 exercise, 46.0 diet and exercise modification (p=0.04) RRR 0.35 diet, 0.39 exercise, 0.32 diet and exercise modification ARR .239 diet, .266 exercise, .217 diet and exercise modification NNT (6 years) 5 diet, 4 exercise, 5 diet and exercise modification | Randomization based on study clinic, not patient; unable to evaluate effectiveness of randomization as baseline characteristics only reported for those completing study Not intent to treat analysis; exclusion of those who did not complete study Non-blinded assessment
Tuomilehto et al., 2001^ 143 ^ Diabetes Prevention Trial | Mean Age: 55 Gender: 63%F Mean BMI: 31.3 Int. Grp: 31.3 (±4.6) Control: 31.0 (±4.5) Mean FPG (mmol/L): Int. Grp: 190 (±14) Control: 110 (±13) Time Frame: Up to 6 years Mean Follow-up: 3.2 years | Randomized: 522 middle-aged, overweight subjects with IGT Randomized to 2 groups: Intervention: N = 265 Control: N = 257 | Design: Randomization by list, stratified by center, sex, mean PG Inclusion: BMI > 25, 40-60 yrs of age, and diagnosis of IGT by WHO criteria Exclusion: Diagnosis of diabetes, chronic disease with < 6 yr survival, psychological or physical disabilities | Intervention Grp: Individualized counseling on goals: Decrease weight > 5% Fat Intake < 30% of Total Energy Consumed Sat Fat < 10% of Total Energy Consumed Fiber > 15g/1000 kcal Exercise > 30 min/day Control Grp: General oral and written materials about diet and exercise | Primary Endpoints: Incidence of DM | % Incidence of DM: Persons who developed DM: 13 pts of the Intervention Grp achieved no goals, of which 38% were later diagnosed with DM 48 pts of the Control Grp achieved no goals, of which 31% were later diagnosed with DM Risk of diabetes reduced by 58% (P < 0.001) in the Int Grp and directly associated with changes in lifestyle. | Intention to Treat Analysis Low drop out rate Quality: Good
  | Per 1000 Person Years | Cumulative Incidence After 4 Years
  Int. Grp: | 32 | 11%
  Control Grp: | 78 | 23%
  | Number of Patients | Average Per Year
  Int. Grp: | 27 | 3%
  Control Grp: | 59 | 6%
Diabetes Prevention Program Research Group 2002^ 142 ^ | Mean Age: 50.6 yrs Gender: 68%F Mean BMI: 34.0 Mean FPG: 106.5 mmol/L Mean Follow-up: 2.8 yrs | Randomized: 3,234 pts at high risk for DM 27 centers Groups: metformin - 1,082 placebo - 1,073 Lifestyle Modification Program - 1,079 | Design: Randomization Inclusion: High risk for DM > 25 yrs; BMI >24, FPG according to 1997 ADA criteria Exclusion: Taking medications known to alter glucose tolerance Serious illnesses to reduce life expectancy or ability to participate in trial | metformin: 850 mg 2xday Control: placebo only Lifestyle Modification Program Goals: > 7% weight loss > 150 minutes of physical activity per week | Diagnosis of DM | Incidence Rate of DM: 11.0* Control Grp 7.8* metformin Grp 4.8* Lifestyle Grp Reduction of DM Incidence: 58% Lifestyle Grp (95% CI, 48-66) 31% metformin (95% CI, 17-43) To prevent one case of DM over 3 yrs, 6.9 persons would have lifestyle modification and 13.9 would receive metformin | Double-blinded Intention to treat analysis Quality: Good

Evidence Table 8. Studies of Harms of Screening or Treatment

Source Author, Year | Study Population | Measurements | Results | Comments Quality
UKPDS Group (UKPDS-33), 1998^ 30 ^ | N: 3,867 (with newly diagnosed diabetes) Age: 25-65 Design: RCT (10 years followup) Intensive vs. conventional glucose control | Hb A1c over course of study Hypoglycemic episodes, all and major (involving medical care) | Median Hb A1c over study: Intensive: 70% Conventional: 79% Major hypoglycemia (% with one or more episodes/year) - insulin treatment: 2.3% - oral hypoglycemic drug: 0.4-0.6% - diet: 0.1% | Quality: Good
Testa, M.A, et al. 1998^ 163 ^ | Description: 594 with diabetes age 30-85 RCT randomized to active glycemic treatment or placeby Gender: 54% (320) M Age: Mean= 58 yrs Range=30-85 yrs Country: US | Quality of life, days worked, health related days missed, restricted activity days, and health care use were assessed at screening, randomization, 4,8, and 12 wks | Treatment differences were more favorable for the active therapy arm vs placebo (symptom distress (+0.59, p<0.001), general perceived health (+0.36, P = 0.004), cognitive functioning (+0.34, P = 0.005), and overall visual analog score ratings (+0.24, p=0.04) Hypoglycemic symptoms were not significant between groups By week 15, absenteeism (missing > @@@frac12@@@ day/week) rose 8.1% (2.4 %-10.5%) for the placebo group and decreased 0.8% (5.6%-4.8%) for the active therapy group | Loss to f/u: 14.9% (30) in placebo group 9.4% (37) in glipizide GITS group Comments: Shows relationship between glycemic control and QOL Quality: Good
UKPDS 37, 1997^ 196 ^ | N: 3,104 with newly diagnosed diabetes Ages: 25-65 RCT, randomized to intensive glycemic control and conventional Description: 2,431 (64% of sample) evaluated by specific questionnaire 154 controls for specific questionnaire 3,104 (85% of sample) evaluated by generic QOL measure 374 (82% of sample) followed longitudinally with specific questionnaire with 184 (49%) followed to 6 yrs Gender: 59% (3,290) M Country: Great Britain | Questionnaires measuring cognitive mistakes, mood disruptions, symptoms and quality of life | Comparison with Control Subjects (specific questionnaire) Comparison of therapeutic policies on QOL: No significant differences in QOL between conventional and intensive blood glucose policies or between less tight and tight BP control policies | Loss to f/u: 672 (166 were untraceable or had emigrated) Comments: 2% (109/5426) had macro-vascular complications 1% (79/5456) had micro-vascular complications Design: 2 cross-sectional studies of patients enrolled in randomized controlled trials of 1-intensive vs. conventional glucose control and 2-tight vs less tight blood pressure control Quality: Good
  QOL are | Control | Glucose | (Pval)
  Symptoms | 13 | 17 | (0.0022)
  Cog mistakes | 34.5 | 31 | (<0.05)
  Vigor | 17 | 16 | (<0.05)

Evidence Table 9. Studies of Cost, Cost-Effectiveness, or Modeling

Source: Author, Year | Study Methods | Study Population: Description | Time Frame | Outcomes Assumptions | Results | Conclusions | Comments Quality
CDC Diabetes Cost-Effectiveness Study Group, 1998^ 167 ^ | Analysis: Cost-effectiveness of 1-time opportunistic screening for Type-2 DM Model: Monte Carlo simulation Inclusion: Persons age 25 and older from US general population Perspective: Single-payer health care system Country: US | Grp1: Hypothetical population without clinically diagnosed diabetes assigned to opportunistic screening or current clinical practice Grp2: 10,000 diabetics followed from onset of diabetes until death | Cohort followed from onset of diabetes until death | Outcome: Cost per additional life-year gained and cost per QALY gained Assumptions: Model parameters based on population surveys, epidemiological studies, clinical trials and other clinical studies. 1995 costs and benefits discounted at 3% | Screening all adults > 25 yrs Estimated Incremental Cost of Screening: $236,449/LY and $56,649/QALY gained Lifetime Reduction in Cum Incidence: ESRD 26% Blindness 35% LEA 22% Cost of Tx increased by $3,388 with 0.02 gain in life-yrs (1 wk) Screening all adults 25-34 yrs Estimated Incremental Cost of Screening: $35,768/LY and $13,376/QALY gained Lifetime Reduction in Cum. Incidence: ESRD 3.3% Blindness 7.5% LEA 2.9% Cost of Tx decreased by $1,275 with 0.13 gain in life-yrs (7 wks) Screening all African Americans 25-34 yrs Estimated Incremental Cost of Screening: $2,219/LY and $822/QALY gained Lifetime Reduction in Cum Incidence: ESRD 4.6% Blindness 8.8% LEA 4.2% Cost of Tx decreased by $5,539 with 0.15 gain in life-yrs | Screening is more cost-effective on younger people and among African Americans. Benefits of early detection and treatment include postponement of complications | Comments: Direct nonmedical or indirect costs not considered. Quality: Good
Brown Pedula et al., 1999^ 168 ^ | Analysis: Cost analysis of complications in Type-2 DM Model: Ordinary Lease Squares Inclusion: People with diabetes from large grp-model HMO with clinical data Perspective: Health care system Country: US | 11,768 members of HMO with Type-2 DM F: 49% >70 yrs: 32% ESRD: 11% CVD: 29% | 9 yrs of clinical data | Outcome: Incremental cost of cardiovascular and renal disease Assumptions: Patients assumed to have Type-2 DM if in registry after age 45 Costs in 1993 dollars | Independent Contributions to Health Care Costs of CVD and Renal Complications in Type-2 DM: | On the population level, greatest cost savings would be achieved by preventing CVD On the individual level, greatest savings achieved by preventing ESRD | Quality: Good
  No CVD or Renal Disease: | $2,033
  Age (per 10 y): | -$67
  F: | $1,105
  CVD Preventive Tx: | $1,087
  CVD Postevent Tx: | $7,352
  Abnormal Renal Complication: | $1,337
  Advanced Renal Complication: | $3,979
  ESRD: | $15,675
Brown Nichols et al., 1999^ 166 ^ | Analysis: Cost analysis of incremental costs after Type-2 DM diagnosis Case-control method; cumulative incidence cohort Inclusion: People with new diagnosis of diabetes from large group model HMO with clinical data Perspective: Health care system Country: USA | 8,685 members of HMO with new diagnosis of Type-2 DM F: 47% Year 1 50% Year 2 Mean age: 59.6 > 65 years: 38.4% | 8 yrs of clinical data | Outcome: Incremental cost of treatment Assumptions: Patients assumed to have Type-2 DM if in registry after age 45 Costs in 1993 dollars | Diabetes-associated incremental costs: Average $2,257 per person per year (Hospitalizations for non-diabetes causes accounted for increased costs in years 1, 7 and 8) Acute Inpatient Care: Hospital Admissions accounted for $8,236 per person, or 46% of 8 yr total (largest share of incremental costs) Hospitalizations account for most of the drop after Year 1, some of steady growth thereafter, and almost all annual fluctuation Outpatient Care: 24-29% of total incremental costs (26% for all 8 years) Ave $292 per year for primary care Ave $303 per year for specialty care Over 8 yr: $2,336 for primary care, $2,424 for specialty Incremental costs of diabetes after year 1: About $100 per year (Year 1 costs spike due to non-diabetic causes) Diabetes complication hospitalizations: $136 per person per year $1,087 per person over 8 years Outpatient Drugs and Supplies: After year 1 - rapid growth in cost of antihyperglycemic drugs and supplies account for 5.9% of total costs Drug costs varied from 20% in Year 1 to 33% in Year 2 Outpatient and Pharmacy costs average $633 per year or $5,060 per person over 8 yr total Annual Incremental Costs: Year 1 - $2,392 Year 2 - $1,707 Year 8 - $2,817 Other: No growth found during first 8 years in hospital and pharmacy due to CVD and renal disease | Diagnosis of diabetes more than doubled the costs incurred by age, sex, and eligibility - matched people without diabetes Diabetes complications do not increase incremental costs as early as is commonly believed when growth for costs due to aging is controlled for Over 8 years, diabetes more than doubled the inpatient cost of cardiac disease, tripled the inpatient cost of cerebrovascular disease, and quadrupled the cost of admission for other CVD problems | Quality: Good
  | Per Person Over 8 Yrs | Per Person Per Year | % of Total Costs
  Cardiac | $1,422 | $178 | 17
  Cerebrovascular | $ 488 | $ 61 | 6
Vijan et al., 1997^ 197 ^ | Analysis: Estimate benefits of intensive glycemic control in patients with Type-2 DM Model: Markov decision model Inclusion: HMO patients with Dx of diabetes Perspective: Clinical risks and benefits Country: US | NR | Cohort followed from onset of diabetes until death | Outcome: Risks for developing blindness and ESRD, NNT Assumptions Model based on DCCT Patients assumed to have no microvascular complications at Dx. Retinop. and micro-albuminuria tied to glycemic control | Lifetime Risks for Blindness and ESRD (diabetes onset b/f age 50) Lifetime Risk for Blindness and ESRD (diabetes onset at age 65) NNT: Offering intervention of intensive glycemic control to the 29.3% of patients with HbA1c levels of 9% or greater, one case of blindness would be prevented for every 181 persons treated for life | Targeting patients on the basis of age at diabetes onset can improve the efficiency of the intervention of intensive glycemic control | Comments: Model based on extrapolation from experience of Type- 1 DM Quality: Good
  | Blindness | ESRD
  Hb A1c 9% | 2.6% | 3.5%
  Hb A1c 7% | 0.3% | 2.0%
  | Blindness | ESRD
  Hb A1c 9% | 0.5% | 0.6%
  Hb A1c 7% | <0.1% | 0.3%
UKPDS 40 1998^ 198 ^ | Analysis: Cost-effectiveness analysis to estimate economic efficiency of tight BP control Model: Not reported Inclusion: Hypertensive patients with diabetes from 20 hospital-based clinics in England, Scotland, and N. Ireland Perspective: Healthcare purchaser Country: UK | 1,148 patients Age: 56.4 yrs F: 46% Grp 1: tight BP control Grp 2: less tight BP control | Trial cohorts run through model until death | Outcome: CER based on 1) use of health care resources 2) trial time free from diabetes Assumptions: Model based on UKPDS trial Costs in 1997 pounds sterling | Treatment costs over trial duration: Complication costs (hospitalization): Total costs (present value discounted at 6%): Time free from diabetes-related endpoints: Incremental cost per life-Yr gained: | Tight control of BP reduced cost of complications, and increased time w/o complications | Limitations: Costs based on trial protocol driven costs and not costs of standard practice Comments: Only direct health service costs analyzed. Quality: Good
  Tight Control | £4,245
  Less Tight Control | £3,505
  Tight Control | £2,930
  Less Tight Control | £3,603
  Tight Control | £7,081
  Less Tight Control | £7,156
  | Undiscounted | 6%
  Tight Control | 8.16 yrs | 4.85 yrs
  Less Tight Control | 7.61 yrs | 4.63 yrs
  Cost and effects discounted at 6% | £720
  Only costs discounted at 6% | £291

Evidence Tables Glossary

Abbreviation | Definition
ACEI | Ace Inhibitors
ADA | American Diabetes Association
ARR | Absolute Relative Risk
BMI | Body Mass Index
CA | Calcium Channel Blockers
CABG | Coronary Artery Bypass Graft
CBG | Capillary Blood Glucose
CHD | Coronary Heart Disease
CHF | Congestive Heart Failure
CI | Confidence Interval
Cog | Cognitive
CVD | Cardiovascular Disease
DB | Diuretics and Beta Blockers
D/C | Discontinued
ECG | Electrocardiogram
ESRD | End State Renal Disease
FPG | Fasting Plasma Glucose
Grp | Group
Hb A1c | Glycated Hemoglobin
HDL | High-Density Lipoprotein
IFG | Impaired Fasting Glucose
IGT | Impaired Glucose Tolerance
Int | Intervention
LEA | Lower Extremity Amputation
LDL | Low-Density Lipoprotein
MI | Myocardial Infarction
New-DM | Newly Diagnosed Diabetes
NGT | Normal Glucose Tolerance
NHANES | National Health and Nutrition Examination Survey
NNT | Number Needed to Treat
OGTT | Oral Glucose Tolerance Test
OR | Odds Ratio
p-y | Person year
PG | Plasma Glucose
PTCA | Percutaneous Transluminal Coronary Angioplasty
QALY | Quality Adjusted Life Year
QOL | Quality of Life
RR | Relative Risk
RRR | Relative Risk Reduction
TX | Treatment
WHO | World Health Organization