# Appendix A. Acknowledgments

This study was developed by the Research Triangle Institute -- University of North Carolina Evidence-based Practice Center under contract to the Agency for Healthcare Research and Quality (Contract No. 290-97-0011), Rockville, Maryland.

We thank David Atkins, MD, MPH, Chief Medical Officer for the Center for Practice and Technology Assessment, and Jean Slutsky, PA, MSPH, the project officer for this project, both at the Agency for Healthcare Research and Quality, for their assistance throughout the project. We are especially indebted to Loraine Monroe of RTI International for superior word processing support. We also acknowledge Warren Newton, MD, and Eric Baggstrom, MD, both of the University of North Carolina at Chapel Hill, for their assistance early in the project.

In addition, we would like to thank our current US Preventive Services Task Force topic liaisons, Paul Frame, MD, of Tri-County Family Medicine, Cochocton, NY, and Steven Woolf, MD, MPH, of Virginia Commonwealth University, Fairfax, VA, for their guidance during this project. We would also like to thank Harold C. Sox, Jr., MD, of the Annals of Internal Medicine, Philadelphia, PA, and formerly of the US Preventive Services Task Force, for his assistance and guidance early in the project.

An earlier version of this systematic review underwent extensive external peer review in 2000. We thank the following peer reviewers for helpful comments and suggestions: Amanda Adler, MD, PhD, Radcliffe Infirmary, Oxford, England; Elizabeth Barrett-Connor, MD, University of California San Diego, La Jolla, CA; Tom Elasy, MD, Vanderbilt University, Nashville, TN; Denice Feig, MD, MSc, FRCPC, Mount Sinai Hospital, Toronto, Onatario; R.A. Hayward, MD, University of Michigan, Ann Arbor, MI; Richard Kahn, PhD, American Diabetes Association, Alexandria, VA; Vincenza Snow, MD, American College of Physicians-American Society of Internal Medicine, Philadelphia, PA; Stephen Spann, MD, Baylor College of Medicine, Houston, TX; and Eric Vogel, MD, MCP, Hahnemann University, Philadelphia, PA.