# References

1 Moyer VA, U. S. Preventive Services Task Force. Screening for cognitive impairment in older adults: U.S. Preventive Services Task Force recommendation statement.[Summary for patients in Ann Intern Med. 2014 Jun 3;160(11). doi: 10.7326/P14-9017; PMID: 24663960]. Annals of Internal Medicine. 2014;160(11):791–7. PMID: 24663815. 10.7326/M14-0496 24663815
2 American Psychiatric Association. Diagnostic and Statistic Manual of Mental Disorders. Washington, DC. 1994. PMID: None.
3 American Psychiatric Association. Diagnostic and statistical manual of mental disorders (5th ed.). Washington, DC. 2013. PMID: None.
4 Plassman BL, Langa KM, Fisher GG, . Prevalence of dementia in the United States: the aging, demographics, and memory study. Neuroepidemiology. 2007;29(1–2):125–32. PMID: 17975326. 10.1159/000109998 17975326
5 Warner JP, Butler R, Gupta S. Dementia. BMJ Clin Evid. 2010;2010. PMID: 21726471.21726471
6 Querfurth HW, LaFerla FM. Alzheimer’s disease. N Engl J Med. 2010;362(4):329–44. PMID: 20107219. 10.1056/NEJMra0909142 20107219
7 Savva GM, Wharton SB, Ince PG, . Age, neuropathology, and dementia. N Engl J Med. 2009;360(22):2302–9. PMID: 19474427. 10.1056/NEJMoa0806142 19474427
8 Sonnen JA, Larson EB, Crane PK, . Pathological correlates of dementia in a longitudinal, population-based sample of aging. Ann Neurol. 2007;62(4):406–13. PMID: 17879383. 10.1002/ana.21208 17879383
9 Espino DV, Jules-Bradley AC, Johnston CL, . Diagnostic approach to the confused elderly patient. Am Fam Physician. 1998;57(6):1358–66. PMID: 9531917.9531917
10 Halter JB, Ouslander JG, Tinetti ME, . Hazzard’s Geriatric Medicine and Gerontology. New York: McGraw-Hill. 2009. PMID: None.
11 Matthews FE, Stephan BC, Bond J, . Operationalization of mild cognitive impairment: a graphical approach. PLoS Med. 2007;4(10):1615–9. PMID: 17973571. 10.1371/journal.pmed.0040304 17973571
12 Winblad B, Palmer K, Kivipelto M, . Mild cognitive impairment--beyond controversies, towards a consensus: report of the International Working Group on Mild Cognitive Impairment. J Intern Med. 2004;256(3):240–6. PMID: 15324367. 10.1111/j.1365-2796.2004.01380.x 15324367
13 Petersen RC, Roberts RO, Knopman DS, . Mild cognitive impairment: ten years later. Arch Neurol. 2009;66(12):1447–55. PMID: 20008648. 10.1001/archneurol.2009.266 20008648
14 Petersen RC, Smith GE, Waring SC, . Mild cognitive impairment: clinical characterization and outcome. Arch Neurol. 1999;56(3):303–8. PMID: 10190820.10190820
15 Mitchell AJ, Shiri-Feshki M. Rate of progression of mild cognitive impairment to dementia--meta-analysis of 41 robust inception cohort studies. Acta Psychiatr Scand. 2009;119(4):252–65. PMID: 19236314. 10.1111/j.1600-0447.2008.01326.x 19236314
16 Seshadri S, Beiser A, Au R, . Operationalizing diagnostic criteria for Alzheimer’s disease and other age-related cognitive impairment-Part 2. Alzheimers Dement. 2011;7(1):35–52. PMID: 21255742. 10.1016/j.jalz.2010.12.002 21255742
17 Stephan BC, Kurth T, Matthews FE, . Dementia risk prediction in the population: are screening models accurate? Nat Rev Neurol. 2010;6(6):318–26. PMID: 20498679. 10.1038/nrneurol.2010.54 20498679
18 Holsinger T, Deveau J, Boustani M, . Does this patient have dementia? JAMA. 2007;297(21):2391–404. PMID: 17551132. 10.1001/jama.297.21.2391 17551132
19 Boise L, Neal MB, Kaye J. Dementia assessment in primary care: results from a study in three managed care systems. J Gerontol A Biol Sci Med Sci. 2004;59(6):M621–6. PMID: 15215282.15215282
20 Bradford A, Kunik ME, Schulz P, . Missed and delayed diagnosis of dementia in primary care: prevalence and contributing factors. Alzheimer Dis Assoc Disord. 2009;23(4):306–14. PMID: 19568149. 10.1097/WAD.0b013e3181a6bebc 19568149
21 Prince M, Bryce R, Albanese E, . The global prevalence of dementia: a systematic review and metaanalysis. Alzheimers Dement. 2013;9(1):63–75 e2. PMID: 23305823. 10.1016/j.jalz.2012.11.007 23305823
22 Gaugler J, James B, Johnson T, . 2019 Alzheimer’s disease facts and figures. Alzheimers Dement. 2019;15(3):321–87. PMID: None.
23 Langa KM, Larson EB, Crimmins EM, . A Comparison of the Prevalence of Dementia in the United States in 2000 and 2012. JAMA Intern Med. 2017;177(1):51–8. PMID: 27893041. 10.1001/jamainternmed.2016.6807 27893041
24 Goodman RA, Lochner KA, Thambisetty M, . Prevalence of dementia subtypes in United States Medicare fee-for-service beneficiaries, 2011–2013. Alzheimers Dement. 2017;13(1):28–37. PMID: 27172148. 10.1016/j.jalz.2016.04.002 27172148
25 Clarfield AM. The decreasing prevalence of reversible dementias: an updated meta-analysis. Arch Intern Med. 2003;163(18):2219–29. PMID: 14557220. 10.1001/archinte.163.18.2219 14557220
26 Jorm AF, Jolley D. The incidence of dementia: a meta-analysis. Neurology. 1998;51(3):728–33. PMID: 9748017.9748017
27 Corrada MM, Brookmeyer R, Paganini-Hill A, . Dementia incidence continues to increase with age in the oldest old: the 90+ study. Ann Neurol. 2010;67(1):114–21. PMID: 20186856. 10.1002/ana.21915 20186856
28 Potter GG, Plassman BL, Burke JR, . Cognitive performance and informant reports in the diagnosis of cognitive impairment and dementia in African Americans and whites. Alzheimers Dement. 2009;5(6):445–53. PMID: 19896583. 10.1016/j.jalz.2009.04.1234 19896583
29 Tang MX, Cross P, Andrews H, . Incidence of AD in African-Americans, Caribbean Hispanics, and Caucasians in northern Manhattan. Neurology. 2001;56(1):49–56. PMID: 11148235. 10.1212/WNL.56.1.49 11148235
30 Chin AL, Negash S, Hamilton R. Diversity and disparity in dementia: the impact of ethnoracial differences in Alzheimer disease. Alzheimer Dis Assoc Disord. 2011;25(3):187–95. PMID: 21399486. 10.1097/WAD.0b013e318211c6c9 21399486
31 Gurland BJ, Wilder DE, Lantigua R, . Rates of dementia in three ethnoracial groups. Int J Geriatr Psychiatry. 1999;14(6):481–93. PMID: 10398359.10398359
32 Alzheimer’s Association. 2012 Alzheimer’s disease facts and figures. Alzheimers Dement. 2012;8(2):131–68. PMID: 22404854. 10.1016/j.jalz.2012.02.001 22404854
33 Altmann A, Tian L, Henderson VW, . Sex modifies the APOE-related risk of developing Alzheimer disease. Ann Neurol. 2014;75(4):563–73. PMID: 24623176. 10.1002/ana.24135 24623176
34 Rocca WA, Mielke MM, Vemuri P, . Sex and gender differences in the causes of dementia: a narrative review. Maturitas. 2014;79(2):196–201. PMID: 24954700. 10.1016/j.maturitas.2014.05.008 24954700
35 Bischkopf J, Busse A, Angermeyer MC. Mild cognitive impairment--a review of prevalence, incidence and outcome according to current approaches. Acta Psychiatr Scand. 2002;106(6):403–14. PMID: 12392483.12392483
36 Ward A, Arrighi HM, Michels S, . Mild cognitive impairment: disparity of incidence and prevalence estimates. Alzheimers Dement. 2012;8(1):14–21. PMID: 22265588. 10.1016/j.jalz.2011.01.002 22265588
37 Mioshi E, Hsieh S, Savage S, . Clinical staging and disease progression in frontotemporal dementia. Neurology. 2010;74(20):1591–7. PMID: 20479357. 10.1212/WNL.0b013e3181e04070 20479357
38 Sollberger M, Neuhaus J, Ketelle R, . Interpersonal traits change as a function of disease type and severity in degenerative brain diseases. J Neurol Neurosurg Psychiatry. 2011;82(7):732–9. PMID: 21172858. 10.1136/jnnp.2010.205047 21172858
39 Xie J, Brayne C, Matthews FE, . Survival times in people with dementia: analysis from population based cohort study with 14 year follow-up. BMJ. 2008;336(7638):258–62. PMID: 18187696. 10.1136/bmj.39433.616678.25 18187696
40 Rait G, Walters K, Bottomley C, . Survival of people with clinical diagnosis of dementia in primary care: cohort study. BMJ. 2010;341:c3584. PMID: 20688840. 10.1136/bmj.c3584 20688840
41 Brookmeyer R, Corrada MM, Curriero FC, . Survival following a diagnosis of Alzheimer disease. Arch Neurol. 2002;59(11):1764–7. PMID: 12433264.12433264
42 Roberson ED, Hesse JH, Rose KD, . Frontotemporal dementia progresses to death faster than Alzheimer disease. Neurology. 2005;65(5):719–25. PMID: 16157905. 10.1212/01.wnl.0000173837.82820.9f 16157905
43 Hodges JR, Davies R, Xuereb J, . Survival in frontotemporal dementia. Neurology. 2003;61(3):349–54. PMID: 12913196.12913196
44 Boustani M, Peterson B, Hanson L, . Screening for dementia in primary care: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;138(11):927–37. PMID: 12779304.12779304
45 Ballard C, O’Brien J, Morris CM, . The progression of cognitive impairment in dementia with Lewy bodies, vascular dementia and Alzheimer’s disease. Int J Geriatr Psychiatry. 2001;16(5):499–503. PMID: 11376466.11376466
46 Hanyu H, Sato T, Hirao K, . Differences in clinical course between dementia with Lewy bodies and Alzheimer’s disease. Eur J Neurol. 2009;16(2):212–7. PMID: 19146642. 10.1111/j.1468-1331.2008.02388.x 19146642
47 McKeith IG, Dickson DW, Lowe J, . Diagnosis and management of dementia with Lewy bodies: third report of the DLB Consortium. Neurology. 2005;65(12):1863–72. PMID: 16237129. 10.1212/01.wnl.0000187889.17253.b1 16237129
48 Engelborghs S, Maertens K, Nagels G, . Neuropsychiatric symptoms of dementia: cross-sectional analysis from a prospective, longitudinal Belgian study. Int J Geriatr Psychiatry. 2005;20(11):1028–37. PMID: 16250064. 10.1002/gps.1395 16250064
49 Rascovsky K, Hodges JR, Knopman D, . Sensitivity of revised diagnostic criteria for the behavioural variant of frontotemporal dementia. Brain. 2011;134(Pt 9):2456–77. PMID: 21810890. 10.1093/brain/awr179 21810890
50 Mathias JL, Morphett K. Neurobehavioral differences between Alzheimer’s disease and frontotemporal dementia: a meta-analysis. J Clin Exp Neuropsychol. 2010;32(7):682–98. PMID: 20063255. 10.1080/13803390903427414 20063255
51 Manly JJ, Tang MX, Schupf N, . Frequency and course of mild cognitive impairment in a multiethnic community. Ann Neurol. 2008;63(4):494–506. PMID: 18300306. 10.1002/ana.21326 18300306
52 Ganguli M, Snitz BE, Saxton JA, . Outcomes of mild cognitive impairment by definition: a population study. Arch Neurol. 2011;68(6):761–7. PMID: 21670400. 10.1001/archneurol.2011.101 21670400
53 Loewenstein DA, Acevedo A, Small BJ, . Stability of different subtypes of mild cognitive impairment among the elderly over a 2- to 3-year follow-up period. Dement Geriatr Cogn Disord. 2009;27(5):418–23. PMID: 19365121. 10.1159/000211803 19365121
54 Ward A, Tardiff S, Dye C, . Rate of conversion from prodromal Alzheimer’s disease to Alzheimer’s dementia: a systematic review of the literature. Dement Geriatr Cogn Dis Extra. 2013;3(1):320–32. PMID: 24174927. 10.1159/000354370 24174927
55 Larrieu S, Letenneur L, Orgogozo JM, . Incidence and outcome of mild cognitive impairment in a population-based prospective cohort. Neurology. 2002;59(10):1594–9. PMID: 12451203. 10.1212/01.WNL.0000034176.07159.F8 12451203
56 Roberts RO, Geda YE, Knopman DS, . The incidence of MCI differs by subtype and is higher in men: the Mayo Clinic Study of Aging. Neurology. 2012;78(5):342–51. PMID: 22282647. 10.1212/WNL.0b013e3182452862 22282647
57 Johansson B, Zarit SH. Early cognitive markers of the incidence of dementia and mortality: a longitudinal population-based study of the oldest old. Int J Geriatr Psychiatry. 1997;12(1):53–9. PMID: 9050424. 10.1002/(SICI)1099-1166(199701)12:1<53::AID-GPS507>3.0.CO;2-M 9050424
58 Wilson RS, Aggarwal NT, Barnes LL, . Biracial population study of mortality in mild cognitive impairment and Alzheimer disease. Arch Neurol. 2009;66(6):767–72. PMID: 19506138. 10.1001/archneurol.2009.80 19506138
59 Guehne U, Luck T, Busse A, . Mortality in individuals with mild cognitive impairment. Results of the Leipzig Longitudinal Study of the Aged (LEILA75+). Neuroepidemiology. 2007;29(3–4):226–34. PMID: 18073495. 10.1159/000112479 18073495
60 Ingles JL, Fisk JD, Merry HR, . Five-year outcomes for dementia defined solely by neuropsychological test performance. Neuroepidemiology. 2003;22(3):172–8. PMID: 12711849. 10.1159/000069891 12711849
61 Palmer K, Wang HX, Backman L, . Differential evolution of cognitive impairment in nondemented older persons: results from the Kungsholmen Project. Am J Psychiatry. 2002;159(3):436–42. PMID: 11870008. 10.1176/appi.ajp.159.3.436 11870008
62 Fisk JD, Rockwood K. Outcomes of incident mild cognitive impairment in relation to case definition. J Neurol Neurosurg Psychiatry. 2005;76(8):1175–7. PMID: 16024904. 10.1136/jnnp.2004.053751 16024904
63 Fisk JD, Merry HR, Rockwood K. Variations in case definition affect prevalence but not outcomes of mild cognitive impairment. Neurology. 2003;61(9):1179–84. PMID: 14610117.14610117
64 Plassman BL, Williams JW, Jr., Burke JR, . Systematic review: factors associated with risk for and possible prevention of cognitive decline in later life. Ann Intern Med. 2010;153(3):182–93. PMID: 20547887. 10.7326/0003-4819-153-3-201008030-00258 20547887
65 Cooper C, Sommerlad A, Lyketsos CG, . Modifiable predictors of dementia in mild cognitive impairment: a systematic review and meta-analysis. Am J Psychiatry. 2015;172(4):323–34. PMID: 25698435. 10.1176/appi.ajp.2014.14070878 25698435
66 Ritchie K, Carriere I, Ritchie CW, . Designing prevention programmes to reduce incidence of dementia: prospective cohort study of modifiable risk factors. BMJ. 2010;341:c3885. PMID: 20688841. 10.1136/bmj.c3885 20688841
67 Boyle PA, Buchman AS, Wilson RS, . Physical frailty is associated with incident mild cognitive impairment in community-based older persons. J Am Geriatr Soc. 2010;58(2):248–55. PMID: 20070417. 10.1111/j.1532-5415.2009.02671.x 20070417
68 Goveas JS, Espeland MA, Hogan P, . Depressive symptoms, brain volumes and subclinical cerebrovascular disease in postmenopausal women: the Women’s Health Initiative MRI Study. J Affect Disord. 2011;132(1–2):275–84. PMID: 21349587. 10.1016/j.jad.2011.01.020 21349587
69 Vemuri P, Lesnick TG, Przybelski SA, . Association of lifetime intellectual enrichment with cognitive decline in the older population. JAMA Neurol. 2014;71(8):1017–24. PMID: 25054282. 10.1001/jamaneurol.2014.963 25054282
70 Satizabal C, Beiser AS, Seshadri S. Incidence of Dementia over Three Decades in the Framingham Heart Study. N Engl J Med. 2016;375(1):93–4. PMID: 27406362. 10.1056/NEJMc1604823 27406362
71 Matthews FE, Arthur A, Barnes LE, . A two-decade comparison of prevalence of dementia in individuals aged 65 years and older from three geographical areas of England: results of the Cognitive Function and Ageing Study I and II. Lancet. 2013;382(9902):1405–12. PMID: 23871492. 10.1016/S0140-6736(13)61570-6 23871492
72 Tolppanen AM, Ngandu T, Kareholt I, . Midlife and late-life body mass index and late-life dementia: results from a prospective population-based cohort. J Alzheimers Dis. 2014;38(1):201–9. PMID: 23948937. 10.3233/JAD-130698 23948937
73 Livingston G, Sommerlad A, Orgeta V, . Dementia prevention, intervention, and care. Lancet. 2017;390(10113):2673–734. PMID: 28735855. 10.1016/S0140-6736(17)31363-6 28735855
74 Stephen R, Hongisto K, Solomon A, . Physical Activity and Alzheimer’s Disease: A Systematic Review. J Gerontol A Biol Sci Med Sci. 2017;72(6):733–9. PMID: 28049634. 10.1093/gerona/glw251 28049634
75 Mukamal KJ, Kuller LH, Fitzpatrick AL, . Prospective study of alcohol consumption and risk of dementia in older adults. JAMA. 2003;289(11):1405–13. PMID: 12636463.12636463
76 Scarmeas N, Luchsinger JA, Schupf N, . Physical activity, diet, and risk of Alzheimer disease. JAMA. 2009;302(6):627–37. PMID: 19671904. 10.1001/jama.2009.1144 19671904
77 Kane R, Butler M, Fink H, . Interventions to Prevent Age-Related Cognitive Decline, Mild Cognitive Impairment, and Clinical Alzheimer’s-Type Dementia. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2015-00008-I.) AHRQ Publication No. 17-EHC008-EF: Rockville, MD: Agency for Healthcare Research and Quality; March 2017. PMID: None.
78 Brasure M, Desai P, Davila H, . Physical Activity Interventions in Preventing Cognitive Decline and Alzheimer-Type Dementia: A Systematic Review. Ann Intern Med. 2018;168(1):30–8. PMID: 29255839. 10.7326/M17-1528 29255839
79 Butler M, Nelson VA, Davila H, . Over-the-Counter Supplement Interventions to Prevent Cognitive Decline, Mild Cognitive Impairment, and Clinical Alzheimer-Type Dementia: A Systematic Review. Ann Intern Med. 2018;168(1):52–62. PMID: 29255909. 10.7326/M17-1530 29255909
80 Fink HA, Jutkowitz E, McCarten JR, . Pharmacologic Interventions to Prevent Cognitive Decline, Mild Cognitive Impairment, and Clinical Alzheimer-Type Dementia: A Systematic Review. Ann Intern Med. 2018;168(1):39–51. PMID: 29255847. 10.7326/M17-1529 29255847
81 Chodosh J, Petitti DB, Elliott M, . Physician recognition of cognitive impairment: evaluating the need for improvement. J Am Geriatr Soc. 2004;52(7):1051–9. 10.1111/j.1532-5415.2004.52301.x 15209641
82 Olafsdottir M, Skoog I, Marcusson J. Detection of dementia in primary care: the Linkoping study. Dement Geriatr Cogn Disord. 2000;11(4):223–9. 10.1159/000017241 10867449
83 Valcour VG, Masaki KH, Curb JD, . The detection of dementia in the primary care setting. Arch Intern Med. 2000;160(19):2964–8.11041904
84 Ganguli M, Rodriguez E, Mulsant B, . Detection and management of cognitive impairment in primary care: The Steel Valley Seniors Survey. J Am Geriatr Soc. 2004;52(10):1668–75. 10.1111/j.1532-5415.2004.52459.x 15450043
85 van den Dungen P, van Marwijk HW, van der Horst HE, . The accuracy of family physicians’ dementia diagnoses at different stages of dementia: a systematic review. Int J Geriatr Psychiatry. 2012;27(4):342–54. 10.1002/gps.2726 21626568
86 Ashford JW, Borson S, O’Hara R, . Should older adults be screened for dementia? It is important to screen for evidence of dementia! Alzheimers Dement. 2007;3(2):75–80. PMID: 19595920. 10.1016/j.jalz.2007.03.005 19595920
87 National Institute on Aging’s Alzheimer’s Disease Foundation Education and Referral (ADEAR) Center. Assessing Cognitive Impairment in Older Patients. A Quick Guide for Primary Care Physicians https://www.nia.nih.gov/alzheimers/publication/assessing-cognitive-impairment-older-patients. Accessed February 11, 2018.
88 Knopman DS, DeKosky ST, Cummings JL, . Practice parameter: diagnosis of dementia (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1143–53. PMID: 11342678. 10.1212/WNL.56.9.1143 11342678
89 Larson EB. Evaluation of cognitive impairment and dementia. Dekosky S, ed. Waltham, MA: UpToDate Inc. http://www.uptodate.com. Accessed December 19, 2018.
90 American College of Medical Genetics/American Society of Human Genetics Working Group on ApoE and Alzheimer disease. Statement on use of apolipoprotein E testing for Alzheimer disease. JAMA. 1995;274(20):1627–9. PMID: 7474250. 10.1001/jama.1995.03530200063039 7474250
91 Weinstein AM, Barton C, Ross L, . Treatment practices of mild cognitive impairment in California Alzheimer’s Disease Centers. J Am Geriatr Soc. 2009;57(4):686–90. PMID: 19392962. 10.1111/j.1532-5415.2009.02200.x 19392962
92 Alzheimer’s Association. Treatment Horizon. http://www.alz.org/research/science/alzheimers_treatment_horizon.asp. Accessed 04/20/2017.
93 American Geriatrics Society. A Guide to Dementia Diagnosis and Treatment. http://dementia.americangeriatrics.org/documents/AGS_PC_Dementia_Sheet_2010v2.pdf Accessed 04/20/2017.
94 Canadian Task Force on Preventive Health Care, Pottie K, Rahal R, . Recommendations on screening for cognitive impairment in older adults. CMAJ. 2016;188(1):37–46. PMID: 26622001. 10.1503/cmaj.141165 26622001
95 Hort J, O’Brien JT, Gainotti G, . EFNS guidelines for the diagnosis and management of Alzheimer’s disease. Eur J Neurol. 2010;17(10):1236–48. PMID: 20831773. 10.1111/j.1468-1331.2010.03040.x 20831773
96 Royal Australian College of General Practitioners. Guidelines for preventive activities in general practice. East Melbourne: Royal Australian College of General Practitioners; 2012. PMID: None.
97 US Department of Veterans Affairs. VHA DEMENTIA STEERING COMMITTEE RECOMMENDATIONS FOR DEMENTIA CARE IN THE VHA HEALTH CARE SYSTEM. September 2016. https://www.va.gov/GERIATRICS/docs/VHA_DSC_RECOMMENDATIONS_SEPT_2016_9-12-16.pdf. Accessed November 28, 2018.
98 Fazio S, Pace D, Maslow K, . Alzheimer’s Association Dementia Care Practice Recommendations. Gerontologist. 2018;58(suppl_1):S1–S9. PMID: 29361074. 10.1093/geront/gnx182 29361074
99 The Gerontological Society of America. The Gerontological Society of America Workgroup on Cognitive Impairment and Earlier Diagnosis: Report and Recommendations. https://www.geron.org/programs-services/alliances-and-multi-stakeholder-collaborations/cognitive-impairment-detection-and-earlier-diagnosis. Accessed February 11, 2019.
100 Patient Protection and Affordable Care Act. Pub. L. No. 111–148, §2702, 124 Stat. 119, 318–319 2010. PMID: None.
101 Institute of Medicine. Cognitive Aging: Progress in Understanding and Opportunities for Action. 2015. PMID: 26540695. 10.17226/21693 26540695
102 Centers for Medicare & Medicaid Services (CMS). Beneficiaries Utilizing Free Preventive Services by State, 2016. https://downloads.cms.gov/files/Beneficiaries%20Utilizing%20Free%20Preventive%20Services%20by%20State%20YTD%202016.pdf. Accessed 04/20/2017.
103 Cordell CB, Borson S, Boustani M, . Alzheimer’s Association recommendations for operationalizing the detection of cognitive impairment during the Medicare Annual Wellness Visit in a primary care setting. Alzheimers Dement. 2013;9(2):141–50. 10.1016/j.jalz.2012.09.011 23265826
104 Gerontological Society of America. Cognitive Impairment Detection and Earlier Diagnosis, KAER Toolkit: 4-Step Process to Detecting Cognitive Impairment and Earlier Diagnosis of Dementia https://www.geron.org/images/gsa/kaer/gsa-kaer-toolkit.pdf. Accessed December 3, 2018.
105 Lin JS, O’Connor E, Rossom RC, . Screening for cognitive impairment in older adults: A systematic review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2013;159(9):601–12.24145578
106 Lin JS, O’Connor E, Rossom RC, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. In: Screening for Cognitive Impairment in Older Adults: An Evidence Update for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2013.
107 Raina P, Santaguida P, Ismaila A, . Effectiveness of cholinesterase inhibitors and memantine for treating dementia: evidence review for a clinical practice guideline. Ann Intern Med. 2008;148(5):379–97. PMID: 18316756.18316756
108 Reid LM, Maclullich AM. Subjective memory complaints and cognitive impairment in older people. Dement Geriatr Cogn Disord. 2006;22(5–6):471–85. PMID: 17047326. 10.1159/000096295 17047326
109 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID: None.
110 Wells G, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed December 3, 2018.
111 Whiting P, Rutjes AW, Reitsma JB, . The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. PMID: 14606960. 10.1186/1471-2288-3-25 14606960
112 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
113 Lijmer JG, Mol BW, Heisterkamp S, . Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282(11):1061–6. PMID: 10493205.10493205
114 Whiting P, Rutjes AW, Reitsma JB, . Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. 2004;140(3):189–202. PMID: 14757617.14757617
115 Rutjes AW, Reitsma JB, Di Nisio M, . Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174(4):469–76. PMID: 16477057. 10.1503/cmaj.050090 16477057
116 de Groot JA, Bossuyt PM, Reitsma JB, . Verification problems in diagnostic accuracy studies: consequences and solutions. BMJ. 2011;343:d4770. PMID: 21810869. 10.1136/bmj.d4770 21810869
117 Gaugler JE, Jutkowitz E, Shippee TP, . Consistency of dementia caregiver intervention classification: an evidence-based synthesis. International Psychogeriatrics. 2017;29(1):19–30. PMID: 27671663. 10.1017/S1041610216001514 27671663
118 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: an update. Contemp Clin Trials. 2007;28(2):105–14. PMID: 16807131. 10.1016/j.cct.2006.04.004 16807131
119 Veroniki AA, Jackson D, Viechtbauer W, . Methods to estimate the between-study variance and its uncertainty in meta-analysis. 2016;7(1):55–79. PMID: 26332144. 10.1002/jrsm.1164 26332144
120 Sterne JAC, Harbord RM. Funnel plots in meta-analysis. In: Meta-Analysis in Stata: An Updated Collection from the Stata Journal. Sterne JAC, editor. College Station, Texas: Stata Press; 2009. p. 109–23.
121 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. PMID: 9310563. 10.1136/bmj.315.7109.629 9310563
122 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
123 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
124 Fowler N, Perkins A, Gao S, . Risks and benefits of screening for dementia in primary care: the IU CHOICE trial. J Am Geriatr Soc. 2019; 10.1111/jgs.16247
125 Fowler NR, Harrawood A, Frame A, . The Indiana University Cognitive Health Outcomes Investigation of the Comparative Effectiveness of dementia screening (CHOICE) study: study protocol for a randomized controlled trial. Trials. 2014;15:209. PMID: 24903469. 10.1186/1745-6215-15-209 24903469
126 Ayalon L. The IQCODE Versus a Single-Item Informant Measure to Discriminate Between Cognitively Intact Individuals and Individuals With Dementia or Cognitive Impairment. J Geriatr Psychiatry Neurol. 2011;24(3):168–73. PMID: 21856971. 10.1177/0891988711418506 21856971
127 Ball LJ, Ogden A, Mandi D, . The validation of a mailed health survey for screening of dementia of the Alzheimer’s type. J Am Geriatr Soc. 2001;49(6):798–802. PMID: 11454121. 10.1046/j.1532-5415.2001.49159.x 11454121
128 Borson S, Scanlan JM, Watanabe J, . Improving identification of cognitive impairment in primary care. Int J Geriatr Psychiatry. 2006;21(4):349–55. PMID: 16534774. 10.1002/gps.1470 16534774
129 Brodaty H, Pond D, Kemp NM, . The GPCOG: a new screening test for dementia designed for general practice. J Am Geriatr Soc. 2002;50(3):530–4. PMID: 11943052. 10.1046/j.1532-5415.2002.50122.x 11943052
130 Buschke H, Kuslansky G, Katz M, . Screening for dementia with the memory impairment screen. Neurology. 1999;52(2):231–8. PMID: 9932936. 10.1212/WNL.52.2.231 9932936
131 Callahan CM, Unverzagt FW, Hui SL, . Six-item screener to identify cognitive impairment among potential subjects for clinical research. Med Care. 2002;40(9):771–81. PMID: 12218768. 10.1097/00005650-200209000-00007 12218768
132 Chan QL, Xu X, Shaik MA, . Clinical utility of the informant AD8 as a dementia case finding instrument in primary healthcare. J Alzheimers Dis Rep. 2016;49(1):121–7. PMID: 26444776. 10.3233/JAD-150390 26444776
133 Cook SE, Marsiske M, McCoy KJ. The use of the Modified Telephone Interview for Cognitive Status (TICS-M) in the detection of amnestic mild cognitive impairment. J Geriatr Psychiatry Neurol. 2009;22(2):103–9. PMID: 19417219. 10.1177/0891988708328214 19417219
134 Cruz-Orduna I, Bellon JM, Torrero P, . Detecting MCI and dementia in primary care: efficiency of the MMS, the FAQ and the IQCODE. Fam Pract. 2012;29(4):401–6. PMID: 22121012. 10.1093/fampra/cmr114 22121012
135 Cullen B, Fahy S, Cunningham CJ, . Screening for dementia in an Irish community sample using MMSE: a comparison of norm-adjusted versus fixed cut-points. Int J Geriatr Psychiatry. 2005;20(4):371–6. PMID: 15799072. 10.1002/gps.1291 15799072
136 Cummings-Vaughn LA, Chavakula NN, Malmstrom TK, . Veterans Affairs Saint Louis University Mental Status examination compared with the Montreal Cognitive Assessment and the Short Test of Mental Status. J Am Soc Geriatr Dent. 2014;62(7):1341–6. PMID: 24916485. 10.1111/jgs.12874 24916485
137 Del Ser T, Sanchez-Sanchez F, Garcia de Yebenes MJ, . Validation of the seven-minute screen neurocognitive battery for the diagnosis of dementia in a Spanish population-based sample. Dement Geriatr Cogn Disord. 2006;22(5–6):454–64. PMID: 16988506. 10.1159/000095858 16988506
138 Donnelly K, Donnelly JP, Cory E. Primary care screening for cognitive impairment in elderly veterans. Am J Alzheimers Dis Other Demen. 2008;23(3):218–26. PMID: 18375531. 10.1177/1533317508315932 18375531
139 Ehreke L, Luck T, Luppa M, . Clock drawing test - screening utility for mild cognitive impairment according to different scoring systems: results of the Leipzig Longitudinal Study of the Aged (LEILA 75+). Int Psychogeriatr. 2011;23(10):1592–601. PMID: 21813037. 10.1017/S104161021100144X 21813037
140 Ehreke L, Luppa M, Luck T, . Is the clock drawing test appropriate for screening for mild cognitive impairment?--Results of the German study on Ageing, Cognition and Dementia in Primary Care Patients (AgeCoDe). Dement Geriatr Cogn Disord. 2009;28(4):365–72. PMID: 19887799. 10.1159/000253484 19887799
141 Erkinjuntti T, Sulkava R, Wikstrom J, . Short Portable Mental Status Questionnaire as a screening test for dementia and delirium among the elderly. J Am Geriatr Soc. 1987;35(5):412–6. PMID: 3571790. 10.1111/j.1532-5415.1987.tb04662.x 3571790
142 Fillenbaum G, Heyman A, Williams K, . Sensitivity and specificity of standardized screens of cognitive impairment and dementia among elderly black and white community residents. J Clin Epidemiol. 1990;43(7):651–60. PMID: 2370572. 10.1016/0895-4356(90)90035-N 2370572
143 Fong TG, Jones RN, Rudolph JL, . Development and validation of a brief cognitive assessment tool: the sweet 16. Arch Intern Med. 2011;171(5):432–7. PMID: 21059967. 10.1001/archinternmed.2010.423 21059967
144 Fuchs A, Wiese B, Altiner A, . Cued Recall and Other Cognitive Tasks to Facilitate Dementia Recognition in Primary Care. J Am Geriatr Soc. 2012:130–5. PMID: 22150245. 10.1111/j.1532-5415.2011.03765.x 22150245
145 Gagnon M, Letenneur L, Dartigues JF, . Validity of the Mini-Mental State examination as a screening instrument for cognitive impairment and dementia in French elderly community residents. Neuroepidemiology. 1990;9(3):143–50. PMID: 2402325. 10.1159/000110764 2402325
146 Galvin JE, Roe CM, Powlishta KK, . The AD8: a brief informant interview to detect dementia. Neurology. 2005;65(4):559–64. PMID: 16116116. 10.1212/01.wnl.0000172958.95282.2a 16116116
147 Grut M, Fratiglioni L, Viitanen M, . Accuracy of the Mini-Mental Status Examination as a screening test for dementia in a Swedish elderly population. Acta Neurol Scand. 1993;87(4):312–7. PMID: 8503262. 10.1111/j.1600-0404.1993.tb05514.x 8503262
148 Heun R, Papassotiropoulos A, Jennssen F. The validity of psychometric instruments for detection of dementia in the elderly general population. Int J Geriatr Psychiatry. 1998;13(6):368–80. PMID: 9658272.9658272
149 Holsinger T, Plassman BL, Stechuchak KM, . Screening for Cognitive Impairment: Comparing the Performance of Four Instruments in Primary Care. J Am Geriatr Soc. 2012;60(6):1027–36. PMID: 22646750. 10.1111/j.1532-5415.2012.03967.x 22646750
150 Hooijer C, Dinkgreve M, Jonker C, . Short screening tests for dementia in the elderly population. I. A comparison between AMTS, MMSE, MSQ and SPMSQ. Int J Geriatr Psychiatry. 1992;7(8):559–71. PMID: None. 10.1002/gps.930070805
151 Hsu JL, Fan YC, Huang YL, . Improved predictive ability of the Montreal Cognitive Assessment for diagnosing dementia in a community-based study. Alzheimers Res Ther. 2015;7(1):69. PMID: 26549573. 10.1186/s13195-015-0156-8 26549573
152 Jeong SK, Cho KH, Kim JM. The usefulness of the Korean version of modified Mini-Mental State Examination (K-mMMSE) for dementia screening in community dwelling elderly people. BMC Public Health. 2004;4:31. PMID: 15283869. 10.1186/1471-2458-4-31 15283869
153 Jorm AF, Broe GA, Creasy H, . Further data on the validity of the informant questionnaire on cognitive decline in the elderly (IQCODE). Int J Geriatr Psychiatry. 1996;11(2):131–9. PMID: None. 10.1002/(SICI)1099-1166(199602)11:2<131::AID-GPS294>3.0.CO;2-5
154 Juva K, Makela M, Erkinjuntti T, . Functional assessment scales in detecting dementia. Age Ageing. 1997;26(5):393–400. PMID: 9351484.9351484
155 Kahle-Wrobleski K, Corrada MM, Li B, . Sensitivity and specificity of the mini-mental state examination for identifying dementia in the oldest-old: the 90+ study. J Am Geriatr Soc. 2007;55(2):284–9. PMID: 17302668. 10.1111/j.1532-5415.2007.01049.x 17302668
156 Kaufer DI, Williams CS, Braaten AJ, . Cognitive screening for dementia and mild cognitive impairment in assisted living: comparison of 3 tests. J Am Med Dir Assoc. 2008;9(8):586–93. PMID: 19083293. 10.1016/j.jamda.2008.05.006 19083293
157 Kay DW, Henderson AS, Scott R, . Dementia and depression among the elderly living in the Hobart community: the effect of the diagnostic criteria on the prevalence rates. Psychol Med. 1985;15(4):771–88. PMID: 4080881.4080881
158 Kirby M, Denihan A, Bruce I, . The clock drawing test in primary care: sensitivity in dementia detection and specificity against normal and depressed elderly. Int J Geriatr Psychiatry. 2001;16(10):935–40. PMID: 11607936.11607936
159 Kuslansky G, Buschke H, Katz M, . Screening for Alzheimer’s disease: the memory impairment screen versus the conventional three-word memory test. J Am Geriatr Soc. 2002;50(6):1086–91. PMID: 12110070. 10.1046/j.1532-5415.2002.50265.x 12110070
160 Lam LC, Tam CW, Lui VW, . Screening of mild cognitive impairment in Chinese older adults--a multistage validation of the Chinese abbreviated mild cognitive impairment test. Neuroepidemiology. 2008;30(1):6–12. PMID: 18204291. 10.1159/000113300 18204291
161 Lee JY, Dong WL, Cho SJ, . Brief screening for mild cognitive impairment in elderly outpatient clinic: validation of the Korean version of the Montreal Cognitive Assessment. J Geriatr Psychiatry Neurol. 2008;21(2):104–10. PMID: 18474719. 10.1177/0891988708316855 18474719
162 Lee KS, Kim EA, Hong CH, . Clock drawing test in mild cognitive impairment: quantitative analysis of four scoring methods and qualitative analysis. Dement Geriatr Cogn Disord. 2008;26(6):483–9. PMID: 18987468. 10.1159/000167879 18987468
163 Lipton RB, Katz MJ, Kuslansky G, . Screening for dementia by telephone using the memory impairment screen. J Am Geriatr Soc. 2003;51(10):1382–90. PMID: 14511157. 10.1046/j.1532-5415.2003.51455.x 14511157
164 Manly JJ, Schupf N, Stern Y, . Telephone-based identification of mild cognitive impairment and dementia in a multicultural cohort. Arch Neurol. 2011;68(5):607–14. PMID: 21555635. 10.1001/archneurol.2011.88 21555635
165 Markwick A, Zamboni G, de Jager CA. Profiles of cognitive subtest impairment in the Montreal Cognitive Assessment (MoCA) in a research cohort with normal Mini-Mental State Examination (MMSE) scores. J Clin Exp Neuropsychol. 2012;34(7):750–7. PMID: 22468719. 10.1080/13803395.2012.672966 22468719
166 McDowell I, Kristjansson B, Hill GB, . Community screening for dementia: the Mini Mental State Exam (MMSE) and Modified Mini-Mental State Exam (3MS) compared. J Clin Epidemiol. 1997;50(4):377–83. PMID: 9179095. 10.1016/S0895-4356(97)00060-7 9179095
167 Morales JM, Bermejo F, Romero M, . Screening of dementia in community-dwelling elderly through informant report. Int J Geriatr Psychiatry. 1997;12(8):808–16. PMID: 9283925.9283925
168 Ozer S, Noonan K, Burke M, . The validity of the Memory Alteration Test and the Test Your Memory test for community-based identification of amnestic mild cognitive impairment. Alzheimers Dement. 2016;12(9):987–95. PMID: 27149906. 10.1016/j.jalz.2016.03.014 27149906
169 Rait G, Burns A, Baldwin R, . Validating screening instruments for cognitive impairment in older South Asians in the United Kingdom. Int J Geriatr Psychiatry. 2000;15(1):54–62. PMID: 10637405.10637405
170 Rait G, Morley M, Burns A, . Screening for cognitive impairment in older African-Caribbeans. Psychol Med. 2000;30(4):957–63. PMID: 11037103.11037103
171 Reischies FM, Geiselmann B. Age-related cognitive decline and vision impairment affecting the detection of dementia syndrome in old age. Br J Psychiatry. 1997;171:449–51. PMID: 9463604. 10.1192/bjp.171.5.449 9463604
172 Rideaux T, Beaudreau SA, Fernandez S, . Utility of the abbreviated Fuld Object Memory Evaluation and MMSE for detection of dementia and cognitive impairment not dementia in diverse ethnic groups. J Alzheimers Dis. 2012;31(2):371–86. PMID: 22555374. 10.3233/JAD-2012-112180 22555374
173 Saxton J, Morrow L, Eschman A, . Computer assessment of mild cognitive impairment. Postgrad Med. 2009;121(2):177–85. PMID: 19332976. 10.3810/pgm.2009.03.1990 19332976
174 Solomon PR, Brush M, Calvo V, . Identifying dementia in the primary care practice. Int Psychogeriatr. 2000;12(4):483–93. PMID: 11263715.11263715
175 Stein J, Luppa M, Kaduszkiewicz H, . Is the Short Form of the Mini-Mental State Examination (MMSE) a better screening instrument for dementia in older primary care patients than the original MMSE? Results of the German study on ageing, cognition, and dementia in primary care patients (AgeCoDe). Psychol Assess. 2015;27(3):895–904. PMID: 25822830. 10.1037/pas0000076 25822830
176 Swearer JM, Drachman DA, Li L, . Screening for dementia in “real world” settings: the cognitive assessment screening test: CAST. Clin Neuropsychol. 2002;16(2):128–35. PMID: 12221476. 10.1076/clin.16.2.128.13235 12221476
177 Tariq SH, Tumosa N, Chibnall JT, . Comparison of the Saint Louis University mental status examination and the mini-mental state examination for detecting dementia and mild neurocognitive disorder--a pilot study. Am J Geriatr Psychiatry. 2006;14(11):900–10. PMID: 17068312. 10.1097/01.JGP.0000221510.33817.86 17068312
178 Tokuhara KG, Valcour VG, Masaki KH, . Utility of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) for dementia in a Japanese-American population. Hawaii Med J. 2006;65(3):72–5. PMID: 16724448.16724448
179 Vannier-Nitenberg C, Dauphinot V, Bongue B, . Performance of cognitive tests, individually and combined, for the detection of cognitive disorders amongst community-dwelling elderly people with memory complaints: the EVATEM study. Eur J Neurol. 2016;23(3):554–61. PMID: 26518736. 10.1111/ene.12888 26518736
180 Vercambre MN, Cuvelier H, Gayon YA, . Validation study of a French version of the modified telephone interview for cognitive status (F-TICS-m) in elderly women. Int J Geriatr Psychiatry. 2010;25(11):1142–9. PMID: 20054838. 10.10002/gps.2447 20054838
181 Waite LM, Broe GA, Casey B, . Screening for Dementia Using an Informant Interview. Neuropsychology, development, and cognition Section B, Aging, neuropsychology and cognition. 1998;5(3):194–202. PMID: 25233059. 10.1076/anec.5.3.194.614 25233059
182 Wolf-Klein GP, Silverstone FA, Levy AP, . Screening for Alzheimer’s disease by clock drawing. J Am Geriatr Soc. 1989;37(8):730–4. PMID: 2754158. 10.1111/j.1532-5415.1989.tb02234.x 2754158
183 McKhann G, Drachman D, Folstein M, . Clinical diagnosis of Alzheimer’s disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer’s Disease. Neurology. 1984;34(7):939–44. PMID: 6610841.6610841
184 Roman GC, Tatemichi TK, Erkinjuntti T, . Vascular dementia: diagnostic criteria for research studies. Report of the NINDS-AIREN International Workshop. Neurology. 1993;43(2):250–60. PMID: 8094895.8094895
185 Petersen RC. Mild cognitive impairment as a diagnostic entity. J Intern Med. 2004;256(3):183–94. PMID: 15324362. 10.1111/j.1365-2796.2004.01388.x 15324362
186 Black S, Roman GC, Geldmacher DS, . Efficacy and tolerability of donepezil in vascular dementia: positive results of a 24-week, multicenter, international, randomized, placebo-controlled clinical trial. Stroke. 2003;34(10):2323–30. PMID: 12970516. 10.1161/01.STR.0000091396.95360.E1 12970516
187 Burns A, Rossor M, Hecker J, . The effects of donepezil in Alzheimer’s disease - results from a multinational trial. Dement Geriatr Cogn Disord. 1999;10(3):237–44. PMID: 10325453. 10.1159/000017126 10325453
188 Doody RS, Ferris SH, Salloway S, . Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. 2009;72(18):1555–61. PMID: 19176895. 10.1212/01.wnl.0000344650.95823.03 19176895
189 Feldman H, Gauthier S, Hecker J, . A 24-week, randomized, double-blind study of donepezil in moderate to severe Alzheimer’s disease.[Erratum appears in Neurology 2001 Dec 11;57(11):2153]. Neurology. 2001;57(4):613–20. PMID: 11524468. 10.1212/WNL.57.4.613 11524468
190 Holmes C, Wilkinson D, Dean C, . The efficacy of donepezil in the treatment of neuropsychiatric symptoms in Alzheimer disease. Neurology. 2004;63(2):214–9. PMID: 15277611. 10.1212/01.WNL.0000129990.32253.7B 15277611
191 Ikeda M, Mori E, Matsuo K, . Donepezil for dementia with Lewy bodies: a randomized, placebo-controlled, confirmatory phase III trial. Alzheimers Res Ther. 2015;7(1):4. PMID: 25713599. 10.1186/s13195-014-0083-0 25713599
192 Krishnan KR, Charles HC, Doraiswamy PM, . Randomized, placebo-controlled trial of the effects of donepezil on neuronal markers and hippocampal volumes in Alzheimer’s disease. Am J Psychiatry. 2003;160(11):2003–11. PMID: 14594748. 10.1176/appi.ajp.160.11.2003 14594748
193 Mazza M, Capuano A, Bria P, . Ginkgo biloba and donepezil: a comparison in the treatment of Alzheimer’s dementia in a randomized placebo-controlled double-blind study. Eur J Neurol. 2006;13(9):981–5. PMID: 16930364. 10.1111/j.1468-1331.2006.01409.x 16930364
194 Mohs RC, Doody RS, Morris JC, . A 1-year, placebo-controlled preservation of function survival study of donepezil in AD patients. Neurology. 2001;57(3):481–8. PMID: 11502917. 10.1212/WNL.57.3.481 11502917
195 Mori E, Ikeda M, Kosaka K. Donepezil for dementia with Lewy bodies: a randomized, placebo-controlled trial. Ann Neurol. 2012;72(1):41–52. PMID: 22829268. 10.1002/ana.23557 22829268
196 Petersen RC, Thomas RG, Grundman M, . Vitamin E and donepezil for the treatment of mild cognitive impairment. NEJM. 2005;352(23):2379–88. PMID: 15829527. 10.1056/NEJMoa050151 15829527
197 Rogers SL, Doody RS, Mohs RC, . Donepezil improves cognition and global function in Alzheimer disease: a 15-week, double-blind, placebo-controlled study. Donepezil Study Group. Arch Intern Med. 1998;158(9):1021–31. PMID: 9588436. 10.1001/archinte.158.9.1021 9588436
198 Rogers SL, Friedhoff LT. The efficacy and safety of donepezil in patients with Alzheimer’s disease: results of a US Multicentre, Randomized, Double-Blind, Placebo-Controlled Trial. The Donepezil Study Group. Dementia. 1996;7(6):293–303. PMID: 8915035. 10.1159/000106895 8915035
199 Salloway S, Ferris S, Kluger A, . Efficacy of donepezil in mild cognitive impairment: a randomized placebo-controlled trial. Neurology. 2004;63(4):651–7. PMID: 15326237. 10.1212/01.WNL.0000134664.80320.92 15326237
200 Seltzer B, Zolnouni P, Nunez M, . Efficacy of donepezil in early-stage Alzheimer disease: a randomized placebo-controlled trial. Arch Neurol. 2004;61(12):1852–6. PMID: 15596605. 10.1001/archneur.61.12.1852 15596605
201 Tune L, Tiseo PJ, Ieni J, . Donepezil HCl (E2020) maintains functional brain activity in patients with Alzheimer disease: results of a 24-week, double-blind, placebo-controlled study. Am J Geriatr Psychiatry. 2003;11(2):169–77. PMID: 12611746. 10.1097/00019442-200303000-00007 12611746
202 Wilkinson D, Doody R, Helme R, . Donepezil in vascular dementia: A randomized, placebo-controlled study. Neurology. 2003;61(4):479–86. PMID: 12939421. 10.1212/01.WNL.0000078943.50032.FC 12939421
203 Winblad B, Engedal K, Soininen H, . A 1-year, randomized, placebo-controlled study of donepezil in patients with mild to moderate AD. Neurology. 2001;57(3):489–95. PMID: 11502918. 10.1212/WNL.57.3.489 11502918
204 Auchus AP, Brashear HR, Salloway S, . Galantamine treatment of vascular dementia: a randomized trial. Neurology. 2007;69(5):448–58. PMID: 17664404. 10.1212/01.wnl.0000266625.31615.f6 17664404
205 Brodaty H, Corey-Bloom J, Potocnik FC, . Galantamine prolonged-release formulation in the treatment of mild to moderate Alzheimer’s disease. Dement Geriatr Cogn Disord. 2005;20(2–3):120–32. PMID: 15990426. 10.1159/000086613 15990426
206 Erkinjuntti T, Kurz A, Gauthier S, . Efficacy of galantamine in probable vascular dementia and Alzheimer’s disease combined with cerebrovascular disease: a randomised trial. Lancet. 2002;359(9314):1283–90. PMID: 11965273. 10.1016/S0140-6736(02)08267-3 11965273
207 Hager K, Baseman A, Nye J, . Effects of galantamine in a 2-year, randomized, placebo-controlled study in Alzheimer’s disease. Neuropsychiatr Dis Treat. 2014;10:391–401. PMID: 24591834. 10.2147/NDT.S57909 24591834
208 Raskind MA, Peskind ER, Wessel T, . Galantamine in AD: A 6-month randomized, placebo-controlled trial with a 6-month extension. The Galantamine USA-1 Study Group. Neurology. 2000;54(12):2261–8. PMID: 10881250. 10.1212/WNL.54.12.2261 10881250
209 Rockwood K, Fay S, Song X, . Attainment of treatment goals by people with Alzheimer’s disease receiving galantamine: a randomized controlled trial. CMAJ. 2006;174(8):1099–105. PMID: 16554498. 10.1503/cmaj.051432 16554498
210 Rockwood K, Mintzer J, Truyen L, . Effects of a flexible galantamine dose in Alzheimer’s disease: a randomised, controlled trial. J Neurol Neurosurg Psychiatry. 2001;71(5):589–95. PMID: 11606667. 10.1136/jnnp.71.5.589 11606667
211 Tariot PN, Solomon PR, Morris JC, . A 5-month, randomized, placebo-controlled trial of galantamine in AD. The Galantamine USA-10 Study Group. Neurology. 2000;54(12):2269–76. PMID: 10881251. 10.1212/WNL.54.12.2269 10881251
212 Wilcock GK, Lilienfeld S, Gaens E. Efficacy and safety of galantamine in patients with mild to moderate Alzheimer’s disease: multicentre randomised controlled trial. Galantamine International-1 Study Group.[Erratum appears in BMJ 2001 Feb 17;322(7283):405]. BMJ. 2000;321(7274):1445–9. PMID: 11110737. 10.1136/bmj.321.7274.1445 11110737
213 Wilkinson D, Murray J. Galantamine: a randomized, double-blind, dose comparison in patients with Alzheimer’s disease. Int J Geriatr Psychiatry. 2001;16(9):852–7. PMID: 11571763. 10.1002/gps.409 11571763
214 Agid Y, Dubois B, Anand R, . Efficacy and tolerability of rivastigmine in patients with dementia of the Alzheimer type. Curr Ther Res Clin Exp. 1998;59:837–45. PMID: None. 10.1016/S0011-393X(98)85048-0
215 Ballard C, Sauter M, Scheltens P, . Efficacy, safety and tolerability of rivastigmine capsules in patients with probable vascular dementia: the VantagE study. Curr Med Res Opin. 2008;24(9):2561–74. PMID: 18674411. 10.1185/03007990802328142 18674411
216 Corey-Bloom J, Anand R, Veach J. A randomized trial evaluating the efficacy and safety of ENA 713 (rivastigmine tartrate), a new acetylcholinesterase inhibitor, in patients with mild to moderately severe Alzheimer’s disease. Int J Geriatr Psychopharmacol. 1998;1(2):55–65. PMID: None.
217 Feldman HH, Lane R, Group S. Rivastigmine: a placebo controlled trial of twice daily and three times daily regimens in patients with Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 2007;78(10):1056–63. PMID: 17353259. 10.1136/jnnp.2006.099424 17353259
218 McKeith I, Del Ser T, Spano P, . Efficacy of rivastigmine in dementia with Lewy bodies: a randomised, double-blind, placebo-controlled international study. Lancet. 2000;356(9247):2031–6. PMID: 11145488. 10.1016/S0140-6736(00)03399-7 11145488
219 Mok V, Wong A, Ho S, . Rivastigmine in Chinese patients with subcortical vascular dementia. Neuropsychiatr Dis Treat. 2007;3(6):943–8. PMID: 19300631. 10.2147/NDT.S2221 19300631
220 Rosler M, Anand R, Cicin-Sain A, . Efficacy and safety of rivastigmine in patients with Alzheimer’s disease: international randomised controlled trial.[Erratum appears in BMJ 2001 Jun 16;322(7300):1456]. BMJ. 1999;318(7184):633–8. PMID: 10066203. 10.1136/bmj.318.7184.633 10066203
221 Winblad B, Cummings J, Andreasen N, . A six-month double-blind, randomized, placebo-controlled study of a transdermal patch in Alzheimer’s disease--rivastigmine patch versus capsule. Int J Geriatr Psychiatry. 2007;22(5):456–67. PMID: 17380489. 10.1002/gps.1788 17380489
222 Bakchine S, Loft H. Memantine treatment in patients with mild to moderate Alzheimer’s disease: results of a randomised, double-blind, placebo-controlled 6-month study.[Republished from J Alzheimers Dis. 2007 Jul;11(4):471–9; PMID: 17656827]. J Alzheimers Dis. 2008;13(1):97–107. PMID: 18334761. 10.3233/JAD-2008-13110 18334761
223 Choi SH, Park KW, Na DL, . Tolerability and efficacy of memantine add-on therapy to rivastigmine transdermal patches in mild to moderate Alzheimer’s disease: a multicenter, randomized, open-label, parallel-group study. Curr Med Res Opin. 2011;27(7):1375–83. PMID: 21561398. 10.1185/03007995.2011.582484 21561398
224 Dysken MW, Sano M, Asthana S, . Effect of vitamin E and memantine on functional decline in Alzheimer disease: the TEAM-AD VA cooperative randomized trial. JAMA. 2014;311(1):33–44. PMID: 24381967. 10.1001/jama.2013.282834 24381967
225 Ferris S, Schneider L, Farmer M, . A double-blind, placebo-controlled trial of memantine in age-associated memory impairment (memantine in AAMI). Int J Geriatr Psychiatry. 2007;22(5):448–55. PMID: 17117395. 10.1002/gps.1711 17117395
226 Herrmann N, Gauthier S, Boneva N, . A randomized, double-blind, placebo-controlled trial of memantine in a behaviorally enriched sample of patients with moderate-to-severe Alzheimer’s disease. Int Psychogeriatr. 2013;25(6):919–27. PMID: 23472619. 10.1017/S1041610213000239 23472619
227 Orgogozo JM, Rigaud AS, Stoffler A, . Efficacy and safety of memantine in patients with mild to moderate vascular dementia: a randomized, placebo-controlled trial (MMM 300). Stroke. 2002;33(7):1834–9. PMID: 12105362. 10.1161/01.STR.0000020094.08790.49 12105362
228 Peskind ER, Potkin SG, Pomara N, . Memantine treatment in mild to moderate Alzheimer disease: a 24-week randomized, controlled trial. Am J Geriatr Psychiatry. 2006;14(8):704–15. PMID: 16861375. 10.1097/01.JGP.0000224350.82719.83 16861375
229 Peters O, Fuentes M, Joachim L, . Combined treatment with memantine and galantamine-CR compared with galantamine-CR only in antidementia drug naive patients with mild-to-moderate Alzheimer’s disease. Alzheimers Dement (N Y). 2015;1(3):198–204. PMID: 29854939. 10.1016/j.trci.2015.10.001 29854939
230 Porsteinsson AP, Grossberg GT, Mintzer J, . Memantine treatment in patients with mild to moderate Alzheimer’s disease already receiving a cholinesterase inhibitor: a randomized, double-blind, placebo-controlled trial. Curr Alzheimer Res. 2008;5(1):83–9. PMID: 18288936. 10.2174/156720508783884576 18288936
231 Saxton J, Hofbauer RK, Woodward M, . Memantine and functional communication in Alzheimer’s disease: results of a 12-week, international, randomized clinical trial. J Alzheimers Dis. 2012;28(1):109–18. PMID: 21955815. 10.3233/JAD-2011-110947 21955815
232 Wilcock G, Mobius HJ, Stoffler A. A double-blind, placebo-controlled multicentre study of memantine in mild to moderate vascular dementia (MMM500). Int Clin Psychopharmacol. 2002;17(6):297–305. PMID: 12409683. 10.1212/WNL.54.12.2269 12409683
233 Wilkinson D, Fox NC, Barkhof F, . Memantine and brain atrophy in Alzheimer’s disease: a 1-year randomized controlled trial. J Alzheimers Dis. 2012;29(2):459–69. PMID: 22269160. 10.3233/JAD-2011-111616 22269160
234 Gill SS, Anderson GM, Fischer HD, . Syncope and its consequences in patients with dementia receiving cholinesterase inhibitors: a population-based cohort study. Arch Intern Med. 2009;169(9):867–73. PMID: 19433698. 10.1001/archinternmed.2009.43 19433698
235 Hernandez RK, Farwell W, Cantor MD, . Cholinesterase inhibitors and incidence of bradycardia in patients with dementia in the veterans affairs new England healthcare system. J Am Geriatr Soc. 2009;57(11):1997–2003. PMID: 19793162. 10.1111/j.1532-5415.2009.02488.x 19793162
236 Thavorn K, Gomes T, Camacho X, . Upper gastrointestinal bleeding in elderly adults with dementia receiving cholinesterase inhibitors: a population-based cohort study. J Am Geriatr Soc. 2014;62(2):382–4. PMID: 24521369. 10.1111/jgs.12670 24521369
237 Moonen JE, Foster-Dingley JC, de Ruijter W, . Effect of Discontinuation of Antihypertensive Treatment in Elderly People on Cognitive Functioning--the DANTE Study Leiden: A Randomized Clinical Trial.[Erratum appears in JAMA Intern Med. 2016 Feb;176(2):284; PMID: 26830247]. JAMA Intern Med. 2015;175(10):1622–30. PMID: 26301603. 10.1001/jamainternmed.2015.4103 26301603
238 Feldman HH, Doody RS, Kivipelto M, . Randomized controlled trial of atorvastatin in mild to moderate Alzheimer disease: LEADe. Neurology. 2010;74(12):956–64. PMID: 20200346. 10.1212/WNL.0b013e3181d6476a 20200346
239 Sano M, Bell KL, Galasko D, . A randomized, double-blind, placebo-controlled trial of simvastatin to treat Alzheimer disease. Neurology. 2011;77(6):556–63. PMID: 21795660. 10.1212/WNL.0b013e318228bf11 21795660
240 Simons M, Schwarzler F, Lutjohann D, . Treatment with simvastatin in normocholesterolemic patients with Alzheimer’s disease: A 26-week randomized, placebo-controlled, double-blind trial. Ann Neurol. 2002;52(3):346–50. PMID: 12205648. 10.1002/ana.10292 12205648
241 Sparks DL, Sabbagh MN, Connor DJ, . Atorvastatin for the treatment of mild to moderate Alzheimer disease: preliminary results. Arch Neurol. 2005;62(5):753–7. PMID: 15883262. 10.1001/archneur.62.5.753 15883262
242 Aisen PS, Schafer KA, Grundman M, . Effects of rofecoxib or naproxen vs placebo on Alzheimer disease progression: a randomized controlled trial. JAMA. 2003;289(21):2819–26. PMID: 12783912. 10.1001/jama.289.21.2819 12783912
243 de Jong D, Jansen R, Hoefnagels W, . No effect of one-year treatment with indomethacin on Alzheimer’s disease progression: a randomized controlled trial. PLoS One. 2008;3(1):e1475. PMID: 18213383. 10.1371/journal.pone.0001475 18213383
244 Pasqualetti P, Bonomini C, Dal Forno G, . A randomized controlled study on effects of ibuprofen on cognitive progression of Alzheimer’s disease. Aging Clin Exp Res. 2009;21(2):102–10. PMID: 19448381.19448381
245 Soininen H, West C, Robbins J, . Long-term efficacy and safety of celecoxib in Alzheimer’s disease. Dement Geriatr Cogn Dis. 2007;23(1):8–21. PMID: 17068392. 10.1159/000096588 17068392
246 Henderson VW, Ala T, Sainani KL, . Raloxifene for women with Alzheimer disease: A randomized controlled pilot trial. Neurology. 2015;85(22):1937–44. PMID: 26537053. 10.1212/WNL.0000000000002171 26537053
247 Henderson VW, Paganini-Hill A, Miller BL, . Estrogen for Alzheimer’s disease in women: randomized, double-blind, placebo-controlled trial. Neurology. 2000;54(2):295–301. PMID: 10668686. 10.1212/WNL.54.2.295 10668686
248 Lu PH, Masterman DA, Mulnard R, . Effects of testosterone on cognition and mood in male patients with mild Alzheimer disease and healthy elderly men. Arch Neurol. 2006;63(2):177–85. PMID: 16344336. 10.1001/archneur.63.2.nct50002 16344336
249 Mulnard RA, Cotman CW, Kawas C, . Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: A randomized controlled trial [Erratum appears in JAMA 2000 Nov 22–29;284(20):2597]. JAMA. 2000;283(8):1007–15. PMID: 10697060. 10.1001/jama.283.8.1007 10697060
250 Valen-Sendstad A, Engedal K, Stray-Pedersen B, . Effects of hormone therapy on depressive symptoms and cognitive functions in women with Alzheimer disease: a 12 month randomized, double-blind, placebo-controlled study of low-dose estradiol and norethisterone. Am J Geriatr Psychiatry. 2010;18(1):11–20. PMID: 20094015. 10.1097/JGP.0b013e3181beaaf4 20094015
251 Wang PN, Liao SQ, Liu RS, . Effects of estrogen on cognition, mood, and cerebral blood flow in AD: a controlled study. Neurology. 2000;54(11):2061–6. PMID: 10851363. 10.1212/WNL.54.11.2061 10851363
252 Aisen PS, Schneider LS, Sano M, . High-dose B vitamin supplementation and cognitive decline in Alzheimer disease: a randomized controlled trial. JAMA. 2008;300(15):1774–83. PMID: 18854539. 10.1001/jama.300.15.1774 18854539
253 Connelly PJ, Prentice NP, Cousland G, . A randomised double-blind placebo-controlled trial of folic acid supplementation of cholinesterase inhibitors in Alzheimer’s disease. Int J Geriatr Psychiatry. 2008;23(2):155–60. PMID: 17600848. 10.1002/gps.1856 17600848
254 de Jager CA, Oulhaj A, Jacoby R, . Cognitive and clinical outcomes of homocysteine-lowering B-vitamin treatment in mild cognitive impairment: a randomized controlled trial. Int J Geriatr Psychiatry. 2012;27(6):592–600. PMID: 21780182. 10.1002/gps.2758 21780182
255 Freund-Levi Y, Eriksdotter-Jonhagen M, Cederholm T, . Omega-3 fatty acid treatment in 174 patients with mild to moderate Alzheimer disease: OmegAD study: a randomized double-blind trial. Arch Neurol. 2006;63(10):1402–8. PMID: 17030655. 10.1001/archneur.63.10.1402 17030655
256 Kwok T, Lee J, Law CB, . A randomized placebo controlled trial of homocysteine lowering to reduce cognitive decline in older demented people. Clinical nutrition (Edinburgh, Scotland). 2011;30(3):297–302. PMID: 21216507. 10.1016/j.clnu.2010.12.004 21216507
257 Phillips MA, Childs CE, Calder PC, . No Effect of Omega-3 Fatty Acid Supplementation on Cognition and Mood in Individuals with Cognitive Impairment and Probable Alzheimer’s Disease: A Randomised Controlled Trial. Int J Mol Sci. 2015;16(10):24600–13. PMID: 26501267. 10.3390/ijms161024600 26501267
258 Quinn JF, Raman R, Thomas RG, . Docosahexaenoic acid supplementation and cognitive decline in Alzheimer disease: a randomized trial. JAMA. 2010;304(17):1903–11. PMID: 21045096. 10.1001/jama.2010.1510 21045096
259 Sano M, Ernesto C, Thomas RG, . A controlled trial of selegiline, alpha-tocopherol, or both as treatment for Alzheimer’s disease. The Alzheimer’s Disease Cooperative Study. NEJM. 1997;336(17):1216–22. PMID: 9110909. 10.1056/NEJM199704243361704 9110909
260 Shinto L, Quinn J, Montine T, . A randomized placebo-controlled pilot trial of omega-3 fatty acids and alpha lipoic acid in Alzheimer’s disease. J Alzheimers Dis. 2014;38(1):111–20. PMID: 24077434. 10.3233/JAD-130722 24077434
261 Sinn N, Milte CM, Street SJ, . Effects of n-3 fatty acids, EPA v. DHA, on depressive symptoms, quality of life, memory and executive function in older adults with mild cognitive impairment: a 6-month randomised controlled trial. Br J Nutr. 2012;107(11):1682–93. PMID: 21929835. 10.1017/S0007114511004788 21929835
262 Sun Y, Lu CJ, Chien KL, . Efficacy of multivitamin supplementation containing vitamins B6 and B12 and folic acid as adjunctive treatment with a cholinesterase inhibitor in Alzheimer’s disease: a 26-week, randomized, double-blind, placebo-controlled study in Taiwanese patients. Clin Ther. 2007;29(10):2204–14. PMID: 18042476. 10.1016/j.clinthera.2007.10.012 18042476
263 Yurko-Mauro K, McCarthy D, Rom D, . Beneficial effects of docosahexaenoic acid on cognition in age-related cognitive decline. Alzheimers Dement. 2010;6(6):456–64. PMID: 20434961. 10.1016/j.jalz.2010.01.013 20434961
264 Troyer AK, Murphy KJ, Anderson ND, . Changing everyday memory behaviour in amnestic mild cognitive impairment: a randomised controlled trial. Neuropsychol Rehabil. 2008;18(1):65–88. PMID: 17943615. 10.1080/09602010701409684 17943615
265 Tsolaki M, Kounti F, Agogiatou C, . Effectiveness of nonpharmacological approaches in patients with mild cognitive impairment. Neurodegener Dis. 2011;8(3):138–45. PMID: 21135531. 10.1159/000320575 21135531
266 Kinsella GJ, Mullaly E, Rand E, . Early intervention for mild cognitive impairment: a randomised controlled trial. J Neurol Neurosurg Psychiatry. 2009;80(7):730–6. PMID: 19332424. 10.1136/jnnp.2008.148346 19332424
267 Olazaran J, Muniz R, Reisberg B, . Benefits of cognitive-motor intervention in MCI and mild to moderate Alzheimer disease. Neurology. 2004;63(12):2348–53. PMID: 15623698. 10.1212/01.WNL.0000147478.03911.28 15623698
268 Chapman SB, Weiner MF, Rackley A, . Effects of cognitive-communication stimulation for Alzheimer’s disease patients treated with donepezil. J Speech Lang Hear Res. 2004;47(5):1149–63. PMID: 15603468. 10.1044/1092-4388(2004/085) 15603468
269 Cahn-Weiner DA, Malloy PF, Rebok GW, . Results of a randomized placebo-controlled study of memory training for mildly impaired Alzheimer’s disease patients. Appl Neuropsychol. 2003;10(4):215–23. PMID: 14690802. 10.1207/s15324826an1004_3 14690802
270 Rapp S, Brenes G, Marsh AP. Memory enhancement training for older adults with mild cognitive impairment: a preliminary study. Aging Ment Health. 2002;6(1):5–11. PMID: 11827617. 10.1080/13607860120101077 11827617
271 Buschert VC, Friese U, Teipel SJ, . Effects of a newly developed cognitive intervention in amnestic mild cognitive impairment and mild Alzheimer’s disease: a pilot study. J Alzheimers Dis. 2011;25(4):679–94. PMID: 21483095. 10.3233/JAD-2011-100999 21483095
272 Quayhagen MP, Quayhagen M, Corbeil RR, . A dyadic remediation program for care recipients with dementia. Nurs Res. 1995;44(3):153–9. PMID: 7761291.7761291
273 Greenaway MC, Duncan NL, Smith GE. The memory support system for mild cognitive impairment: randomized trial of a cognitive rehabilitation intervention. Int J Geriatr Psychiatry. 2012. PMID: 22678947. 10.1002/gps.3838 22678947
274 Kurz A, Thone-Otto A, Cramer B, . CORDIAL: cognitive rehabilitation and cognitive-behavioral treatment for early dementia in Alzheimer disease: a multicenter, randomized, controlled trial. Alzheimer Dis Assoc Disord. 2012;26(3):246–53. PMID: 21986341. 10.1097/WAD.0b013e318231e46e 21986341
275 Orrell M, Yates L, Leung P, . The impact of individual Cognitive Stimulation Therapy (iCST) on cognition, quality of life, caregiver health, and family relationships in dementia: A randomised controlled trial. PLoS Med. 2017;14(3):e1002269. PMID: 28350796. 10.1371/journal.pmed.1002269 28350796
276 Jeong JH, Na HR, Choi SH, . Group- and Home-Based Cognitive Intervention for Patients with Mild Cognitive Impairment: A Randomized Controlled Trial. Psychother Psychosom. 2016;85(4):198–207. PMID: 27230861. 10.1159/000442261 27230861
277 Amieva H, Robert PH, Grandoulier AS, . Group and individual cognitive therapies in Alzheimer’s disease: the ETNA3 randomized trial. Int Psychogeriatr. 2016;28(5):707–17. PMID: 26572551. 10.1017/S1041610215001830 26572551
278 Vidovich MR, Lautenschlager NT, Flicker L, . The PACE study: a randomized clinical trial of cognitive activity strategy training for older people with mild cognitive impairment. Am J Geriatr Psychiatry. 2015;23(4):360–72. PMID: 24801607. 10.1016/j.jagp.2014.04.002 24801607
279 Cove J, Jacobi N, Donovan H, . Effectiveness of weekly cognitive stimulation therapy for people with dementia and the additional impact of enhancing cognitive stimulation therapy with a carer training program. Clin Interv Aging. 2014;9:2143–50. PMID: 25525349. 10.2147/CIA.S66232 25525349
280 Fiatarone Singh MA, Gates N, Saigal N, . The Study of Mental and Resistance Training (SMART) study-resistance training and/or cognitive training in mild cognitive impairment: a randomized, double-blind, double-sham controlled trial. J Am Med Dir Assoc. 2014;15(12):873–80. PMID: 25444575. 10.1016/j.jamda.2014.09.010 25444575
281 Orrell M, Aguirre E, Spector A, . Maintenance cognitive stimulation therapy for dementia: single-blind, multicentre, pragmatic randomised controlled trial. Br J Psychiatry. 2014;204(6):454–61. PMID: 24676963. 10.1192/bjp.bp.113.137414 24676963
282 Bergamaschi S, Arcara G, Calza A, . One-year repeated cycles of cognitive training (CT) for Alzheimer’s disease. Aging Clin Exp Res. 2013;25(4):421–6. PMID: 23784727. 10.1007/s40520-013-0065-2 23784727
283 Herrera C, Chambon C, Michel BF, . Positive effects of computer-based cognitive training in adults with mild cognitive impairment. Neuropsychologia. 2012;50(8):1871–81. PMID: 22525705. 10.1016/j.neuropsychologia.2012.04.012 22525705
284 Jelcic N, Cagnin A, Meneghello F, . Effects of lexical-semantic treatment on memory in early Alzheimer disease: an observer-blinded randomized controlled trial. Neurorehabil Neural Repair. 2012;26(8):949–56. PMID: 22460609. 10.1177/1545968312440146 22460609
285 Tsantali E, Economidis D, Rigopoulou S. Testing the benefits of cognitive training vs. Cognitive stimulation in mild Alzheimer’s disease: A randomised controlled trial. Brain Impair. 2017;18(2):188–96. PMID: None. 10.1017/BrImp.2017.6
286 Cavallo M, Hunter EM, van der Hiele K, . Computerized structured cognitive training in patients affected by early-stage Alzheimer’s disease is feasible and effective: A randomized controlled study. Archives of clinical neuropsychology : the official journal of the National Academy of Neuropsychologists. 2016;31(8):868–76. PMID: 27600448. 10.1093/arclin/acw072 27600448
287 Hyer L, Scott C, Atkinson MM, . Cognitive training program to improve working memory in older adults with MCI. Clinical Gerontologist. 2016;39(5):410–27. PMID: 29471774. 10.1080/07317115.2015.1120257 29471774
288 Nousia A, Siokas V, Aretouli E, . Beneficial Effect of Multidomain Cognitive Training on the Neuropsychological Performance of Patients with Early-Stage Alzheimer’s Disease. Neural Plast. 2018;2018:2845176. PMID: 30123243. 10.1155/2018/2845176 30123243
289 Pantoni L, Poggesi A, Diciotti S, . Effect of Attention Training in Mild Cognitive Impairment Patients with Subcortical Vascular Changes: The RehAtt Study. J Alzheimers Dis. 2017;60(2):615–24. PMID: 28869475. 10.3233/JAD-170428 28869475
290 Kallio EL, Ohman H, Hietanen M, . Effects of Cognitive Training on Cognition and Quality of Life of Older Persons with Dementia. J Am Geriatr Soc. 2018;66(4):664–70. PMID: 29345724. 10.1111/jgs.15196 29345724
291 Belleville S, Hudon C, Bier N, . MEMO+: Efficacy, Durability and Effect of Cognitive Training and Psychosocial Intervention in Individuals with Mild Cognitive Impairment. J Am Geriatr Soc. 2018;66(4):655–63. PMID: 29313875. 10.1111/jgs.15192 29313875
292 Pitkälä KH, Pöysti MM, Laakkonen ML, . Effects of the Finnish Alzheimer disease exercise trial (FINALEX): a randomized controlled trial. JAMA Intern Med. 2013;173(10):894–901. PMID: 23589097. 10.1001/jamainternmed.2013.359 23589097
293 Liu-Ambrose T, Best JR, Davis JC, . Aerobic exercise and vascular cognitive impairment: A randomized controlled trial. Neurology. 2016;[Epub ahead of print]. PMID: 27760869. 10.1212/wnl.0000000000003332 27760869
294 Lautenschlager NT, Cox KL, Flicker L, . Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial.[Erratum appears in JAMA. 2009 Jan 21;301(3):276]. JAMA. 2008;300(9):1027–37. PMID: 18768414. 10.1001/jama.300.9.1027 18768414
295 Lam LC, Chau RC, Wong BM, . Interim follow-up of a randomized controlled trial comparing Chinese style mind body (Tai Chi) and stretching exercises on cognitive function in subjects at risk of progressive cognitive decline. Int J Geriatr Psychiatry. 2011;26(7):733–40. PMID: 21495078. 10.1002/gps.2602 21495078
296 Schwenk M, Zieschang T, Oster P, . Dual-task performances can be improved in patients with dementia: a randomized controlled trial. Neurology. 2010;74(24):1961–8. PMID: 20445152. 10.1212/WNL.0b013e3181e39696 20445152
297 Venturelli M, Lanza M, Muti E, . Positive effects of physical training in activity of daily living-dependent older adults. Exp Aging Res. 2010;36(2):190–205. PMID: 20209421. 10.1080/03610731003613771 20209421
298 Baker LD, Frank LL, Foster-Schubert K, . Effects of aerobic exercise on mild cognitive impairment: a controlled trial. Arch Neurol. 2010;67(1):71–9. PMID: 20065132. 10.1001/archneurol.2009.307 20065132
299 Suzuki T, Shimada H, Makizako H, . Effects of multicomponent exercise on cognitive function in WMS-LM older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. 2012;12(1):128. PMID: 23113898. 10.1186/1471-2377-12-128 23113898
300 Vreugdenhil A, Cannell J, Davies A, . A community-based exercise programme to improve functional ability in people with Alzheimer’s disease: a randomized controlled trial. Scand J Caring Sci. 2012;26(1):12–9. PMID: 21564154. 10.1111/j.1471-6712.2011.00895.x 21564154
301 Lazarou I, Parastatidis T, Tsolaki A, . International Ballroom Dancing Against Neurodegeneration: A Randomized Controlled Trial in Greek Community-Dwelling Elders With Mild Cognitive impairment. Am J Alzheimers Dis Other Demen. 2017:1533317517725813. PMID: 28840742. 10.1177/1533317517725813 28840742
302 Hong SG, Kim JH, Jun TW. Effects of 12-Week Resistance Exercise on Electroencephalogram Patterns and Cognitive Function in the Elderly With Mild Cognitive Impairment: A Randomized Controlled Trial. Clinical journal of sport medicine : official journal of the Canadian Academy of Sport Medicine. 2017. PMID: 28727639. 10.1097/jsm.0000000000000476 28727639
303 Morris JK, Vidoni ED, Johnson DK, . Aerobic exercise for Alzheimer’s disease: A randomized controlled pilot trial. PLoS One. 2017;12(2):e0170547. PMID: 28187125. 10.1371/journal.pone.0170547 28187125
304 Hoffmann K, Sobol NA, Frederiksen KS, . Moderate-to-High Intensity Physical Exercise in Patients with Alzheimer’s Disease: A Randomized Controlled Trial. J Alzheimers Dis. 2016;50(2):443–53. PMID: 26682695. 10.3233/JAD-150817 26682695
305 Holthoff VA, Marschner K, Scharf M, . Effects of physical activity training in patients with Alzheimer’s dementia: results of a pilot RCT study. PLoS One. 2015;10(4):e0121478. PMID: 25884637. 10.1371/journal.pone.0121478 25884637
306 Doi T, Verghese J, Makizako H, . Effects of Cognitive Leisure Activity on Cognition in Mild Cognitive Impairment: Results of a Randomized Controlled Trial. J Am Med Dir Assoc. 2017;18(8):686–91. PMID: 28396179. 10.1016/j.jamda.2017.02.013 28396179
307 Dawson NT. Examining the effects of a moderate-intensity home-based functional exercise intervention on cognition and function in individuals with dementia. Diss Abstr Int. 2016;76(12-A(E)):No Pagination Specified. PMID: None.
308 Lamb SE, Sheehan B, Atherton N, . Dementia And Physical Activity (DAPA) trial of moderate to high intensity exercise training for people with dementia: randomised controlled trial. BMJ. 2018;361:K1675. PMID: 29769247. 10.1136/bmj.k1675 29769247
309 Blumenthal JA, Smith PJ, Mabe S, . Lifestyle and neurocognition in older adults with cognitive impairments: A randomized trial. Neurology. 2018. PMID: 30568005. 10.1212/WNL.0000000000006784 30568005
310 Ho RTH, Fong TCT, Chan WC, . Psychophysiological effects of Dance Movement Therapy and physical exercise on older adults with mild dementia: A randomized controlled trial. J Gerontol B Psychol Sci Soc Sci. 2018. PMID: 30496547. 10.1093/geronb/gby145 30496547
311 Siu MY, Lee DTF. Effects of tai chi on cognition and instrumental activities of daily living in community dwelling older people with mild cognitive impairment. BMC Geriatr. 2018;18(1):37. PMID: 29394884. 10.1186/s12877-018-0720-8 29394884
312 Karssemeijer EGA, Aaronson JA, Bossers WJR, . The quest for synergy between physical exercise and cognitive stimulation via exergaming in people with dementia: a randomized controlled trial. Alzheimers Res Ther. 2019;11(1):3. PMID: 30611286. 10.1186/s13195-018-0454-z 30611286
313 Bellantonio S, Kenny AM, Fortinsky RH, . Efficacy of a geriatrics team intervention for residents in dementia-specific assisted living facilities: effect on unanticipated transitions. J Am Geriatr Soc. 2008;56(3):523–8. PMID: 18179497. 10.1111/j.1532-5415.2007.01591.x 18179497
314 Burgener SC, Yang Y, Gilbert R, . The effects of a multimodal intervention on outcomes of persons with early-stage dementia. Am J Alzheimers Dis Other Demen. 2008;23(4):382–94. PMID: 18453642. 10.1177/1533317508317527 18453642
315 Wolfs CAG, Kessels A, Dirksen CD, . Integrated multidisciplinary diagnostic approach for dementia care: Randomised controlled trial. Br J Psychiatry. 2008;192(4):300–5. PMID: 18378994. 10.1192/bjp.bp.107.035204 18378994
316 Quinn C, Toms G, Jones C, . A pilot randomized controlled trial of a self-management group intervention for people with early-stage dementia (The SMART study). Int Psychogeriatr. 2016;28(5):787–800. PMID: 26674087. 10.1017/S1041610215002094 26674087
317 Marshall A, Spreadbury J, Cheston R, . A pilot randomised controlled trial to compare changes in quality of life for participants with early diagnosis dementia who attend a ‘Living Well with Dementia’ group compared to waiting-list control. Aging Ment Health. 2015;19(6):526–35. PMID: 25196239. 10.1080/13607863.2014.954527 25196239
318 Jha A, Jan F, Gale T, . Effectiveness of a recovery-orientated psychiatric intervention package on the wellbeing of people with early dementia: a preliminary randomised controlled trial. Int J Geriatr Psychiatry. 2013;28(6):589–96. PMID: 22847712. 10.1002/gps.3863 22847712
319 Richard E, Kuiper R, Dijkgraaf MG, . Vascular care in patients with Alzheimer’s disease with cerebrovascular lesions-a randomized clinical trial. J Am Geriatr Soc. 2009;57(5):797–805. PMID: 19484836.19484836
320 Rovner BW, Casten RJ, Hegel MT, . Preventing Cognitive Decline in Black Individuals With Mild Cognitive Impairment: A Randomized Clinical Trial. JAMA Neurol. 2018. PMID: 30208380. 10.1001/jamaneurol.2018.2513 30208380
321 Train the Brain Consortium. Randomized trial on the effects of a combined physical/cognitive training in aged MCI subjects: the Train the Brain study. Sci. 2017;7:39471. PMID: 28045051. 10.1038/srep39471 28045051
322 Bae S, Lee S, Lee S, . The effect of a multicomponent intervention to promote community activity on cognitive function in older adults with mild cognitive impairment: A randomized controlled trial. Complement Ther Med. 2019;42:164–9. PMID: 30670238. 10.1016/j.ctim.2018.11.011 30670238
323 Shimada H, Makizako H, Doi T, . Effects of Combined Physical and Cognitive Exercises on Cognition and Mobility in Patients With Mild Cognitive Impairment: A Randomized Clinical Trial. J Am Med Dir Assoc. 2018;19(7):584–91. PMID: 29153754. 10.1016/j.jamda.2017.09.019 29153754
324 Straubmeier M, Behrndt E-M, Seidl H, . Non-pharmacological treatment in people with cognitive impairment: Results from the randomized controlled German Day Care Study. Dtsch. 2017;114(48):815–21. PMID: 29249224. 10.3238/arztebl.2017.0815 29249224
325 Bahar-Fuchs A, Clare L, Woods B. Cognitive training and cognitive rehabilitation for mild to moderate Alzheimer’s disease and vascular dementia. Cochrane Database of Systematic Reviews. 2013(6). PMID: 23924584. 10.1002/14651858.CD003260.pub2 23924584
326 Woods B, Aguirre E, Spector AE, . Cognitive stimulation to improve cognitive functioning in people with dementia. Cochrane Database of Systematic Reviews. 2012(2):CD005562. PMID: 22336813. 10.1002/14651858.CD005562.pub2 22336813
327 Barnes CJ, Markham C. A pilot study to evaluate the effectiveness of an individualized and cognitive behavioural communication intervention for informal carers of people with dementia: The Talking Sense programme. Int J Lang Commun Disord. 2018;53(3):615–27. PMID: 29460337. 10.1111/1460-6984.12375 29460337
328 Belle SH, Burgio L, Burns R, . Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial.[Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I39; PMID: 17116914]. Ann Int Med. 2006;145(10):727–38. PMID: 17116917. 10.7326/0003-4819-145-10-200611210-00005 17116917
329 Berwig M, Heinrich S, Spahlholz J, . Individualized support for informal caregivers of people with dementia - effectiveness of the German adaptation of REACH II. BMC Geriatr. 2017;17(1):286. PMID: 29233097. 10.1186/s12877-017-0678-y 29233097
330 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer’s disease. Nurs Res. 1995;44(3):166–72. PMID: 7761293. 10.1097/00006199-199505000-00007 7761293
331 Bruvik FK, Allore HG, Ranhoff AH, . The effect of psychosocial support intervention on depression in patients with dementia and their family caregivers: an assessor-blinded randomized controlled trial. Dement Geriatr Cogn Dis Extra. 2013;3(1):386–97. PMID: 24348500. 10.1159/000355912 24348500
332 Burgio L, Stevens A, Guy D, . Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. 2003;43(4):568–79. PMID: 12937335.12937335
333 Chang BL. Cognitive-behavioral intervention for homebound caregivers of persons with dementia. Nurs Res. 1999;48(3):173–82. PMID: 10337848. 10.1097/00006199-199905000-00007 10337848
334 Chu H, Yang CY, Liao YH, . The effects of a support group on dementia caregivers’ burden and depression. J Aging Health. 2011;23(2):228–41. PMID: 20847363. 10.1177/0898264310381522 20847363
335 Coon DW, Thompson L, Steffen A, . Anger and depression management: psychoeducational skill training interventions for women caregivers of a relative with dementia. Gerontologist. 2003;43(5):678–89. PMID: 14570964. 10.1093/geront/43.5.678 14570964
336 Cristancho-Lacroix V, Wrobel J, Cantegreil-Kallen I, . A web-based psychoeducational program for informal caregivers of patients with Alzheimer’s disease: a pilot randomized controlled trial. J Med Internet Res. 2015;17(5):e117. PMID: 25967983. 10.2196/jmir.3717 25967983
337 De Rotrou J, Cantegreil I, Faucounau V, . Do patients diagnosed with Alzheimer’s disease benefit from a psycho-educational programme for family caregivers? A randomised controlled study. Int J Geriatr Psychiatry. 2011;26(8):833–42. PMID: 20922772. 10.1002/gps.2611 20922772
338 Ducharme FC, Levesque LL, Lachance LM, . “Learning to become a family caregiver” efficacy of an intervention program for caregivers following diagnosis of dementia in a relative. Gerontologist. 2011;51(4):484–94. PMID: 21383112. 10.1093/geront/gnr014 21383112
339 Duggleby W, Ploeg J, McAiney C, . Web-Based Intervention for Family Carers of Persons with Dementia and Multiple Chronic Conditions (My Tools 4 Care): Pragmatic Randomized Controlled Trial. J Med Internet Res. 2018;20(6):e10484. PMID: 29959111. 10.2196/10484 29959111
340 Finkel S, Czaja SJ, Schulz R, . E-care: a telecommunications technology intervention for family caregivers of dementia patients. Am J Geriatr Psychiatry. 2007;15(5):443–8. PMID: 17463195. 10.1097/JGP.0b013e3180437d87 17463195
341 Fung W, Chien W. The effectiveness of a mutual support group for family caregivers of a relative with dementia. Arch Psychiatr Nurs. 2002;16(3):134–44. PMID: 12037799. 10.1053/apnu.2002.32951 12037799
342 Gallagher-Thompson D, Coon DW, Solano N, . Change in indices of distress among Latino and Anglo female caregivers of elderly relatives with dementia: site-specific results from the REACH national collaborative study. Gerontologist. 2003;43(4):580–91. PMID: 12937336. 10.1093/geront/43.4.580 12937336
343 Gallagher-Thompson D, Gray HL, Dupart T, . Effectiveness of cognitive/behavioral small group intervention for reduction of depression and stress in non-Hispanic White and Hispanic/Latino women dementia family caregivers: Outcomes and mediators of change. J Ration Emot Cogn Behav Ther. 2008;26(4):286–303. PMID: 25067886. 10.1007/s10942-008-0087-4 25067886
344 Gallagher-Thompson D, Wang PC, Liu W, . Effectiveness of a psychoeducational skill training DVD program to reduce stress in Chinese American dementia caregivers: results of a preliminary study. Aging Ment Health. 2010;14(3):263–73. PMID: 20425645. 10.1080/13607860903420989 20425645
345 Garand L, Rinaldo DE, Alberth MM, . Effects of problem solving therapy on mental health outcomes in family caregivers of persons with a new diagnosis of mild cognitive impairment or early dementia: a randomized controlled trial. Am J Geriatr Psychiatry. 2014;22(8):771–81. PMID: 24119856. 10.1016/j.jagp.2013.07.007 24119856
346 Gaugler JE, Reese M, Mittelman MS. Effects of the NYU caregiver intervention-adult child on residential care placement. Gerontologist. 2013;53(6):985–97. PMID: 23339050. 10.1093/geront/gns193 23339050
347 Gitlin LN, Corcoran M, Winter L, . A randomized, controlled trial of a home environmental intervention: effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. 2001;41(1):4–14. PMID: 11220813. 10.1093/geront/41.1.4 11220813
348 Gitlin LN, Winter L, Burke J, . Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: a randomized pilot study. Am J Geriatr Psychiatry. 2008;16(3):229–39. PMID: 18310553. 10.1097/JGP.0b013e318160da72 18310553
349 Gitlin LN, Winter L, Corcoran M, . Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. 2003;43(4):532–46. PMID: 12937332. 10.1093/geront/43.4.532 12937332
350 Gitlin LN, Winter L, Dennis MP, . Targeting and managing behavioral symptoms in individuals with dementia: a randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. 2010;58(8):1465–74. PMID: 20662955. 10.1111/j.1532-5415.2010.02971.x 20662955
351 Graff MJ, Vernooij-Dassen MJ, Thijssen M, . Community based occupational therapy for patients with dementia and their care givers: randomised controlled trial. BMJ. 2006;333(7580):1196. PMID: 17114212. 10.1136/bmj.39001.688843.BE 17114212
352 Hebert R, Levesque L, Vezina J, . Efficacy of a psychoeducative group program for caregivers of demented persons living at home: a randomized controlled trial. J Gerontol B Psychol Sci Soc Sci. 2003;58(1):S58–S67. PMID: 12496309. 10.1093/geronb/58.1.S58 12496309
353 Hepburn KW, Lewis M, Narayan S, . Partners in Caregiving: A Psychoeducation Program Affecting Dementia Family Caregivers’ Distress and Caregiving Outlook. Clin Gerontol. 2005;29(1):53–69. PMID: None. 10.1300/J018v29n01_05
354 Joling KJ, van Marwijk HW, Smit F, . Does a family meetings intervention prevent depression and anxiety in family caregivers of dementia patients? A randomized trial. PLoS One. 2012;7(1):e30936. PMID: 22303473. 10.1371/journal.pone.0030936 22303473
355 Judge KS, Yarry SJ, Looman WJ, . Improved Strain and Psychosocial Outcomes for Caregivers of Individuals with Dementia: Findings from Project ANSWERS. Gerontologist. 2013;53(2):280–92. PMID: 22899427. 10.1093/geront/gns076 22899427
356 Koivisto AM, Hallikainen I, Valimaki T, . Early psychosocial intervention does not delay institutionalization in persons with mild Alzheimer disease and has impact on neither disease progression nor caregivers’ well-being: ALSOVA 3-year follow-up. Int J Geriatr Psychiatry. 2016;31(3):273–83. PMID: 26177825. 10.1002/gps.4321 26177825
357 Kurz A, Wagenpfeil S, Hallauer J, . Evaluation of a brief educational program for dementia carers: the AENEAS study. Int J Geriatr Psychiatry. 2010;25(8):861–9. PMID: 19946869. 10.1002/gps.2428 19946869
358 Kwok T, Wong B, Ip I, . Telephone-delivered psychoeducational intervention for Hong Kong Chinese dementia caregivers: a single-blinded randomized controlled trial. Clin Interv Aging. 2013;8:1191–7. PMID: 24072965. 10.2147/CIA.S48264 24072965
359 Laakkonen ML, Kautiainen H, Holtta E, . Effects of Self-Management Groups for People with Dementia and Their Spouses--Randomized Controlled Trial. J Am Geriatr Soc. 2016;64(4):752–60. PMID: 27060101. 10.1111/jgs.14055 27060101
360 Livingston G, Barber J, Rapaport P, . Clinical effectiveness of a manual based coping strategy programme (START, STrAtegies for RelaTives) in promoting the mental health of carers of family members with dementia: pragmatic randomised controlled trial. BMJ. 2013;347:f6276. PMID: 24162942. 10.1136/bmj.f6276 24162942
361 Losada A, Marquez-Gonzalez M, Romero-Moreno R. Mechanisms of action of a psychological intervention for dementia caregivers: effects of behavioral activation and modification of dysfunctional thoughts. Int J Geriatr Psychiatry 2010:1119–27. PMID: 21061414. 10.1002/gps.2648 21061414
362 Marriott A, Donaldson C, Tarrier N, . Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer’s disease. Br J Psychiatry. 2000;176:557–62. PMID: 10974962. 10.1192/bjp.176.6.557 10974962
363 Martin-Carrasco M, Dominguez-Panchon AI, Gonzalez-Fraile E, . Effectiveness of a psychoeducational intervention group program in the reduction of the burden experienced by caregivers of patients with dementia: the EDUCA-II randomized trial. Alzheimer Dis Assoc Disord. 2014;28(1):79–87. PMID: 24113563. 10.1097/WAD.0000000000000003 24113563
364 Martin-Carrasco M, Martin MF, Valero CP, . Effectiveness of a psychoeducational intervention program in the reduction of caregiver burden in Alzheimer’s disease patients’ caregivers. Int J Geriatr Psychiatry. 2009;24(5):489–99. PMID: 18949763. 10.1002/gps.2142 18949763
365 Martin-Cook K, Davis BA, Hynan LS, . A randomized, controlled study of an Alzheimer’s caregiver skills training program. Am J Alzheimers Dis Other Demen. 2005;20(4):204–10. PMID: 16136843. 10.1177/153331750502000411 16136843
366 Martindale-Adams J, Nichols LO, Burns R, . A trial of dementia caregiver telephone support. The Canadian journal of nursing research = Revue canadienne de recherche en sciences infirmieres. 2013;45(4):30–48. PMID: 24617278. 10.1177/084456211304500404 24617278
367 Mittelman MS, Roth DL, Coon DW, . Sustained benefit of supportive intervention for depressive symptoms in caregivers of patients with Alzheimer’s disease. Am J Psychiatry. 2004;161(5):850–6. PMID: 15121650. 10.1176/appi.ajp.161.5.850 15121650
368 Nunez-Naveira L, Alonso-Bua B, de Labra C, . UnderstAID, an ICT Platform to Help Informal Caregivers of People with Dementia: A Pilot Randomized Controlled Study. Biomed Res Int. 2016;2016:5726465. PMID: 28116300. 10.1155/2016/5726465 28116300
369 Ostwald SK, Hepburn KW, Caron W, . Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. 1999;39(3):299–309. PMID: 10396888. 10.1093/geront/39.3.299 10396888
370 Roberts J, Browne G, Milne C, . Problem-solving counseling for caregivers of the cognitively impaired: effective for whom? Nurs Res. 1999;48(3):162–72. PMID: 10337847.10337847
371 Schoenmakers B, Buntinx F, DeLepeleire J. Supporting family carers of community-dwelling elder with cognitive decline: a randomized controlled trial. Int J Family Med. 2010;2010:184152. PMID: 22332005. 10.1155/2010/184152 22332005
372 Spalding-Wilson KN, Guzman-Velez E, Angelica J, . A novel two-day intervention reduces stress in caregivers of persons with dementia. Alzheimers Dement (N Y). 2018;4:450–60. PMID: 30258974. 10.1016/j.trci.2018.08.004 30258974
373 Steffen AM, Gant JR. A telehealth behavioral coaching intervention for neurocognitive disorder family carers. Int J Geriatr Psychiatry. 2016;31(2):195–203. PMID: 26077904. 10.1002/gps.4312 26077904
374 Teri L, McCurry SM, Logsdon R, . Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. 2005;45(6):802–11. PMID: 16326662. 10.1093/geront/45.6.802 16326662
375 Tremont G, Davis JD, Papandonatos GD, . Psychosocial telephone intervention for dementia caregivers: A randomized, controlled trial. Alzheimers Dement. 2015;11(5):541–8. PMID: 25074341. 10.1016/j.jalz.2014.05.1752 25074341
376 Ulstein ID, Sandvik L, Wyller TB, . A one-year randomized controlled psychosocial intervention study among family carers of dementia patients--effects on patients and carers. Dement Geriatr Cogn Dis Extra. 2007;24(6):469–75. PMID: 17986818. 10.1159/000110740 17986818
377 Voigt-Radloff S, Graff M, Leonhart R, . A multicentre RCT on community occupational therapy in Alzheimer’s disease: 10 sessions are not better than one consultation. BMJ Open. 2011;1(1):e000096. PMID: 22021760. 10.1136/bmjopen-2011-000096 22021760
378 Waldorff FB, Buss DV, Eckermann A, . Efficacy of psychosocial intervention in patients with mild Alzheimer’s disease: the multicentre, rater blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ. 2012;345:e4693. PMID: 22807076. 10.1136/bmj.e4693 22807076
379 Wang L-Q, Chien W-T. Randomised controlled trial of a family-led mutual support programme for people with dementia. Journal of clinical nursing. 2011;20(15–16):2362–6. PMID: 21752121. 10.1111/j.1365-2702.2011.03746.x 21752121
380 Williams VP, Bishop-Fitzpatrick L, Lane JD, . Video-based coping skills to reduce health risk and improve psychological and physical well-being in Alzheimer’s disease family caregivers. Psychosom Med. 2010;72(9):897–904. PMID: 20978227. 10.1097/PSY.0b013e3181fc2d09 20978227
381 Wilz G, Soellner R. Evaluation of a Short-Term Telephone-Based Cognitive Behavioral Intervention for Dementia Family Caregivers. Clin Gerontol. 2016;39(1):25–47. PMID: None. 10.1080/07317115.2015.1101631
382 Wilz G, Reder M, Meichsner F, . The Tele.TAnDem Intervention: Telephone-based CBT for Family Caregivers of People With Dementia. Gerontologist. 2018;58(2):e118–e29. PMID: 29190357. 10.1093/geront/gnx183 29190357
383 Wright LK, Litaker M, Laraia MT, . Continuum of care for Alzheimer’s disease: a nurse education and counseling program. Issues Ment Health Nurs. 2001;22(3):231–52. PMID: 11885210. 10.1080/01612840117980 11885210
384 Bass DM, Clark PA, Looman WJ, . The Cleveland Alzheimer’s managed care demonstration: outcomes after 12 months of implementation. Gerontologist. 2003;43(1):73–85. PMID: 12604748. 10.1093/geront/43.1.73 12604748
385 Callahan CM, Boustani MA, Unverzagt FW, . Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. 2006;295(18):2148–57. PMID: 16684985. 10.1001/jama.295.18.2148 16684985
386 Chien WT, Lee IY. Randomized controlled trial of a dementia care programme for families of home-resided older people with dementia. J Adv Nurs. 2011;67(4):774–87. PMID: 21198803. 10.1111/j.1365-2648.2010.05537.x 21198803
387 Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. 2008;59(4):433–6. PMID: 18378844. 10.1176/ps.2008.59.4.433 18378844
388 Chu P, Edwards J, Levin R, . The use of clinical case management for early state Alzheimer’s patients and their families. Am J Alzheimers Dis Other Demen. 2000;15(5):284–90. PMID: None. 10.1177/153331750001500506
389 Eloniemi-Sulkava U, Notkola IL, Hentinen M, . Effects of supporting community-living demented patients and their caregivers: a randomized trial. J Am Geriatr Soc. 2001;49(10):1282–7. PMID: 11890485. 10.1046/j.1532-5415.2001.49255.x 11890485
390 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen ML, . Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. 2009;57(12):2200–8. PMID: 20121986. 10.1111/j.1532-5415.2009.02564.x 20121986
391 Fortinsky RH, Kulldorff M, Kleppinger A, . Dementia care consultation for family caregivers: collaborative model linking an Alzheimer’s association chapter with primary care physicians. Aging Ment Health. 2009;13(2):162–70. PMID: 19347683. 10.1080/13607860902746160 19347683
392 Jansen AP, van Hout HP, Nijpels G, . Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: A randomized clinical trial. Int J Nurs Stud. 2011;48(8):933–43. PMID: 21356537. 10.1016/j.ijnurstu.2011.02.004 21356537
393 Lam LC, Lee JS, Chung JC, . A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. 2010;25(4):395–402. PMID: 19606455. 10.1002/gps.2352 19606455
394 Mavandadi S, Wright EM, Graydon MM, . A randomized pilot trial of a telephone-based collaborative care management program for caregivers of individuals with dementia. Psychol Serv. 2017;14(1):102–11. PMID: 28134558. 10.1037/ser0000118 28134558
395 Meeuwsen EJ, Melis RJ, Van Der Aa GC, . Effectiveness of dementia follow-up care by memory clinics or general practitioners: randomised controlled trial. BMJ. 2012;344:e3086. PMID: 22589500. 10.1136/bmj.e3086 22589500
396 Menn P, Holle R, Kunz S, . Dementia care in the general practice setting: a cluster randomized trial on the effectiveness and cost impact of three management strategies. Value Health. 2012;15(6):851–9. PMID: 22999135. 10.1016/j.jval.2012.06.007 22999135
397 Samus QM, Johnston D, Black BS, . A multidimensional home-based care coordination intervention for elders with memory disorders: the maximizing independence at home (MIND) pilot randomized trial. Am J Geriatr Psychiatry. 2014;22(4):398–414. PMID: 24502822. 10.1016/j.jagp.2013.12.175 24502822
398 Thyrian JR, Hertel J, Wucherer D, . Effectiveness and Safety of Dementia Care Management in Primary Care: A Randomized Clinical Trial. JAMA Psychiatry. 2017;74(10):996–1004. PMID: 28746708. 10.1001/jamapsychiatry.2017.2124 28746708
399 Vickrey BG, Mittman BS, Connor KI, . The effect of a disease management intervention on quality and outcomes of dementia care: a randomized, controlled trial. Ann Int Med. 2006;145(10):713–26. PMID: 17116916. 10.7326/0003-4819-145-10-200611210-00004 17116916
400 Xiao LD, De Bellis A, Kyriazopoulos H, . The Effect of a Personalized Dementia Care Intervention for Caregivers From Australian Minority Groups. Am J Alzheimers Dis Other Demen. 2016;31(1):57–67. PMID: 25805891. 10.1177/1533317515578256 25805891
401 Charlesworth G, Shepstone L, Wilson E, . Befriending carers of people with dementia: randomised controlled trial. BMJ. 2008;336(7656):1295–7. PMID: 18505757. 10.1136/bmj.39549.548831.AE 18505757
402 Connell CM, Janevic MR. Effects of a telephone-based exercise intervention for dementia caregiving wives: A randomized controlled trial. J Appl Gerontol. 2009;28(2):171–94. PMID: 21709757. 10.1177/0733464808326951 21709757
403 Gitlin LN, Arthur P, Piersol C, . Targeting Behavioral Symptoms and Functional Decline in Dementia: A Randomized Clinical Trial. J Am Geriatr Soc. 2018;66(2):339–45. PMID: 29192967. 10.1111/jgs.15194 29192967
404 Hirano A, Suzuki Y, Kuzuya M, . Influence of regular exercise on subjective sense of burden and physical symptoms in community-dwelling caregivers of dementia patients: a randomized controlled trial. Arch Gerontol Geriatr. 2011;53(2):e158–e63. PMID: 20850878. 10.1016/j.archger.2010.08.004 20850878
405 King AC, Baumann K, O’Sullivan P, . Effects of Moderate-Intensity Exercise on Physiological, Behavioral, and Emotional Responses to Family Caregiving. J Gerontol A Biol Sci Med Sci. 2002;57(1):M26–M36. PMID: 11773209. 10.1093/gerona/57.1.M26 11773209
406 Leach M, Francis A, Ziaian T. Transcendental Meditation for the improvement of health and wellbeing in community-dwelling dementia caregivers : a randomised wait-list controlled trial. BMC Complement Altern Med. 2015;15:145. PMID: 25952550. 10.1186/s12906-015-0666-8 25952550
407 LoGiudice D, Waltrowicz W, Brown K, . Do memory clinics improve the quality of life of carers? A randomized pilot trial. Int J Geriatr Psychiatry. 1999;14(8):626–32. PMID: 10489653. 10.1002/(SICI)1099-1166(199908)14:8<626::AID-GPS990>3.0.CO;2-5 10489653
408 Nourhashemi F, Andrieu S, Gillette-Guyonnet S, . Effectiveness of a specific care plan in patients with Alzheimer’s disease: cluster randomised trial (PLASA study). BMJ. 2010;340:c2466. PMID: 20522656. 10.1136/bmj.c2466 20522656
409 Pillemer K, Jill SJ. Peer support for Alzheimer’s caregivers: Is it enough to make a difference? Res Aging. 2002;24(2):171–92. PMID: None. 10.1177/0164027502242001
410 Prick AE, de Lange J, Twisk J, . The effects of a multi-component dyadic intervention on the psychological distress of family caregivers providing care to people with dementia: a randomized controlled trial. Int Psychogeriatr. 2015;27(12):2031–44. PMID: 26004290. 10.1017/S104161021500071X 26004290
411 Spijker A, Wollersheim H, Teerenstra S, . Systematic care for caregivers of patients with dementia: a multicenter, cluster-randomized, controlled trial. Am J Geriatr Psychiatry. 2011:521–31. PMID: 21358385. 10.1097/JGP.0b013e3182110599 21358385
412 Teri L, Gibbons LE, McCurry SM, . Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. JAMA. 2003;290(15):2015–22. PMID: 14559955. 10.1001/jama.290.15.2015 14559955
413 Winter L, Gitlin LN. Evaluation of a telephone-based support group intervention for female caregivers of community-dwelling individuals with dementia. Am J Alzheimers Dis Other Demen. 2006;21(6):391–7. PMID: 17267370. 10.1177/1533317506291371 17267370
414 Kuo LM, Huang HL, Huang HL, . A home-based training program improves Taiwanese family caregivers’ quality of life and decreases their risk for depression: a randomized controlled trial. Int J Geriatr Psychiatry. 2013;28(5):504–13. PMID: 22778053. 10.1002/gps.3853 22778053
415 National Institute on Aging, National Institutes of Health, US Department of Health & Human Services. Dementia Resources for Health Professionals: Assessing Cognitive Impairment in Older Patients. https://www.nia.nih.gov/health/assessing-cognitive-impairment-older-patients. Accessed December 3, 2018.
416 Prince M, Bryce R, Ferri C, . World Alzheimer Report 2011: The benefits of early diagnosis and intervention. https://www.alz.co.uk/research/WorldAlzheimerReport2011.pdf. Accessed December 5, 2018.
417 Martin S, Kelly S, Khan A, . Attitudes and preferences towards screening for dementia: a systematic review of the literature. BMC Geriatr. 2015;15:66. PMID: 26076729. 10.1186/s12877-015-0064-6 26076729
418 Borson S, Frank L, Bayley PJ, . Improving dementia care: the role of screening and detection of cognitive impairment. Alzheimers Dement. 2013;9(2):151–9. PMID: 23375564. 10.1016/j.jalz.2012.08.008 23375564
419 Le Couteur DG, Doust J, Creasey H, . Political drive to screen for pre-dementia: not evidence based and ignores the harms of diagnosis. BMJ. 2013;347:f5125. PMID: 24018000.24018000
420 Bunn F, Goodman C, Sworn K, . Psychosocial factors that shape patient and carer experiences of dementia diagnosis and treatment: a systematic review of qualitative studies. PLoS Med. 2012;9(10):e1001331. PMID: 23118618. 10.1371/journal.pmed.1001331 23118618
421 Boustani MA, Justiss MD, Frame A, . Caregiver and noncaregiver attitudes toward dementia screening. J Am Geriatr Soc. 2011;59(4):681–6. PMID: 21438862. 10.1111/j.1532-5415.2011.03327.x 21438862
422 Holsinger T, Boustani M, Abbot D, . Acceptability of dementia screening in primary care patients. Int J Geriatr Psychiatry. 2011;26(4):373–9. PMID: 20845398. 10.1002/gps.2536 20845398
423 Boustani M, Callahan CM, Unverzagt FW, . Implementing a screening and diagnosis program for dementia in primary care. J Gen Intern Med. 2005;20(7):572–7. PMID: 16050849.16050849
424 Fowler NR, Frame A, Perkins AJ, . Traits of patients who screen positive for dementia and refuse diagnostic assessment. Alzheimers Dement (Amst). 2015;1(2):236–41. PMID: 26258162. 10.1016/j.dadm.2015.01.002 26258162
425 Stites SD, Karlawish J, Harkins K, . Awareness of Mild Cognitive Impairment and Mild Alzheimer’s Disease Dementia Diagnoses Associated With Lower Self-Ratings of Quality of Life in Older Adults. J Gerontol B Psychol Sci Soc Sci. 2017;72(6):974–85. PMID: 28958089. 10.1093/geronb/gbx100 28958089
426 Lineweaver TT, Bondi MW, Galasko D, . Effect of knowledge of APOE genotype on subjective and objective memory performance in healthy older adults. Am J Psychiatry. 2014;171(2):201–8. PMID: 24170170. 10.1176/appi.ajp.2013.12121590 24170170
427 Eichler T, Thyrian JR, Hertel J, . Patient Variables Associated with the Assignment of a Formal Dementia Diagnosis to Positively Screened Primary Care Patients. Curr Alzheimer Res. 2017. PMID: 28891445. 10.2174/1567205014666170908095707 28891445
428 Mormont E, Jamart J, Jacques D. Symptoms of depression and anxiety after the disclosure of the diagnosis of Alzheimer disease. J Geriatr Psychiatry Neurol. 2014;27(4):231–6. PMID: 24759087. 10.1177/0891988714532021 24759087
429 Lee SM, Roen K, Thornton A. The psychological impact of a diagnosis of Alzheimer’s disease. Dementia (London, England). 2014;13(3):289–305. PMID: 24339103. 10.1177/1471301213497080 24339103
430 Mate KE, Pond CD, Magin PJ, . Diagnosis and disclosure of a memory problem is associated with quality of life in community based older Australians with dementia. International Psychogeriatrics. 2012;24(12):196271. 10.1017/S1041610212001111
431 van den Dungen P, van Kuijk L, van Marwijk H, . Preferences regarding disclosure of a diagnosis of dementia: a systematic review. International Psychogeriatrics. 2014;26(10):1603–18. PMID: 24933479. 10.1017/S1041610214000969 24933479
432 Press D, Alexander M. Cholinesterase inhibitors in the treatment of dementia. DeKosky S, ed. Waltham, MA: UpToDate Inc. http://www.uptodate.com. Accessed December 4, 2018.
433 Gaugler JE, Mittelman MS, Hepburn K, . Clinically significant changes in burden and depression among dementia caregivers following nursing home admission. BMC Med. 2010;8:85. PMID: 21167022. 10.1186/1741-7015-8-85 21167022
434 Gaugler JE, Roth DL, Haley WE, . Can counseling and support reduce burden and depressive symptoms in caregivers of people with Alzheimer’s disease during the transition to institutionalization? Results from the New York University caregiver intervention study. J Am Geriatr Soc. 2008;56(3):421–8. PMID: 18179495.18179495
435 Tsoi KK, Chan JY, Hirai HW, . Cognitive Tests to Detect Dementia: A Systematic Review and Meta-analysis. JAMA Intern Med. 2015;175(9):1450–8. PMID: 26052687. 10.1001/jamainternmed.2015.2152 26052687
436 Tsoi KKF, Chan JYC, Hirai HW, . Recall Tests Are Effective to Detect Mild Cognitive Impairment: A Systematic Review and Meta-analysis of 108 Diagnostic Studies. J Am Med Dir Assoc. 2017;18(9):807.e17–.e29. PMID: 28754516. 10.1016/j.jamda.2017.05.016 28754516
437 Birks Jacqueline S, Grimley Evans J. Rivastigmine for Alzheimer’s disease. Cochrane Database of Systematic Reviews. 2015(4). PMID: 25858345. 10.1002/14651858.CD001191.pub3 25858345
438 Birks JS, Harvey RJ. Donepezil for dementia due to Alzheimer’s disease. The Cochrane database of systematic reviews. 2018;6:CD001190. PMID: 29923184. 10.1002/14651858.CD001190.pub3 29923184
439 Jiang D, Yang X, Li M, . Efficacy and safety of galantamine treatment for patients with Alzheimer’s disease: a meta-analysis of randomized controlled trials. J Neural Transm. 2015;122(8):1157–66. PMID: 25547862. 10.1007/s00702-014-1358-0 25547862
440 Jiang J, Jiang H. Efficacy and adverse effects of memantine treatment for Alzheimer’s disease from randomized controlled trials. Neurological Sciences. 2015;36(9):1633–41. PMID: 25899425. 10.1007/s10072-015-2221-2 25899425
441 Kobayashi H, Ohnishi T, Nakagawa R, . The comparative efficacy and safety of cholinesterase inhibitors in patients with mild-to-moderate Alzheimer’s disease: a Bayesian network meta-analysis. Int J Geriatr Psychiatry. 2016;31(8):892–904. PMID: 26680338. 10.1002/gps.4405 26680338
442 Strohle A, Schmidt DK, Schultz F, . Drug and Exercise Treatment of Alzheimer Disease and Mild Cognitive Impairment: A Systematic Review and Meta-Analysis of Effects on Cognition in Randomized Controlled Trials. Am J Geriatr Psychiatry. 2015;23(12):1234–49. PMID: 26601726. 10.1016/j.jagp.2015.07.007 26601726
443 Burckhardt M, Herke M, Wustmann T, . Omega-3 fatty acids for the treatment of dementia. Cochrane Database of Systematic Reviews. 2016;4:CD009002. PMID: 27063583. 10.1002/14651858.CD009002.pub3 27063583
444 Farina N, Llewellyn D, Isaac M, . Vitamin E for Alzheimer’s dementia and mild cognitive impairment. Cochrane Database of Systematic Reviews. 2017;4:CD002854. PMID: 28418065. 10.1002/14651858.CD002854.pub5 28418065
445 McGuinness B, Craig D, Bullock R, . Statins for the treatment of dementia. Cochrane Database of Systematic Reviews. 2014(7). 10.1002/14651858.CD007514.pub3
446 Miguel-Alvarez M, Santos-Lozano A, Sanchis-Gomar F, . Non-steroidal anti-inflammatory drugs as a treatment for Alzheimer’s disease: a systematic review and meta-analysis of treatment effect. Drugs & Aging. 2015;32(2):139–47. PMID: 25644018. 10.1007/s40266-015-0239-z 25644018
447 Forbes D, Forbes Scott C, Blake Catherine M, . Exercise programs for people with dementia. Cochrane Database of Systematic Reviews. 2015(4). PMID: 24302466. 10.1002/14651858.CD006489.pub4 24302466
448 Reilly S, Miranda-Castillo C, Malouf R, . Case management approaches to home support for people with dementia. Cochrane Database of Systematic Reviews. 2015(1). 10.1002/14651858.CD008345.pub2
449 Lins S, Hayder-Beichel D, Rücker G, . Efficacy and experiences of telephone counselling for informal carers of people with dementia. Cochrane Database of Systematic Reviews. 2014(9). 10.1002/14651858.CD009126.pub2
450 Liu Z, Sun YY, Zhong BL. Mindfulness-based stress reduction for family carers of people with dementia. The Cochrane database of systematic reviews. 2018;8:CD012791. PMID: 30106471. 10.1002/14651858.CD012791.pub2 30106471
451 Abrahams R, Liu KPY, Bissett M, . Effectiveness of interventions for co-residing family caregivers of people with dementia: Systematic review and meta-analysis. Aust Occup Ther J. 2018;65(3):208–24. PMID: 29527683. 10.1111/1440-1630.12464 29527683
452 Wray L, Wade M, Beehler G, . A program to improve detection of undiagnosed dementia in primary care and its association with healthcare utilization. Am J Geriatr Psychiatry. 2014;22(11):1282–91. PMID: 23954037. 10.1016/j.jagp.2013.04.018 23954037
453 Ziegler-Graham K, Brookmeyer R, Johnson E, . Worldwide variation in the doubling time of Alzheimer’s disease incidence rates. Alzheimers Dement. 2008;4(5):316–23. PMID: 18790458. 10.1016/j.jalz.2008.05.2479 18790458
454 Fitzpatrick AL, Kuller LH, Ives DG, . Incidence and prevalence of dementia in the Cardiovascular Health Study. J Am Geriatr Soc. 2004;52(2):195–204. PMID: 14728627. 10.1111/j.1532-5415.2004.52058.x 14728627
455 Cummings J, Lee G, Ritter A, . Alzheimer’s disease drug development pipeline: 2018. Alzheimers Dement (N Y). 2018;4:195–214. PMID: 29955663. 10.1016/j.trci.2018.03.009 29955663
456 Jack CR, Jr., Bennett DA, Blennow K, . NIA-AA Research Framework: Toward a biological definition of Alzheimer’s disease. Alzheimers Dement. 2018;14(4):535–62. PMID: 29653606. 10.1016/j.jalz.2018.02.018 29653606
457 US Department of Health and Human Services. PROMIS® (Patient-Reported Outcomes Measurement Information System). http://www.healthmeasures.net/explore-measurement-systems/promis. Accessed December 5, 2018.
458 Morley JE, Morris JC, Berg-Weger M, . Brain health: the importance of recognizing cognitive impairment: an IAGG consensus conference. J Am Med Dir Assoc. 2015;16(9):731–9. PMID: 26315321. 10.1016/j.jamda.2015.06.017 26315321
459 National Institute for Health Care and Excellence (NICE). Dementia: supporting people with dementia and their carers in health and social care. London (UK): National Institute for Health and Care Excellence: 2011. PMID: None.
460 Mao HF, Chang LH, Tsai AY, . Diagnostic accuracy of Instrumental Activities of Daily Living for dementia in community-dwelling older adults. Age Ageing. 2018. PMID: 29528375. 10.1093/ageing/afy021 29528375
461 Ranson JM, Kuźma E, Hamilton W, . Predictors of dementia misclassification when using brief cognitive assessments. Neurol Clin Pract. 2018;9(1):1–9. PMID: None. 10.1212/CPJ.0000000000000566
462 Gitlin LN, Winter L, Dennis MP, . A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. 2010;304(9):983–91. PMID: 20810376. 10.1001/jama.2010.1253 20810376
463 Mohs RC, Rosen WG, Davis KL. The Alzheimer’s disease assessment scale: an instrument for assessing treatment efficacy. Psychopharmacol Bull. 1983;19(3):448–50. PMID: 6635122.6635122
464 Rosen WG, Mohs RC, Davis KL. A new rating scale for Alzheimer’s disease. Am J Psychiatry. 1984;141(11):1356–64. PMID: 6496779. 10.1176/ajp.141.11.1356 6496779
465 Folstein MF, Folstein SE, McHugh PR. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. 1975;12(3):189–98. PMID: 1202204.1202204
466 Schneider LS, Olin JT, Doody RS, . Validity and reliability of the Alzheimer’s Disease Cooperative Study-Clinical Global Impression of Change. The Alzheimer’s Disease Cooperative Study. Alzheimer Dis Assoc Disord. 1997;11: Suppl 2:S22–32. PMID: 9236949.9236949
467 Morris JC. The Clinical Dementia Rating (CDR): current version and scoring rules. Neurology. 1993;43(11):2412–4. PMID: 8232972.8232972
468 Reisberg B, Ferris SH, de Leon MJ, . The Global Deterioration Scale for assessment of primary degenerative dementia. Am J Psychiatry. 1982;139(9):1136–9. PMID: 7114305. 10.1176/ajp.139.9.1136 7114305
469 Galasko D, Bennett D, Sano M, . An inventory to assess activities of daily living for clinical trials in Alzheimer’s disease. The Alzheimer’s Disease Cooperative Study. Alzheimer Dis Assoc Disord. 1997;11: Suppl 2:S33–9. PMID: 9236950.9236950
470 Gelinas I, Gauthier L, McIntyre M, . Development of a functional measure for persons with Alzheimer’s disease: the disability assessment for dementia. Am J Occup Ther. 1999;53(5):471–81. PMID: 10500855.10500855
471 Lawton MP, Brody EM. Assessment of older people: self-maintaining and instrumental activities of daily living. Gerontologist. 1969;9(3):179–86. PMID: 5349366.5349366
472 Alexopoulos GS, Abrams RC, Young RC, . Cornell Scale for Depression in Dementia. Biol Psychiatry. 1988;23(3):271–84. PMID: 3337862.3337862
473 Yesavage JA, Brink TL, Rose TL, . Development and validation of a geriatric depression screening scale: a preliminary report. J Psychiatr Res. 1982;17(1):37–49. PMID: 7183759.7183759
474 Cummings JL, Mega M, Gray K, . The Neuropsychiatric Inventory: comprehensive assessment of psychopathology in dementia. Neurology. 1994;44(12):2308–14. PMID: 7991117.7991117
475 Cummings JL. The Neuropsychiatric Inventory: assessing psychopathology in dementia patients. Neurology. 1997;48(5 Suppl 6):S10–6. PMID: 9153155.9153155
476 Teri L, Truax P, Logsdon R, . Assessment of behavioral problems in dementia: the revised memory and behavior problems checklist. Psychol Aging. 1992;7(4):622–31. PMID: 1466831.1466831
477 Radloff LS. The CES-D Scale: A Self-Report Depression Scale for Research in the General Population. Appl Psychol Meas. 1977;1(385–401). PMID: None. 10.1177/014662167700100306
478 Beck AT, Ward CH, Mendelson M, . An inventory for measuring depression. Arch Gen Psychiatry. 1961;4:561–71. PMID: 13688369.13688369
479 Zarit SH, Reever KE, Bach-Peterson J. Relatives of the impaired elderly: correlates of feelings of burden. Gerontologist. 1980;20(6):649–55. PMID: 7203086.7203086
480 Logsdon RG, Gibbons LE, McCurry SM, . Assessing quality of life in older adults with cognitive impairment. Psychosom Med. 2002;64(3):510–9. PMID: 12021425.12021425
481 Smith SC, Lamping DL, Banerjee S, . Measurement of health-related quality of life for people with dementia: development of a new instrument (DEMQOL) and an evaluation of current methodology. Health Technol Assess. 2005;9(10):1–93, iii–iv. PMID: 15774233.15774233
482 EuroQol G. EuroQol--a new facility for the measurement of health-related quality of life. Health Policy. 1990;16(3):199–208. PMID: 10109801.10109801
483 Hays RD, Sherbourne CD, Mazel RM. The RAND 36-Item Health Survey 1.0. Health Econ. 1993;2(3):217–27. PMID: 8275167.8275167