# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Elizabeth Eckstrom, MD, MPH, at Oregon Health & Science University and Mary Ganguli, MD, at the University of Pittsburgh for their content expertise and review of the draft report; Amy Sanders, MD, Deborah Barnes, PhD, Joseph Gaugler, PhD, and Parminder Raina, PhD, who provided expert review of the draft report; Marcel E. Salive, MD, Molly Wagster, PhD, and Nina Silverberg, PhD, at the National Institute on Aging and Jovier E. Evans, PhD, at the National Institute of Mental Health for providing federal review of our draft report; and Smyth Lai, MLS, Shannon Robalino, MLS, Elizabeth O’Connor, PhD, Denis Nyongesa, MS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.